# Appendix A Search Strategies

Database: Ovid MEDLINE(R) and Ovid OLDMEDLINE(R)

Search Strategy:

--------------------------------------------------------------------

1. exp Glasgow Coma Scale/ (7598)
2. exp Trauma Severity Indices/ (26320)
3. ((glasgow adj3 coma^*^) or tgcs or mgcs or gcs).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier] (17103)
4. 2 and 3 (8526)
5. 1 or 4 (8526)
6. exp Craniocerebral Trauma/ (133918)
7. (tbi or ((head or brain^*^ or cereb^*^ or crani^*^ or skull^*^) adj3 (injur^*^ or traum^*^ or wound^*^ or damag^*^))).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier] (136121)
8. 6 or 7 (196584)
9. exp Emergencies/ (35777)
10. exp Emergency Medical Services/ (105134)
11. (pre-hospital^*^ or prehospital or paramedic^*^ or emt or ems or emergency medical technician^*^ or ambulance^*^ or ((field^*^ or onsite or on-site or scene^*^ or accident^*^) adj5 triag^*^)).mp. (40109)
12. exp Emergency Treatment/ (100260)
13. exp emergency medicine/ (10629)
14. (pre-hospital^*^ or prehospital or paramedic^*^ or emt or ems or emergency medical technician^*^ or ambulance^*^ or ((field^*^ or onsite or on-site or scene^*^ or accident^*^) adj5 triag^*^)).mp. (40109)
15. exp accidents/ (152529)
16. (emergency or emergencies or triage or priorit^*^).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier] (302727)
17. 15 and 16 (13350)
18. 9 or 10 or 12 or 13 or 14 or 17 (249494)
19. 5 and 8 and 18 (990)
20. limit 19 to english language (889)
21. limit 19 to abstracts (928)
22. 20 or 21 (973)

Database: Ovid MEDLINE(R)

Search Strategy:

--------------------------------------------------------------------

1. exp Glasgow Coma Scale/ (7453)
2. exp Trauma Severity Indices/ (26003)
3. ((glasgow adj3 coma^*^) or tgcs or mgcs or gcs).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier] (16669)
4. 2 and 3 (8367)
5. 1 or 4 (8367)
6. exp “wounds and injuries”/ (764490)
7. exp accidents/ (153435)
8. exp violence/ (73131)
9. (tbi or ((head or brain^*^ or cereb^*^ or crani^*^ or skull^*^) adj3 (injur^*^ or traum^*^ or wound^*^ or damag^*^))).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier] (133113)
10. ((case^*^ or patient^*^ or triag^*^ or unconsciou^*^ or consciou^*^ or call^*^ or “911” or emergenc^*^) adj5 (injur^*^ or traum^*^ or wound^*^ or damag^*^ or hurt^*^)).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier] (158827)
11. 6 or 7 or 8 or 9 or 10 (1040851)
12. exp Emergencies/ (36151)
13. exp Emergency Medical Services/ (104345)
14. (pre-hospital^*^ or prehospital or paramedic^*^ or emt or ems or emergency medical technician^*^ or ambulance^*^ or ((field^*^ or onsite or on-site or scene^*^ or accident^*^) adj5 triag^*^)).mp. (39234)
15. exp Emergency Treatment/ (100137)
16. exp emergency medicine/ (10652)
17. (pre-hospital^*^ or prehospital or paramedic^*^ or emt or ems or emergency medical technician^*^ or ambulance^*^ or ((field^*^ or onsite or on-site or scene^*^ or accident^*^) adj5 triag^*^)).mp. (39234)
18. exp accidents/ (153435)
19. (emergency or emergencies or triage or priorit^*^).mp. [mp=title, abstract, original title, name of substance word, subject heading word, keyword heading word, protocol supplementary concept word, rare disease supplementary concept word, unique identifier] (297798)
20. 18 and 19 (13245)
21. 12 or 13 or 15 or 16 or 17 or 20 (248295)
22. 5 and 11 and 21 (1587)
23. limit 22 to english language (1444)
24. limit 22 to abstracts (1483)
25. 23 or 24 (1562)

Database: CINAHL

Search Strategy:

--------------------------------------------------------------------

1. (MH “Head Injuries+”) (29202)
2. (tbi or ((head or brain^*^ or cereb^*^ or crani^*^ or skull^*^) n3 (injur^*^ or traum^*^ or wound^*^ or damag^*^))) (31690)
3. 1 or 2 (38057)
4. (MH “Trauma Severity Indices+”) (10932)
5. ((glasgow n3 coma^*^) or tgcs or mgcs or gcs) (6372)
6. 4 or 5 (11,836)
7. (MH “Emergency Medical Services+”) (69526)
8. (MH “Emergency Medical Technicians”) or (MH “Emergency Medical Technician Attitudes”) (8776 )
9. (MH “Physicians, Emergency”) or (MH “Emergency Nurse Practitioners”) (2383)
10. (MH “Emergency Nursing”) (11557)
11. pre-hospital^*^ or prehospital or paramedic^*^ or emt or ems or emergency medical technician^*^ or ambulance^*^ (27129)
12. (emergency or emergencies or accident^*^) n5 (triage or priorit^*^ or classif^*^ or identif^*^) (2730)
13. 7 or 8 or 9 or 10 or 11 or 12 (90644)
14. 3 and 6 and 13 (774)

Database: CINAHL

Search Strategy:

--------------------------------------------------------------------

1. (MH “trauma+”) or (MH “wounds and injuries+”) or (MH “emergency patients+”) or (MH “accidents+”) or (MH “violence+”) (286638)
2. (tbi or ((head or brain^*^ or cereb^*^ or crani^*^ or skull^*^) n3 (injur^*^ or traum^*^ or wound^*^ or damag^*^))) (31922)
3. 1 or 2 (293880)
4. (MH “Trauma Severity Indices+”) (10983)
5. ((glasgow n3 coma^*^) or tgcs or mgcs or gcs) (6432)
6. 4 or 5 (11915)
7. (MH “Emergency Medical Services+”) (69734)
8. (MH “Emergency Medical Technicians”) or (MH “Emergency Medical Technician Attitudes”) (8800)
9. (MH “Physicians, Emergency”) or (MH “Emergency Nurse Practitioners”) (2395)
10. (MH “Emergency Nursing”) (11562)
11. pre-hospital^*^ or prehospital or paramedic^*^ or emt or ems or emergency medical technician^*^ or ambulance^*^ (27291)
12. (emergency or emergencies or accident^*^) n5 (triage or priorit^*^ or classif^*^ or identif^*^) (2762)
13. 7 or 8 or 9 or 10 or 11 or 12 (91020)
14. 3 and 6 and 13 (2364)

Database: EBM Reviews - Cochrane Central Register of Controlled Trials

Search Strategy:

---------------------------------------------------------

1. (injur^*^ or traum^*^ or wound^*^ or damag^*^).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (47806)
2. ((glasgow adj3 coma^*^) or tgcs or mgcs or gcs).mp. (1148)
3. ((traum^*^ or injur^*^) adj3 sever^*^ adj5 (rated or rating^*^ or scale^*^)).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (123)
4. 2 or 3 (1175)
5. (pre-hospital^*^ or prehospital or paramedic^*^ or emt or ems or emergency medical technician^*^ or ambulance^*^ or emergency or emergencies or accident^*^ or triage or priorit^*^ or classif^*^ or identif^*^).mp. [mp=title, original title, abstract, mesh headings, heading words, keyword] (125583)
6. 1 and 4 and 5 (217)

Database: EBM Reviews - Cochrane Database of Systematic Reviews

Search Strategy:

---------------------------------------------------------

1. (injur^*^ or traum^*^ or wound^*^ or damag^*^).mp. [mp=title, abstract, full text, keywords, caption text] (4650)
2. ((glasgow adj3 coma^*^) or tgcs or mgcs or gcs).mp. (88)
3. ((traum^*^ or injur^*^) adj3 sever^*^ adj5 (rated or rating^*^ or scale^*^)).mp. [mp=title, abstract, full text, keywords, caption text] (24)
4. 2 or 3 (97)
5. (pre-hospital^*^ or prehospital or paramedic^*^ or emt or ems or emergency medical technician^*^ or ambulance^*^ or emergency or emergencies or accident^*^ or triage or priorit^*^ or classif^*^ or identif^*^).mp. [mp=title, abstract, full text, keywords, caption text] (8818)
6. 1 and 4 and 5 (80)

Database: PsycINFO

Search Strategy:

---------------------------------------------------------

1. exp Traumatic Brain Injury/ (13891)
2. exp Head Injuries/ (5271)
3. exp trauma/ (59345)
4. exp accidents/ (11000)
5. exp violence/ (62018)
6. (tbi or ((head or brain^*^ or cereb^*^ or crani^*^ or skull^*^) adj3 (injur^*^ or traum^*^ or wound^*^ or damag^*^))).mp. (47797)
7. 1 or 2 or 3 or 4 or 5 or 6 (155040)
8. ((glasgow adj3 coma^*^) or tgcs or mgcs or gcs).mp. (4566)
9. ((traum^*^ or injur^*^) adj5 (critical^*^ or sever^*^ or threat^*^) adj7 (rat^*^ or scale^*^ or index^*^ or classif^*^ or identif^*^)).mp. [mp=title, abstract, heading word, table of contents, key concepts, original title, tests & measures] (1171)
10. 8 or 9 (5448)
11. exp Emergency Services/ (6316)
12. exp accidents/ (11000)
13. (pre-hospital^*^ or prehospital or paramedic^*^ or emt or ems or emergency medical technician^*^ or ambulance^*^ or ((field^*^ or onsite or on-site or scene^*^ or accident^*^) adj5 triag^*^)).mp. (2424)
14. (emergency or emergencies or triage or ((priorit^*^ or early or earlie^*^ or rapid^*^ or quick^*^ or swift^*^) adj5 (treat^*^ or therap^*^ or interven^*^ or interven^*^ or transport^*^ or procedur^*^))).mp. (60383)
15. 11 or 12 or 13 or 14 (72337)
16. 7 and 10 and 15 (546)

Database: Health and Psychosocial Instruments

Search Strategy:

---------------------------------------------------------

1. (tbi or ((head or brain^*^ or cereb^*^ or crani^*^ or skull^*^) adj3 (injur^*^ or traum^*^ or wound^*^ or damag^*^))).mp. (1769)
2. ((glasgow adj3 coma^*^) or tgcs or mgcs or gcs).mp. (329)
3. ((traum^*^ or injur^*^) adj3 sever^*^ adj5 (rated or rating^*^ or scale^*^)).mp. [mp=title, acronym, descriptors, measure descriptors, sample descriptors, abstract, source] (23)
4. 2 or 3 (350)
5. (pre-hospital^*^ or prehospital or paramedic^*^ or emt or ems or emergency medical technician^*^ or ambulance^*^ or ((field^*^ or onsite or on-site or scene^*^ or accident^*^) adj5 triag^*^)).mp. (96)
6. (emergency or emergencies or accident^*^ or triage or priorit^*^).mp. (1413)
7. 5 or 6 (1486)
8. 1 and 4 and 7 (8)
9. 4 and 7 (23)

Database: Health and Psychosocial Instruments

Search Strategy:

---------------------------------------------------------

1. (injur^*^ or traum^*^ or wound^*^ or damag^*^).mp. [mp=title, acronym, descriptors, measure descriptors, sample descriptors, abstract, source] (7032)
2. ((glasgow adj3 coma^*^) or tgcs or mgcs or gcs).mp. (330)
3. ((traum^*^ or injur^*^) adj3 sever^*^ adj5 (rated or rating^*^ or scale^*^)).mp. [mp=title, acronym, descriptors, measure descriptors, sample descriptors, abstract, source] (23)
4. 2 or 3 (351)
5. (pre-hospital^*^ or prehospital or paramedic^*^ or emt or ems or emergency medical technician^*^ or ambulance^*^ or emergency or emergencies or accident^*^ or triage or priorit^*^ or classif^*^ or identif^*^).mp. [mp=title, acronym, descriptors, measure descriptors, sample descriptors, abstract, source] (6531)
6. 1 and 4 and 5 (29)