# Abbreviations and Acronyms

Abbreviation: Definition
AHRQ: Agency for Healthcare Research and Quality
AIS: Abbreviated Injury Scale
AOR: Adjusted Odds Ratio
AUROC: Area Under the Receiver Operating Characteristic Curve
CCP: Critical Care Paramedic
CDC: Centers for Disease Control and Prevention
CER: Comparative Effectiveness Review
CI: Confidence Interval
CINAHL: Cumulative Index to Nursing and Allied Health Literature
CT: Computed Tomography
ED: Emergency Department
EMS: Emergency Medical Services
EMT: Emergency Medical Technician
GCS: Glasgow Coma Scale
HAPI: Health & Psychosocial Instruments
ICU: Intensive Care Unit
IQR: Interquartile Range
ISS: Injury Severity Score
KQ: Key Question
MEDLINE: Medical Literature Analysis and Retrieval System Online
mGCS: Motor Glasgow Coma Scale
n: Number
NHTSA: National Highway Traffic Safety Administration
NLR: Negative Likelihood Ratio
NPV: Negative Predictive Value
NR: Not Reported
NTDB: National Trauma Data Bank
OR: Odds Ratio
PENTA: Pediatric Trauma Registry
PICOTS: Populations, Interventions, Comparators, Outcomes, Timing, Types of Studies, and Setting
PLR: Positive Likelihood Ratio
PPV: Positive Predictive Values
QUADAS: Quality Assessment of Diagnostic Accuracy Studies
QUIPS: Quality in Prognostic Studies
RCT: Randomized Controlled Trial
SD: Standard Deviation
SMS: Simplified Motor Score
SOE: Strength of Evidence
TBI: Traumatic Brain Injury
TEP: Technical Expert Panel
tGCS: Total Glasgow Coma Scale
TX: Texas
U.S. and USA: United States of America
vs.: Versus