# Results

## Introduction

This section presents the findings of this systematic review, starting with the results of the literature searches and description of included studies. The findings for each Key Question (KQ) present an overview of the identified evidence, followed by key points and detailed results. Detailed results include a description of relevant studies, intermediate outcome findings, patient health and service utilization outcomes, risk of bias considerations (with rating presented in full in Appendix D), and strength of evidence grades for each study. KQ 1 studies are presented individually. We synthesized the results qualitatively rather than quantitatively because of high levels of heterogeneity in the number and types of strategy components, differences between the experimental and control arms (i.e., in some studies, a single component distinguished strategy and control arms, and in other studies, several components differed between arms), and outcomes assessed. We relied on author-reported measures of differences between groups and associated variances, but when these were not reported, we calculated differences and computed odds ratios (ORs) or mean differences, along with 95% confidence intervals (CIs) for between-arm comparisons.

Results of our searches appear in Figure 2. We reviewed 7,917 titles and abstracts dually and independently and identified 533 articles for full-text review. Because of the lack of standard terminology used to define the types of studies of interest to this review, we used a wide-ranging search strategy. As a result, many citations were not relevant, leading to a much smaller pool of included studies at the full-text review stage. We excluded 516 of these articles at the full-text review stage, leaving 17 articles representing 17 studies (one article reports on two different studies,^66^ and another two articles^67,68^ report outcomes for the same trial). Common reasons for exclusion included not meeting review criteria for population (i.e., not focusing on health care systems, organizations, or practitioners that provide mental health care for children and adolescents with mental health problems [n=242]), not meeting review criteria for comparator (i.e., not including a comparator [n=44]), not meeting review criteria for intervention (i.e., quality improvement [QI], implementation, and dissemination strategies [n=100]), not meeting review criteria for publication type (cross-sectional studies, nonsystematic reviews [n=57]), and not meeting review criteria for outcome (included only patient health outcomes or only intermediate outcomes for strategies not implementing an evidence-based practice [EBP] [n=40]).

Figure 2 Results of literature searches

Figure 2 is a flow chart that outlines the report’s retrieval and selection process. It begins with the total number of citations retrieved from the literature searches and ends with the number of studies that satisfied the inclusion criteria of the report. This figure is described further in the Section entitled “Results of Literature Search” as follows: “We reviewed 7,917 titles and abstracts dually and independently, and identified 533 articles for full-text review. 516 articles that were identified for full-text review were excluded for not meeting review criteria. Common reasons for exclusion included not meeting review criteria for population (i.e., not focusing on health care systems, organizations, or providers that provide mental health care for children and adolescents with mental health problems [n=242]), not meeting review criteria for comparator (n=44), not meeting review criteria for intervention (i.e., dissemination, implementation, or quality improvement strategies [n=100]), not meeting review criteria for publication type (n=57), and not meeting review criteria for outcome (n=40)”.

All full-text studies had a minimum of two independent reviewers, but for several studies, applying the inclusion/exclusion criteria consistently and reliably required multiple iterations of full-text review, often culminating in group discussions with the entire team to reach consensus. Our challenges arose from the process of applying consistent logic when encountering new or unanticipated “boundary” cases, the complexity of included studies, and the inadequacy of reporting in some instances. Several studies that were otherwise eligible were eventually excluded because they examined efficacy or effectiveness instead of the impact of a QI, implementation, or dissemination strategy.^69–73^ In other instances, we excluded studies otherwise eligible for having the wrong comparator: we could not distinguish the effects of the strategy of interest (QI, implementation, or dissemination) from the underlying EBP.^74–80^ We encountered strategies that used teachers and nonmental health care practitioners that we judged to be ineligible because they were not providers of mental health care.^81,82^ Some studies had relevant strategies but were directed at children who were at risk of but were not identified with mental health problems.^83^ One study also required contacting the authors to obtain additional details on the care received by usual-care participants, which was unclear in the published article.^74–77^ We did not identify any relevant studies upon our review of the English-language abstracts of non-English-language studies. A complete list of articles that were excluded during full-text review can be found in Appendix C.

Seventeen published articles met the review inclusion criteria. One article included 2 studies within the same publication,^66^ and another trial reported outcomes in 2 separate papers.^67,68^ All 17 included studies (17 articles) addressed KQ 1, with 7 studies examining strategies classified as professional training studies and 10 studies examining strategies classified as financial or organizational change studies based on categorizing components based on the Effective Practice and Organisation of Care (EPOC) taxonomy. One of the included articles addressed KQ 2, and 4 articles were identified that addressed KQ 3. The evidence base included randomized controlled trials (RCTs),^13,14,66–68,84–92^ controlled clinical trials (CCTs),^93,94^ interrupted time series,^95^ and cohort designs.^66^ Additional details describing the included studies are provided in the relevant sections of this results section and at http://srdr.ahrq.gov/projects/530.

In addition, we searched for related publications to extract contextual information on the reasons for success or failure of strategies. Our searches yielded 1,158 citations of which we reviewed 33 full-text studies. Six studies provided additional contextual information and were incorporated in the results pertaining to each intervention. Additionally, we found two articles that contributed to our evidence base. Specifically, one article^68^ contributed new outcomes to an already included study; we constructed an add-on search to capture its indexing terms. We included a second article in the review as a new study, arising from handsearches.^91^ PubMed indexed it as an adult rather than a child study; as a result, we did not capture it in our systematic searches.

We also reached out to principal investigators or their surrogates to elicit their views on the critical components of the strategies included in this review. Three investigators (lead investigators on two studies and one proxy for two studies with a deceased principal investigator) did not respond to our repeated outreach attempts. A fourth respondent refused because of lack of time, and a fifth responded to us but was unable to provide us with information because the principal investigator (lead on two studies) was deceased. Investigators for the remaining 10 studies listed critical components or contextual factors, which we present in the results below.

## Description of Included Studies

Our review focused on 17 included studies from 17 publications.^13,14,66–68,84–95^ One of these studies addressed KQ 2 (harms) and four addressed KQ 3 (moderators of effectiveness). We first attempted to categorize each strategy by whether it focused on QI, implementation, or dissemination according to our definitions, but we encountered several difficulties. First, our categorizations—assessed independently by two reviewers, with conflicts resolved by consensus—did not always match the study authors’ categorization (QI, implementation, or dissemination). Second, the complexity of several of the strategies meant that we could not assign studies to mutually exclusive categories for QI, implementation, or dissemination. We judged that 7 of 17 studies could be classified as having dual categories (Figure 3). Third, studies within the same category (QI, implementation, or dissemination) did not have sufficient similarities in strategy components to enable meaningful synthesis of findings.

Figure 3 Venn diagram representing study team’s original classification of included studies

Figure 3 is titled “Venn diagram representing study team’s original classification of included studies.” The figure displays a Venn diagram that includes the 17 included studies and the study authors’ original categorization of the strategies examined within each study. The diagram includes three partially overlapping circles, the circle on top is labelled implementation studies, the circle on the bottom left is labelled quality improvement, and the circle on the bottom right is labeled dissemination. The top circle labeled implementation studies includes Beidas et al., 2012, Glisson et al., 2012, Glisson et al., 2010, Sterling et al., 2015, and Wildman et al., 2012. The bottom left circle is labeled quality improvement studies and includes Bickman et al., 2011, Carroll et al., 2013, Lester et al., 2009, Ronsley et al., 2012, and Epstein et al., 2007. The bottom right circle of the Venn diagram labeled dissemination studies does not include any studies because no studies classified only as dissemination studies were captured by the search. Garner et al., 2012 and Henggeler et al., 2008 were categorized dually as implementation and quality improvement. Lochman et al., 2009 was categorized dually as implementation and dissemination. Epstein et al., 2011 and study 1 and study 2 included within Gully et al., 2008 were dually categorized as quality improvement and dissemination.

As a result of these difficulties, we decided to categorize each of the strategies according to the EPOC taxonomy, indicating each of the professional, organizational, financial, or regulatory components that were present. No included studies contained regulatory components. Because many of the comparison groups also contained several of these components, we marked the components contained in each treatment and comparison group (i.e., study arm). This allowed us to fully describe the numerous components that were being combined and tested in each strategy and enabled us to determine whether the study arms differed by a single or multiple components. Appendix B provides the full table of EPOC taxonomy components contained in each strategy by study arm; Table 3 presents a summary version of this table with descriptions of strategy components and differences by study arms. Strategies with one or more financial or organizational components were classified as “financial or organizational change” strategies, and strategies with only professional components were classified as “professional training” strategies. These categories guided our qualitative synthesis. Our outreach to investigators to identify critical components yielded responses for 10 included strategies. Of these, 8 highlighted specific interventions. Specifically, 4 cited training, 3 cited feedback, 1 cited referral processes, and 1 cited financial incentives. One investigator cited a contextual factor, specifically the recruitment of patients from community-based pediatric practices.

Table 3 Summary table of strategies tested

Author Study Arms | Target Condition and Ages of Youth | QI/I/D^a^ | Primary Categorization | Number and Types of EPOC Components Included in Strategy | Differences Across Study Arms Critical Components for Replication as Identified by Study Authors (personal communication)
Beidas et al., 2012^87^ Augmented active learning vs. computerized routine vs. routine professional training workshop to implement an EBP (three arms) | Anxiety 8–17 years | I | Professional training | 2 professional components (distribution of educational materials in one arm, educational meetings in two arms, plus one “other” component in all three arms—weekly consultation via virtual conferencing platform for 3 months after training) | Single difference across arms in the method of training program delivery (distribution of program’s educational materials delivered via the computer in one group vs. workshop with behavioral role play and small group activities in another group vs. workshop with didactic instruction only in routine professional training group) Augmented training: focus on principles of treatment and use of experiential learning; the ongoing support/consultation
Bickman et al., 2011^13^ Weekly and cumulative 90-day feedback vs. cumulative 90-day feedback only on patient symptoms and functioning to practitioners | General mental health problem (children who receive home-based mental health treatment) Mean=15 years | QI | Financial or organizational change | 5 professional components (distribution of educational materials, educational meetings, patient-mediated interventions, audit and feedback, and one other—individual support by phone or email) 1 organizational structural component (quality monitoring) | Single difference across arms (frequency of audit and feedback mechanism—weekly and cumulative 90-day vs. cumulative 90-day feedback to practitioners only), although classified as a financial or organizational change strategy because strategy required a structural change of quality monitoring Feedback
Carroll et al., 2013^89^ Computer decision support plus electronic health record (EHR) that included diagnosis and treatment guidelines vs. computer decision support plus EHR only | General mental health problem (children who receive home-based mental health treatment) Mean=15 years | QI | Financial or organizational change | 2 professional components (patient-mediated intervention and reminders) 1 organizational structural component (quality monitoring) | All components differed across arms (computer decision support plus EHR-only group included none of these components) NR
Epstein et al., 2011^85^ Internet portal providing practitioner access to practice guidelines vs. wait-list control | Attention deficit hyperactivity disorder (ADHD) 6 to 12 years | QI/D | Financial or organizational change | 5 professional components (distribution of educational materials, educational meetings, patient-mediated interventions, audit and feedback, and reminders) 1 financial component (provider incentives) 2 organizational structural components (quality monitoring and staff organization) | All components differed across arms (wait-list control group included none of these components) An Internet-based platform through which parents, teachers, and pediatricians input information about the target child during initial ADHD assessment and treatment, which then resulted in a report and change in office flow
Epstein et al., 2007^86^ Collaborative consultation treatment service to promote the use of titration trials and periodic monitoring during medication management vs. control | ADHD Mean age=7 years | QI | Financial or organizational change | 1 professional component (audit and feedback) 1 organizational provider-oriented component (clinical multidisciplinary teams) | All (both) components differed across arms (control group included neither of these components) Recruitment of patients from community-based pediatric practices.
Garner et al., 2012^84^ Paying practitioners for performance in successfully delivering an EBP intervention vs. implementation as usual (IAU) | Substance use disorders Mean age=16 years | QI/I | Financial or organizational change | 4 professional components (distribution of educational materials, educational meetings, educational outreach visits, and one other—feedback from trained raters and weekly phone calls from developers) 2 financial provider components (provider incentives and provider grant/allowance) | Single difference across arms in provider incentives Financial incentives provided to the staff delivering the intervention
Glisson et al., 2012^67,68^ Program to improve organizational climate and culture vs. control | General mental health problems 8–24 years | I | Financial or organizational change | 5 professional components (distribution of educational materials, educational meetings, educational outreach visits, audit and feedback, and one other—training and cognitive models to improve effectiveness) 1 organizational provider-oriented component (satisfaction of providers with conditions of their work) | All components differed across arms (control group included none of these components) The ARC intervention strategies depend on trained specialists who work at all levels of a service system to (a) embed guiding principles for improving services, (b) develop shared mental models among organizational members to support the improvement effort, and (c) enact organizational tools (e.g., feedback) for identifying and addressing service barriers
Glisson et al., 2010^14^ Program to improve organizational climate and culture vs. control | Externalizing behaviors (youth referred to juvenile court with behavioral or psychiatric symptoms that require intervention) 9–17 years | I | Financial or organizational change | 5 professional components (distribution of educational materials, educational meetings, educational outreach visits, audit and feedback, and one other—training and cognitive models to improve effectiveness) 1 organizational provider-oriented component (satisfaction of providers with conditions of their work) | All components differed across arms (control group included none of these components) The ARC intervention strategies depend on trained specialists who work at all levels of a service system to (a) embed guiding principles for improving services, (b) develop shared mental models among organizational members to support the improvement effort, and (c) enact organizational tools (e.g., feedback) for identifying and addressing service barriers
Gully^b^ et al., 2008^66^ Protocol to train nurses to educate parents about EBPs vs. typical services | General mental health symptoms (children suspected of abuse during forensic medical examinations) 2–17 years | QI/D | Professional training | 4 professional components (distribution of educational materials, educational meetings, educational outreach visits, patient-mediated interventions) | All components differed across arms (typical services group included none of these components) NR
Henggeler et al., 2008^93^ Intensive Quality Assurance (IQA) system vs. workshop only to implement an EBP intervention | Substance use disorders (adolescents with marijuana abuse) 12–17 years | QI/I | Financial or organizational change | 4 professional components (distribution of educational materials, educational meetings, educational outreach visits, and one other—drug screen tests and supplies) 1 financial provider component (other—money to facilitate treatment goals via a voucher system) 1 financial patient component (patient incentives) 1 organizational structural component (quality monitoring) | Two of 7 components differed across arms (patient incentives and quality monitoring were not part of the workshop-only group) NR
Henggeler et al., 2013^91^ Workshop and resources (WSR) vs. WSR and computer-assisted training (WSR+CAT) vs. WSR+CAT and supervisory support (WSR+CAT+SS) to implement an EBP intervention | Substance use disorders 12–17 years | QI/I | Professional training | 5 professional components (distribution of educational materials, educational meetings, educational outreach visits, and two other—drug screens and supplies and continuing education credits) 1 financial patient component (vouchers for providers to hand out to youth) | Two of 6 components differed across arms (only the WSR+CAT+SS group had site visits and telephone consultations between EBP experts and therapist supervisors and educational materials differed in intensity among the three groups) NR
Lester et al., 2009^90^ Professional training to identify and refer cases vs. usual care | Psychosis (adolescents and adults with first-episode psychosis) 14–30 years | QI | Professional training | 4 professional components (educational meetings, local consensus process, educational outreach visits, and marketing) | All components differed across arms (control group included none of these components) NR
Lochman et al., 2009^88^ Professional training plus feedback to implement an EBP intervention vs. professional training only to implement an EBP intervention vs. control (three arms) | Externalizing behaviors (children at risk for aggressive behaviors) Third-grade students | D/I | Professional training | 5 professional components (educational materials, educational meetings, audit and feedback, marketing, and one other—monthly ongoing training sessions) | Difference across the three study arms varied (training plus feedback group had all five components, training-only group had educational meetings and marketing components, and control group had none of these components) Audit and feedback components where trainers reviewed the rate of completion of session objectives and provided individualized supervisory feedback
Ronsley et al., 2012^95^ Patient medication monitoring training program for practitioners vs. usual care | Psychosis <19 years (mean=11) | QI | Professional training | 5 professional components (educational materials, educational meetings, educational outreach visits, reminders, and one other—online access and project coordinator) | All components differed across arms (usual-care group included none of these components) NR
Sterling et al., 2015^92^ Pediatrician only vs. embedded BHCP implementation of an EBP | Patients ages 12–18 attending a pediatric primary care office | I | Financial or organizational change | 1 organizational provider-oriented component (clinical multidisciplinary teams) | Single difference across arms (embedded BHCP implementation of Screening, Brief Intervention, and Referral to Treatment [SBIRT] vs. pediatrician-only implementation of SBIRT) Brief training in how to deliver SBIRT in the pediatrician-only arm; embedding a BHCP in the BHCP arm
Wildman et al., 2009^94^ Colocation of an EBP program in primary care vs. enhanced referral to an EBP program | Externalizing behavior problems 2–12 years | I | Financial or organizational change | 2 organizational structural components (changes in scope and nature of benefits and services and one other—choice of treatment) | Single difference across arms (choice of treatment was not included in the enhanced referral group) Creating easy referral procedures for primary care providers to use for behavioral health care

a Original categorization made by study team.

b Applicable to both studies included in this publication.

ADHD = attention deficit hyperactivity disorder; ARC = Availability, Responsiveness and Continuity; BHCP = behavioral health care practitioner; CAT = computer-assisted training; EBP = evidence-based practice; EPOC = Effective Practice and Organisation of Care; EHR = electronic health record; IAU = implementation as usual; MST = multisystemic therapy; NR = no response; QI/I/D = quality improvement\implementation\dissemination; SBIRT = Screening, Brief Intervention, and Referral to Treatment; SS = supervisory support; vs. = versus; WSR = workshop and resources.

Table 4 exhibits study characteristics of included studies organized by primary component of strategy according to the EPOC taxonomy (i.e., professional training or financial or organizational change).

Table 4 Strategies to improve mental health of children and adolescents: Study characteristics

Study Descriptor | Characteristics | Primary Strategy: Professional Training^a^ | Primary Strategy: Financial or Organizational Change^b^ | Total
Design | RCT | 2 | 0 | 2
Design | 2-stage RCT | 0 | 1 | 1
Design | Cluster RCT | 3 | 7 | 10
Design | CCT | 0 | 2 | 2
Design | Non-RCT | 2 | 0 | 2
Setting | Primary care | 1 | 2 | 3
Setting | Community mental health | 4 | 8 | 12
Setting | School | 1 | 0 | 1
Strategy categorization^c^ | Quality improvement | 2 | 3 | 5
Strategy categorization^c^ | Implementation | 1 | 4 | 5
Strategy categorization^c^ | Dissemination | 0 | 0 | 0
Strategy categorization^c^ | Hybrid QI and I | 1 | 2 | 3
Strategy categorization^c^ | Hybrid QI and D | 2 | 1 | 3
Strategy categorization^c^ | Hybrid I and D | 1 | 0 | 1
Risk of bias | Low | 1 | 0 | 1
Risk of bias | Medium | 0 | 3 | 3
Risk of bias | High | 3 | 4 | 6
Risk of bias | Unclear | 4 | 3 | 7
Key question | KQ 1 | 7 | 10 | 17
Key question | KQ 2 | 1 | 0 | 1
Key question | KQ 3 | 1 | 3 | 4
Total N of studies | | 7 | 10 | 17

a Included all professional components.

b Included at least 1 financial or organizational component.

c Categories dually assigned by members of the study team according to the definitions of QI, I, and D included in the PICOTS.

CCT = controlled clinical trial; D =Dissemination; I=Implementation; KQ = Key Question; QI = quality improvement; RCT = randomized controlled trial.

Seven studies had unclear risk of bias, 1 had low, 3 had medium, and 6 had high. Most studies were RCTs or CCTs. The majority were clustered at the practitioner, practice, or organizational level. The other two studies included an interrupted time-series study and a cohort study with a historical control. Seven of the studies focused on professional training (i.e., only included professional components), while the other 10 studies focused on financial or organizational changes (i.e., included at least one financial or organizational component). Settings included primary care, community health, and schools. Each included study is reported in detail by KQ below. Full evidence tables are available at http://srdr.ahrq.gov/projects/530.

## Key Question 1 Effectiveness of Strategies

Each of the 17 included studies from 17 publications^13,14,66–68,84–95^ addressed our first KQ on strategy effectiveness. Key points and additional details of intermediate and patient health and service utilization outcomes overall and by the primary component of the strategy are shown in Table 5, according to our classification based on the EPOC taxonomy.

Table 5 Intermediate and patient health and service utilization outcomes by primary component of strategy

Outcome Category | Outcomes | Professional Training^a^ (7 Studies) | Financial or Organizational Change^b^ (10 Studies) | Total
Intermediate outcome: practitioner | Satisfaction/acceptability | 1 | 1 | 2
Intermediate outcome: practitioner | Adherence/fidelity | 3 | 8 | 11
Intermediate outcome: practitioner | Competence/skills | 2 | 2 | 4
Intermediate outcome: system | Feasibility | 0 | 0 | 0
Intermediate outcome: system | Uptake | 1 | 0 | 1
Intermediate outcome: system | Timeliness | 0 | 0 | 0
Intermediate outcome: system | Penetration | 0 | 0 | 0
Intermediate outcome: system | Sustainability | 0 | 0 | 0
Intermediate outcome: patient | Resources (including costs) | 0 | 0 | 0
Intermediate outcome: patient | Access to care | 3 | 1 | 4
Intermediate outcome: patient | Satisfaction | 2 | 0 | 2
Intermediate outcome: patient | Treatment engagement | 2 | 0 | 2
Intermediate outcome: patient | Therapeutic alliance with provider | 2 | 0 | 2
Patient health and service utilization outcome | Changes in mental health status | 2 | 4 | 6
Patient health and service utilization outcome | Comorbid mental, substance use, developmental disorders | 0 | 0 | 0
Patient health and service utilization outcome | Mortality | 0 | 0 | 0
Patient health and service utilization outcome | Socialization skills and behaviors | 1 | 0 | 1
Patient health and service utilization outcome | Functional status | 0 | 1 | 1
Patient health and service utilization outcome | Quality of life | 0 | 0 | 0
Patient health and service utilization outcome | Service utilization | 2 | 2 | 4
Patient health and service utilization outcome not reported | N/A^c^ | 4 | 3 | 7
Total | | 7 | 11 | 17

a Included all professional components.

b Included at least 1 financial or organizational component.

c N/A = Not applicable because the strategy employed an EBP intervention, which has known benefits to these outcomes.

EBP = evidence-based practice.

### Key Points: Characterization of Strategies

We categorized the strategies tested in 7 studies as spanning multiple categories of our original three classifications: QI, implementation, or dissemination. This overlap prompted us to use a different system, based on the EPOC taxonomy, to ultimately classify strategies as professional training (i.e., strategies that comprised only professional components) or financial or organizational change (i.e., strategies that comprised at least one financial or organizational component).

- We categorized 7 of the studies as examining professional training strategies and 10 of the studies as examining financial or organizational change strategies.
- The strategies tested all had multiple components, some of which spanned EPOC groupings of categories (e.g., professional, organizational, financial).
- The number of components differing between arms (treatment vs. control) varied by study; 5 studies had single-component differences across arms (i.e., a single active component) and 12 studies had multiple-component differences across arms (i.e., multiple active components).
- Among investigators who responded to our inquiries regarding critical components, 4 highlighted training, 3 focused on feedback, 1 noted referral processes, 1 cited financial incentives, and 1 cited the recruitment of patients from community-based pediatric practices.

### Intermediate Outcomes

#### Practitioner Outcomes

We found studies that examined each of our three prespecified practitioner intermediate outcomes: satisfaction with or acceptability of approach (n=2), protocol adherence or program model fidelity (n=11), and competence/skill (n=4).

- For practitioner satisfaction with or acceptability of approach, we found low strength of evidence for no benefit of one professional training study and low strength of evidence for benefit of one financial/organizational study.
- For protocol adherence or program model fidelity, strength of evidence varied based on the specific strategy. We did not find consistent evidence that the type of strategy was associated with a direction or strength of evidence; for example, we found low strength of evidence of benefit as well as low strength of evidence for no benefit and insufficient evidence for strategies with professional training. The same holds true for strategies with a financial/organizational component.

#### System Outcomes

A single study evaluated the prespecified system intermediate outcomes of uptake.

- We found insufficient strength of evidence to judge the benefit of a strategy testing for the use of a workshop plus resources (with or without computer-assisted training) plus resources to implement an EBP intervention vs. the workshop plus resources only.

#### Patient Outcomes

Four types of prespecified patient intermediate outcomes were reported: patient access to care (n=4), patient satisfaction (n=2), treatment adherence (n=2), and therapeutic alliance (n=2).

- For patient access to care intermediate outcomes, strength of evidence varied based on the specific strategy.
- For other three patient intermediate outcomes—patient satisfaction, treatment adherence, and therapeutic alliance—we found low strength of evidence for benefit from two studies each.

### Key Points: Patient Health and Service Utilization Outcomes

Seven studies did not report a patient health or service utilization outcome because the strategy employed an EBP. For these studies, positive intermediate outcomes were assumed to have positive effects on patient outcomes. Six studies reported on changes in mental health status (e.g., symptoms, recovery, remission), one on socialization skills and behaviors, one on functional status, and four on service utilization.

- For mental health status outcomes, strength of evidence varied based on the specific strategy (n=6).
- For changes in socialization skills and behaviors, in one study with three arms, we found low strength of evidence for benefit of professional training plus feedback to implement an EBP intervention versus control, and low strength of evidence for no benefit of professional training only to implement an EBP intervention versus control.
- For changes in functional status outcomes, we found low strength of evidence for benefit of a financial or organizational change strategy (n=1) testing weekly and cumulative 90-day versus cumulative 90-day feedback to practitioners that had a single active component, a quality monitoring mechanism.
- The strength of evidence for service utilization outcomes varied based on the specific strategy (n=4).

### Key Points: Qualitative Comparative Analysis Findings

The model from qualitative comparative analysis (QCA) that best explained the data looked at the presence of several components. These included educational materials or meetings, educational outreach components, patient-mediated intervention components, audit and feedback, one or more reminders components, one or more financial components, use of a clinical multidisciplinary team, and changing of the scope of patient benefits. The model evaluated these components in relation to having a statistically significant improvement in a majority of the practitioner-, system-, and patient-level intermediate outcomes tested (and rated as having at least low strength of evidence for benefit) [underlined: or] having at least low strength of evidence for benefit for at least one patient health or service utilization outcome (and rated as having at least low strength of evidence for benefit).

#### Solutions

- The QCA identified seven solutions, which accounted for 83.3 percent of the studies that achieved the outcome.
- Four solutions represented single studies.
- The other three solutions encompassed a mix of components found in seven studies that achieved success.

### Detailed Synthesis

#### Professional Training Strategies

Seven studies reported in six publications focused on professional training strategies.^66,87,88,90,91,95^ These studies each included various professional components according to the EPOC taxonomy and no financial or organizational components. Studies included a maximum of five professional components. Components included distribution of educational materials, educational meetings, local consensus processes, educational outreach visits, patient-mediated interventions, audit and feedback, reminders, marketing, individual support by phone or email, project coordinator assistance, and monthly ongoing training sessions.

One strategy targeted school counselors, five targeted community-based mental health providers, and one targeted general practitioners. One of these studies ultimately targeted general practitioners who treated children and adolescents with psychosis,^90^ two targeted community-based mental health practitioners,^91,95^ one targeted community therapists treating children with anxiety,^87^ one targeted school counselors attempting to prevent externalizing behaviors among children at high risk of aggressive behaviors,^88^ and two studies reported in one publication targeted nurses who encountered children and adolescents who were suspected victims of abuse.^66^ Details of each of these studies are described below.

##### Adding an Active Learning Component to a Professional Training Workshop To Implement an EBP

###### Study Description

One RCT^87^ (low risk of bias), conducted in 2009, focused on implementing cognitive behavioral therapy (CBT). Specifically, it evaluated the effectiveness of three 6-hour training modalities of CBT for anxiety in youth and the impact of ongoing consultation after training. Participants were 115 community therapists randomly assigned to one of three 1-day workshops to examine the effectiveness of the training modality: routine training (RT, training as usual, n=41), computer training (CT, computerized training as usual, n=34), and augmented training that emphasized active learning (AT, n=39). After the workshops, all participants received 3 months of ongoing consultation that included case consultation, didactics, and problem solving.

Participants included community therapists (mean age=35.9, 90% female) working in the community with children ages 8 to 17 with anxiety disorders who had not had more than 8 hours of prior CBT training for child anxiety. Outcomes measured at baseline and at posttraining included a measure of training satisfaction (range 12–60), a knowledge test of CBT for youth anxiety (range 0–20), and a measure of therapist fidelity that included adherence as assessed by six CBT competencies (range 0–6) and the therapist’s competence as rated by a coder blind to treatment condition (range 1–7). Authors compared the means across treatment groups at posttreatment using t-tests; we calculated mean difference scores and 95% CIs of differences between the AT and RT groups and the CT and RT groups.

Therapists participated in an additional role-playing exercise at posttraining and 3-month followup (postconsultation) that involved simulated clinical situations where therapists encountered a research assistant acting as a child with anxiety seeking care. Independent assessors coded digital recordings of these sessions to determine the proportion of therapists in each training condition trained to adherence, skill, and knowledge criteria.

###### Intermediate Outcomes

All three modalities resulted in limited gains in therapist adherence, skill, or knowledge (Table 6). All groups improved in adherence to CBT measured by an Adherence Skills Checklist, participant skill (level of competence shown by the therapist in delivering treatment), and knowledge of CBT for youth anxiety, but the study found no significant effect on training or interaction of time and training. In addition, the proportion of therapists trained to criterion did not differ across treatment groups for adherence, skill, or knowledge. The study found differences in satisfaction across training modalities (F=7.22, df=2 and 112, p<0.001), with participants in the CT group reporting lower satisfaction scores than the RT group (50.8±5.9 vs. 53.7±5.4; calculated mean difference, −2.9; 95% CI, −5.46 to −0.340; p=0.03). Satisfaction did not significantly differ between the AT group and the RT group.

Table 6 Adding an active learning component to a professional training workshop to implement an EBP: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Beidas et al., 2012^87^ RCT/Low | G1: Augmented active learning professional training workshop to implement an EBP intervention (CBT) G2: Computerized routine professional training workshop to implement an EBP intervention (CBT) G3: Routine professional training workshop to implement an EBP intervention (CBT) Single difference across arms: distribution of educational materials delivered via the computer in one arm vs. workshop with behavioral role play and small group activities in another arm vs. workshop with didactic instruction only in comparison arm | G1: 40 G2: 34 G3: 41 | Practitioner adherence to CBT: mean posttraining score difference G1–G3 and G2–G3 and differences in proportion of community therapists trained to criterion at posttraining (after a 1-day workshop) and postconsultation (after 3 months of followup consultation) | Mean post difference G1–G3: 0.43, 95% CI, −0.17 to 1.03 (calculated) Mean post difference G2–G3: −0.22, 95% CI, −0.89 to 0.45 (calculated) Posttraining G1 vs. G3 OR, 0.94, 95% CI, 0.39 to 2.30 G2 vs. G3 OR, 0.56, 95% CI, 0.21 to 1.48 Postconsultation G1 vs. G3 1.43, 95% CI, 0.55 to 3.73 G2 vs. G3 OR, 0.93, 95% CI: 0.35 to 2.49 (calculated)
Beidas et al., 2012^87^ RCT/Low | | G1: 40 G2: 34 G3: 41 | Practitioner skill: mean posttraining score difference between G1–G3 and G2–G3 and differences in proportion of community therapists trained to criterion at posttraining (after a 1-day workshop) and postconsultation (after 3 months of followup consultation) | Mean post difference G1–G3: −0.45, 95% CI, −1.10 to 0.20 (calculated) Mean post difference G2–G3: −0.46, 95% CI, −1.14 to 0.22 (calculated) Posttraining G1 vs. G3 OR, 2.00, 95% CI, 0.75 to 5.34 G2 vs. G3 OR, 0.68, 95% CI, 0.27 to 1.71 Postconsultation G1 vs. G3 OR, 0.94, 95% CI, 0.39 to 2.30 G2 vs. G3 OR, 0.97, 95% CI, 0.29 to 3.26 (calculated)
Beidas et al., 2012^87^ RCT/Low | | G1: 40 G2: 34 G3: 41 | Practitioner knowledge: mean posttraining score difference between G1–G3 and G2–G3 and differences in proportion of community therapists trained to criterion at posttraining (after a 1-day workshop) and postconsultation (after 3 months of followup consultation) | Mean post difference G1–G3: −0.62, 95% CI, −1.45 to 0.21 (calculated) Mean post difference G2–G3: −0.03, 95% CI, −0.87 to 0.81 (calculated) Posttraining G1 vs. G3 OR, 1.50, 95% CI, 0.24 to 9.49 G2 vs. G3 OR, 2.61, 95% CI, 0.26 to 26.3 Postconsultation G1 vs. G3 OR, 1.07, 95% CI, 0.06 to 17.8 G2 vs. G3 OR, 0.39, 95% CI, 0.03 to 4.53 (calculated)
Beidas et al., 2012^87^ RCT/Low | | G1: 40 G2: 34 G3: 41 | Practitioner satisfaction: mean satisfaction score (range 12–60) difference between G1–G3 and G2–G3 | Mean post difference G1–G3 (calculated): 1.8, 95% CI, −0.423 to 4.023, p=0.11 Mean post difference G2–G3 (calculated): −2.9, t=−3.78, df=112, p<.001

CBT = cognitive behavioral therapy; CI = confidence interval; EBP = evidence-based practice; G = group; N = number; OR = odds ratio; RCT = randomized controlled trial; vs. = versus.

A companion qualitative analysis explored barriers and facilitators to implementation among therapists^96^ and found that client, intervention, and organizational factors played important roles. Client-level barriers included the presence of complex issues and multiple comorbidities and psychosocial stressors, low motivation, and younger age. Client-level facilitators included higher motivation and functioning. Regarding intervention-level factors, the structured nature of CBT served as a barrier for some and facilitator for others. Therapists cited the school setting as a barrier when it prevented them from allocating the required time in each session but as a facilitator when it provided access to youths. Therapists also noted support at work (through supervision) and autonomy as organizational facilitators. A second companion study focused on inner-setting variables, specifically, perceptions of organizational climate and adopter characteristics, as predictors of fidelity and penetration of the intervention.^97^ It reported that as individual perceptions of organization climate increased, adherence also increased. However, greater experience and more positive attitudes to the intervention were associated with lower adherence, suggesting a complex relationship between adopter characteristics and intervention fidelity. Neither adopter characteristics nor perceptions of organizational climate predicted penetration of the intervention.

###### Patient Health and Service Utilization Outcomes

The study did not report patient health and service utilization outcomes because the investigators implemented an EBP (CBT for anxiety).

###### Risk of Bias Considerations

We rated this study as having low risk of bias. Most procedures used by the study authors did not raise risk of bias concerns. One exception is that the authors randomized the therapists to treatment condition by date of enrollment, although allocation to group was concealed. Another minor concern was that the authors did not report differences in baseline characteristics between groups, and baseline differences, if significant, were uncontrolled in analyses. Attrition was 2 percent at posttraining and 12 percent at postconsultation (3-month followup) assessment.

###### Conclusion and Strength of Evidence

We graded the strength of evidence on a strategy on adding active learning to a professional training workshop for community therapists to implement an EBT, CBT for youth anxiety, as low for no benefit. The evidence consisted of a single publication that presented data from an RCT with low risk of bias, small sample size, and imprecise results. Specifically, the strategy included educational materials or meetings. It did not improve practitioner (1) satisfaction with or acceptability of approach, (2) protocol adherence or program model fidelity, or (3) skills or knowledge (Table F-1).

##### Training Nurses To Educate Parents About EBPs

###### Study Description

Two studies in one publication^66^ examined a nurse-provided EBP intervention (high risk of bias) delivered to parents or caregivers to increase access to evidence-based mental health treatment for children ages 2 to 17 years who were suspected victims of abuse. The authors describe two studies; the first was cohort study with a historical control, and the second was an RCT. In Study 1, nurses at hospitals and community-based treatment centers received the EBP intervention, following which the investigators collected data from parents and caregivers. The comparison data came from the same study sites prior to the EBP intervention but from different parents and caregivers. In Study 2, parents or caregivers of children who were suspected victims of abuse presenting to a children’s hospital forensic unit were randomly assigned to the EBP intervention protocol or typical services. The EBP intervention took place during forensic medical examinations performed for children who were referred for child abuse investigations. During the examination, nurses followed a protocol to educate parents and caregivers about EBPs for child mental health problems, addressing barriers to care and discussing with the parents the logistics of setting up an appointment.

In Study 1, the EBP intervention group included 172 parents or caregivers in both groups (number in each group not specified). In Study 2, the EBP intervention group included 24 parents or caregivers, and the usual-care group included 27 parents or caregivers. Outcomes in both studies included parent/caregiver ratings (1–5, with 5 being definitely yes and 1 being definitely no) of access to EBT, satisfaction with services, helpfulness of mental health treatment, confidence to set and attend mental health treatment appointments, learning about an EBT, and feelings of being respected. Outcomes were assessed via phone calls with parents 1 month after the examination.

###### Intermediate Outcomes

Parents or caregivers in the EBP intervention group reported significantly higher ratings than parents or caregivers in the usual-care group for each of the six outcomes assessing access to EBTs, satisfaction with services, helpfulness of mental health treatment, confidence to set and attend mental health treatment appointments, learning about an EBT, and feelings of being respected. Outcomes were assessed via phone calls with parents 1 month after the examination (Table 7). The statistical significance of the findings held for both studies, with the exception that parents’ or caregivers’ ratings of the helpfulness of mental health treatment did not significantly differ between groups in Study 2 (i.e., the RCT). The patterns of significance held constant across unadjusted and adjusted analyses.

Table 7 Training nurses to educate parents about EBPs: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Gully et al., 2008^66^ Study 1: Cohort design/High | Study 1: G1: Protocol to train nurses to educate parents about EBPs G2: Typical services All 4 professional components (distribution of educational materials, educational meetings, educational outreach visits, patient-mediated interventions) differed across arms (comparison group strategy contained no components) | Study 1: G1: 86 G2: 86 | Calculated mean G1–G2 difference in parent report (scale=1–5) of nurse discussing EBT during appointment | 0.8 95% CI, 0.30 to 1.30
Gully et al., 2008^66^ Study 1: Cohort design/High | | Study 1: G1: 86 G2: 86 | Calculated mean G1–G2 difference in parent report (scale=1–5) of satisfaction with services | 0.4, 95% CI, 0.15 to 0.65
Gully et al., 2008^66^ Study 1: Cohort design/High | | Study 1: G1: 86 G2: 86 | Calculated mean G1–G2 difference in parent report (scale=1–5) of perceived value of services | 0.8, 95% CI, 0.52 to 1.08
Gully et al., 2008^66^ Study 1: Cohort design/High | | Study 1: G1: 86 G2: 86 | Calculated mean G1–G2 difference in parent report (scale=1–5) of confidence in setting/attending child mental health treatment appointments | 0.9, 95% CI, 0.58 to 1.22
Gully et al., 2008^66^ Study 1: Cohort design/High | | Study 1: G1: 86 G2: 86 | Calculated mean G1–G2 difference in parent report (scale=1–5) of knowledge about EBPs | 2.4, 95% CI, 2.04 to 2.76
Gully et al., 2008^66^ Study 1: Cohort design/High | | Study 1: G1: 86 G2: 86 | Calculated mean G1–G2 difference in parent report (scale=1–5) of rapport with the nurse | 0.4, 95% CI, 0.15 to 0.65
Gully et al., 2008^66^ Study 2: RCT/High | Study 2: G1: Education of parents and caregivers of children suspected of being abuse victims G2: Typical services during a forensic medical examination All 4 professional components (distribution of educational materials, educational meetings, educational outreach visits, patient-mediated interventions) differed across arms (comparison group strategy contained no components) | Study 2: G1: 24 G2: 27 | Calculated mean G1–G2 difference in parent report (scale=1–5) of nurse discussing EBT during appointment | 1.9, 95% CI, 1.13 to 2.67
Gully et al., 2008^66^ Study 2: RCT/High | | Study 2: G1: 24 G2: 27 | Calculated mean G1–G2 difference in parent report (scale=1–5) of satisfaction with services | 0.9, 95% CI, 0.36 to 1.44
Gully et al., 2008^66^ Study 2: RCT/High | | Study 2: G1: 24 G2: 27 | Calculated mean G1–G2 difference in parent report (scale=1–5) of perceived value of services | 0.6, 95% CI, −0.02 to 1.18
Gully et al., 2008^66^ Study 2: RCT/High | | Study 2: G1: 24 G2: 27 | Calculated mean G1–G2 difference in parent report (scale=1–5) of confidence in setting/attending child mental health treatment appointments | 2.5, 95% CI, 1.86 to 3.14
Gully et al., 2008^66^ Study 2: RCT/High | | Study 2: G1: 24 G2: 27 | Calculated mean G1–G2 difference in parent report (scale=1–5) of knowledge about EBPs | 1.1 95% CI, 0.60 to 1.60
Gully et al., 2008^66^ Study 2: RCT/High | | Study 2: G1: 24 G2: 27 | Calculated mean G1–G2 difference in parent report (scale=1–5) of rapport with the nurse | 1.1, 95% CI, −0.49 to 1.69

CI = confidence interval; EBP = evidence-based practice; G = group; N = number; RCT = randomized controlled trial.

Study authors also collected data on motivation to use the protocol and length of administration time from nurses in the EBP intervention group and combined across both studies. The nurses rated the protocol favorably and reported that the time to use the protocol took a mean of 2.4 minutes longer than it would have taken to address similar issues without the protocol.

###### Patient Health and Service Utilization Outcomes

The study did not report patient health and service utilization outcomes.^98, p. 8^ The EBPs supporting the strategy included those identified as providing the “greatest level of theoretical, clinical, and empirical support” for abused children and their families: Trauma-Focused Cognitive Behavioral Therapy, Abuse-Focused Cognitive Behavioral Therapy, and Parent-Child Interaction Therapy.^98^

###### Risk of Bias Considerations

We rated both studies presented in this publication as having high risk of bias. Both studies had high attrition and no adjustment for missing data (48% for Study 1 and 41% for Study 2). In addition, Study 1 had the potential for confounding through nonrandom assignment, because of its cohort design. Study 2 did not report details about randomization, although the authors did conduct post hoc tests and determined that neither variable that significantly differed between groups (age and race/ethnicity) was significantly associated with outcomes. All outcomes were parent or caregiver answers to nonvalidated questions measured on a Likert scale (1–5).

###### Conclusion and Strength of Evidence

We graded the strength of evidence for a strategy training nurses to educate parents about EBP as low for benefit. The evidence consisted of a single publication presenting data from two studies, a cohort study with a historical control and an RCT, rated as having high risk of bias, but providing consistent, direct, precise results. Specifically, the strategy (comprising educational meetings or materials, education outreach visits, and patient-reported data components) was directed at parents of children suspected to be victims of abuse. It increased access to care, satisfaction, treatment engagement, and therapeutic alliance (Table F-2).

##### Training Practitioners To Identify and Refer Cases

###### Study Description

One stratified cluster RCT^90^ (high risk of bias) focused on testing an educational strategy targeting general practitioners (GPs). These GPs had access to early-intervention services for young people ages 14 to 30 with first-episode psychosis in three inner-city primary care trusts in Birmingham, England. Practices in the strategy arm received an educational intervention addressing practitioner knowledge, skills, and attitudes about first-episode psychosis; control practices did not receive the educational intervention but had access to the early-intervention services. The primary outcome was the difference in the proportion of young patients with first-episode psychosis referred to early-intervention services between practices. Secondary outcomes included duration of untreated psychosis, time to recovery (with recovery measured by the Positive and Negative Syndrome Scale), detainment under the Mental Health Act, and GP consultation rate. The authors used nonlinear mixed models to present the relative risk (RR) and 95% CIs for the primary outcome (difference in number of referrals per practice using Poisson error).

A total of 110 of 135 (81%) of eligible practices were recruited between 2004 and 2007 and randomized to the strategy or control arm (n=55 in each). One hundred seventy-nine patients with first-episode psychosis ages 14 to 30 were referred; 25 referred from the early-intervention services, and 54 were found eligible for inclusion during the team’s audit of mental health notes. Eighty-three of the 179 patients provided secondary outcomes data (97 from the strategy group and 82 from the control group); a total of 68 of these were followed up 4 months later. Practices were recruited over three time periods, as more early-intervention services opened, allowing more practices to become eligible for study inclusion.

###### Intermediate Outcomes

The relative risk of referral to early-intervention services (patient access to care) did not significantly differ between strategy and control practices (Table 8).

Table 8 Training practitioners to identify and refer cases: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Lester et al., 2009^90^ Stratified cluster RCT/High | G1: Professional training to identify and refer cases G2: Usual care All professional components (educational meetings, local consensus process, educational outreach visits, marketing) differed across arms (comparison group strategy contained no components) | G1: 55 practices (97 patients) G2: 55 practices (82 patients) | RR for referral to early-intervention services after first contact (patient access to care) | RR: 1.20 95% CI, 0.74 to 1.95 p=0.48
Lester et al., 2009^90^ Stratified cluster RCT/High | | G1: 55 practices (97 patients) G2: 55 practices (82 patients) | Relative difference in detainment under the Mental Health Act within 4 months | Risk difference: 3.3%, p=0.79
Lester et al., 2009^90^ Stratified cluster RCT/High | | G1: 55 practices (97 patients) G2: 55 practices (82 patients) | Duration of untreated psychosis as defined from onset of psychosis through receipt of early-intervention services (mental health symptoms) | Mean difference = −13.8, 95% CI, −199.1 to 171.6, p=0.88
Lester et al., 2009^90^ Stratified cluster RCT/High | | G1: 55 practices (97 patients) G2: 55 practices (82 patients) | Delay in reaching early-intervention services as defined from first decision to seek care through 4 months after strategy (health care utilization) | Mean difference = −222.03; 95% CI, −83.5 to −360.5; p=0.002

CI = confidence interval; G = group; N = number; p = p-value; RCT = randomized controlled trial; RR = relative risk.

###### Patient Health and Service Utilization Outcomes

Several patient health and service utilization outcomes also did not differ between strategy practices and control practices (Table 9): detainment under the Mental Health Act during 4-month followup, recovery at the end of 4-month followup (as defined by a score of less than 10 on the positive subscale of the Positive and Negative Syndrome Scale; 55.3 percent vs. 64.4 percent, p=0.66 for strategy vs. control practices, respectively), number of consultations in primary care (RR, 0.77; 95% CI, 0.45 to 1.33; p=0.34), and mean duration of untreated psychosis as retrospectively assessed at baseline. Patients registered to strategy practices, however, had shorter delays than patients registered to control practices in reaching early-intervention services, as defined by the time from the first decision to seek care to the point of referral to an early-intervention service.

Table 9 Training practitioners with or without feedback to implement an EBP: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Lochman et al., 2009^88^ Cluster RCT/Unclear | G1: Professional training plus feedback to implement an EBP intervention (Coping Power: CP-TF) G2: Professional training only to implement an EBP intervention (Coping Power: CP-BT) G3: Control Training plus feedback arm had 5 professional components (educational materials, educational meetings, audit and feedback, marketing, and one other—monthly ongoing training sessions) Training-only arm had 2 components (educational meetings and marketing) Control arm had no components | G1: 168 G2: 183 G3: 180 | Behavior problems: beta coefficient, SE, and p-value for externalizing composite (teacher-rated) score change at 2 yrs in HLM analyses adjusted for baseline score, within-student variation, and between-counselor variation | G1 vs. G3: −0.41, SE=0.16, p=0.01 G2 vs. G3: 0.10, SE=0.16, p=0.52
Lochman et al., 2009^88^ Cluster RCT/Unclear | | G1: 168 G2: 183 G3: 180 | Behavior problems: beta coefficient, SE, and p-value for externalizing composite (parent-rated) score change at 2 yrs in HLM analyses adjusted for baseline score, within-student variation, and between-counselor variation | G1 vs. G3: −0.23, SE=0.12, p=0.05 G2 vs. G3: −0.13, SE=0.11, p=0.26
Lochman et al., 2009^88^ Cluster RCT/Unclear | | G1: 168 G2: 183 G3: 180 | Behavioral problems: beta coefficient, SE, and p-value for minor assault (child-rated) score change at 2 yrs in HLM analyses adjusted for baseline score, within-student variation, and between-counselor variation | G1 vs. G3: −0.25, SE=0.12, p=0.03 G2 vs. G3: 0.04, SE=0.11, p=0.70
Lochman et al., 2009^88^ Cluster RCT/Unclear | | G1: 168 G2: 183 G3: 180 | Targeted processes: beta coefficient, SE, and p-value for social/academic competence (teacher-rated) score change at 2 yrs in HLM analyses adjusted for baseline score, within-student variation, and between-counselor variation | G1 vs. G3: 0.35 SE=0.13, p=0.01 G2 vs. G3: 0.24, SE=0.13, p=0.06
Lochman et al., 2009^88^ Cluster RCT/Unclear | | G1: 168 G2: 183 G3: 180 | Targeted processes: beta coefficient, SE, and p-value for social composite (parent-rated) score change at 2 yrs in HLM analyses adjusted for baseline score, within-student variation, and between-counselor variation | G1 vs. G3: 0.06, SE=0.12, p=0.65 G2 vs. G3: 0.15, SE=0.12, p=0.21
Lochman et al., 2009^88^ Cluster RCT/Unclear | | G1: 168 G2: 183 G3: 180 | Targeted processes: beta coefficient, SE, and p-value for Outcome Expectations Questionnaire (child-rated) score change at 2 yrs in HLM analyses adjusted for baseline score, within-student variation, and between-counselor variation | G1 vs. G3: −0.24, SE=0.12, p=0.05 G2 vs. G3: 0.05, SE=0.12, p=0.67
Lochman et al., 2009^88^ Cluster RCT/Unclear | | G1: 168 G2: 183 G3: 180 | Targeted processes: beta coefficient, SE, and p-value for inconsistent discipline (parent-rated) score change at 2 yrs in HLM analyses adjusted for baseline score, within-student variation, and between-counselor variation | G1 vs. G3: 0.03, SE=0.11, p=0.80 G2 vs. G3: 0.04, SE=0.11, p=0.75

CP-BT = Coping Power-Basic Training; CP-TF = Coping Power-Training plus Feedback; EBP = evidence-based practice; G = group; HLM = hierarchical linear modeling; N = number; OR = odds ratio; RCT = randomized controlled trial; RR = relative risk; p = p-value; SE = standard error; yr = year.

###### Risk of Bias Considerations

We rated the study as having high risk of bias because of high rates of patient attrition for the secondary outcomes (53.6% attrition for completion of study schedules and 62.0% attrition at 4-month followup). The authors did not use intention-to-treat models or adjust analyses for baseline differences across groups. For example, the randomization did not preclude the overrepresentation of young people from black and ethnic minority communities, but this difference was not accounted for in the analyses.

###### Conclusion and Strength of Evidence

We rated the evidence on a general professional training strategy to improve the identification and referral of cases of first-episode psychosis in young adults ages 14 to 30 as insufficient for early referral to care (patient access) or mental health symptoms and low for benefit for service utilization (a significant reduction in the duration of untreated psychosis) (Table F-3). The evidence consisted of a single publication that presented data from a stratified cluster RCT, with high study limitations and imprecise results. The strategy included educational meetings or materials and educational outreach visits components.

##### Training Practitioners With or Without Feedback To Implement an EBP

###### Study Description

One cluster RCT study^88^ focused on training school counselors to prevent the development of externalizing disorders among children at high risk for aggression. The investigators trained school counselors to use the Coping Power (CP) program with third-grade children at high risk for aggressive behaviors as they transitioned to middle school. Study investigators randomly assigned counselors to one of three study arms: CP training plus feedback (CP-TF), CP-basic training (CP-BT), or comparison; thus, the two groups’ testing strategies differed with respect to training intensity. Study investigators randomly assigned school counselors in 57 public schools to one of the three conditions, resulting in 19 schools per condition: 15 counselors in CP-TF, 17 in CP-BT, and 17 in the comparison group. Teachers nominated at-risk students using a rating scale for aggressive behavior. Investigators excluded the upper 2 percent of aggressive students because they were believed to be likely to have psychiatric diagnoses and were not appropriate for the indicated prevention programs. A total of 1,422 children met inclusion criteria from a screened sample of 3,838 children. The investigators were able to make contact with 670 of these potential participants, and 531 agreed to participate (79%). Sixty-five percent of the screened sample was boys. Eighty-four percent were African Americans, 14 percent were Caucasians, and 2 percent were of other race/ethnicity.

CP-TF provided more intensive training than CP-BT and had four components: (1) school counselors received three initial workshop training days in the fall, (2) school counselors participated in monthly ongoing 2-hour training sessions, (3) the trainers made individualized consultation to the school counselors available by email and telephone, and (4) the trainers reviewed the rate of completion of session objectives and provided individualized supervisory feedback through written and telephone contact on the quality of their intervention implementation to enhance EBP intervention integrity. The feedback involved the trainer reviewing whether intervention objectives were met for each session and discussing the involvement and enthusiasm of the participants, as well as whether the counselors were using appropriate monitoring techniques.^99^ This feedback was viewed as the most important component of the intervention, because prior studies had shown that successful engagement of students and parents in the CP intervention was critical to success, as was maintaining their active involvement and attendance once engaged.^99^ CP-BT did not include feedback but comprised the same first two training components as CP-TF. In the CP-BT group, school counselors received 3 training days in the fall and monthly 2-hour training sessions. Eight variables evaluated concrete aspects of program delivery and counselor engagement in delivering the program. Research assistants coded seven of these measures from audiotapes of child and parent sessions by using the objectives list for CP sessions after each EBP intervention session. Ninety-four percent of the parents and children and 88 percent of teachers in the sample provided assessment data. The authors tested baseline differences between completers and those lost to followup within each of the three groups for each of seven outcomes and found significant differences on 3 of the 21 tests. In the comparison condition, those lost to followup had higher externalizing problems and lower social skills according to parents; conversely, they also had lower expectations that aggression would lead to better outcomes than completers in the comparison condition. Thus, the authors concluded that there were no clear patterns of differential attrition.

The authors used hierarchical linear modeling (HLM) to evaluate the effects of the strategy on poststrategy assessments of three externalizing behaviors and four positive targeted processes collected from children, caretakers, and/or teachers 2 years after baseline data collection. Intermediate outcomes included implementation outcome comparisons between CP-TF and CP-BT strategy group children. These included, for both children and for parents, number of sessions scheduled and attended, rates of strategy objectives completed, number of contacts with trainers, and ratings of counselors’ engagement. Patient health and service utilization outcomes included children’s externalizing behavior problems (as rated by teachers, parents, and children), positive social and academic behaviors as rated by parents and teachers, children’s outcome expectations for aggressive behavior, and parents’ consistency of discipline. Study investigators compared scores for participants in the TF group and BT group with scores of participants in the comparison group.

###### Intermediate Outcomes

The study did not examine differences in intermediate outcomes between groups. It did, however, present intermediate outcomes for differences between the two strategy groups that differed based on training intensity, which we considered to be relevant to KQ 3. We describe these comparisons below in the KQ 3 section.

###### Patient Health and Service Utilization Outcomes

The study found that children in the CP-TF group showed larger decreases in teacher-rated externalizing problems and child-rated minor assaults, as well as larger increases in teacher-rated social and academic competence than the control group children at 2-year followup (Table 9). The study reported no significant differences (p>0.05) on any of these outcomes between children in the CP-BT group and children in the comparison group.

###### Risk of Bias Considerations

We rated this study as having unclear risk of bias. The authors did not report details about the randomization method, allocation concealment, blinding of outcome assessors, or fidelity to protocol. Further, the study did not report differences in baseline characteristics between groups so the success of the randomization method is unknown. In addition, analyses only adjusted for clustering within students, clustering between counselors, and baseline levels of each outcome, so any significant differences in characteristics by group membership were uncontrolled. Although attrition was not at a concerning level (6% for parents and 12% for teachers), the authors noted some differences in characteristics between those lost to followup and completers (data not reported). Furthermore, the authors did not use intention-to-treat analyses.

###### Conclusion and Strength of Evidence

We graded the strength of evidence on a strategy training school counselors to prevent the development of externalizing disorders among children at high risk for aggression as low for no benefit for one outcome and low for benefit for another. The evidence consisted of a single publication that presented data from a cluster RCT with medium study limitations and precise results. Specifically, the strategy included educational meetings and materials and audit and feedback components. The study found no improvements in mental health symptoms but increases in socialization skills and behaviors. This study examined the effect of altering the level of intensity in disseminating a prevention training and feedback program (Table F-4).

##### Training Practitioners To Use a Patient Medication Monitoring Program

###### Study Description

One interrupted time-series study (outcomes were averaged across patients before and after the strategy)^95^ evaluated the effect of a strategy to train practitioners to monitor patients on second-generation antipsychotics (SGAs) using a metabolic monitoring training program (MMTP). The MMTP instructed prescribers among the Vancouver Health Child and Youth Mental Teams on best practice in metabolic monitoring and the use of a metabolic monitoring and documentation tool (MMT). The study analyzed four data points before (from September 1, 2007, through December 31, 2008) and four after implementing the MMTP (from January 1, 2009, through April 20, 2010). The sample before MMTP implementation (N=1,114) was evaluated at baseline, 3, 6, and 12 months. The sample after MMTP implementation (N=1,262) was evaluated starting from a baseline measure (immediately after MMTP implementation) and then at 3, 6, and 12 months post-MMTP, using retrospective chart reviews.

###### Intermediate Outcomes

A chart review revealed that the MMT was in the chart of 38.3 percent of recipients of SGAs after implementation. The study also reported a drop in the prevalence of SGA prescribing from pre-MMTP period to post-MMTP (Table 10).

Table 10 Training practitioners to use an MMTP: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Ronsley et al., 2012^95^ Interrupted time series-retrospective chart review/Unclear | G1: 1,262 post-MMTP patients G2: 1,114 pre-MMTP patients All professional components (educational materials, educational meetings, educational outreach visits, reminders, and one other—online access and project coordinator) differed across study arms (comparison group strategy contained no components) | G1: Patient MMTP for practitioners G2: Usual care | Proportion with SGA prescription Timing unclear | G1: 172/1,114 (15.4%) G2: 81/1,262 (6.4%) Calculated OR: 0.376; 95% CI: 0.284 to 0.496, p<0.001

CI = confidence interval; G = group; MMTP = Metabolic Monitoring Training Program; N = number; OR = odds ratio; p = p-value; SGA = second-generation antipsychotic.

###### Patient Health and Service Utilization Outcomes

For SGA-treated patients, the authors also reported monitoring rates pre- and postimplementation for anthropometric measures (height, weight, waist circumference, and blood pressure) and blood work parameters (fasting glucose, insulin, total cholesterol, triglycerides, high-density lipoprotein cholesterol or low-density lipoprotein cholesterol alanine aminotransferase or aspartate aminotransferase, prolactin). The authors reported that all measures were statistically significantly between pre-MMTP and post-MMTP measures at baseline, at 3 and 6 months, but not at 12 months. Our calculated OR, however, based on overall reported Ns (Appendix E) suggests a decline in OR over time for some but not all measures. Nearly all measures continue to have statistically significant effects over time.

###### Risk of Bias Considerations

The study did not report many key details pertaining to design and conduct. For example, we could not ascertain the proportion of patients that were retained in the sample before and after MMTP. A key concern for time-series and other types of ecological or aggregate studies relates to unmeasured concomitant strategies or secular changes. The rates of metabolic monitoring declined over time in both the pre-MMTP and the post-MMTP period. The authors did not comment on reasons for a decline in the pre-MMTP period, but in the absence of an active strategy during this phase, it is unclear whether concomitant external changes explain the pre-MMTP trend toward lower monitoring. Without further information on the reasons for the decline over time in monitoring before program implementation, the large differences between the pre-MMTP period and the post-MMTP period cannot be confidently attributed to the strategy alone. As a result, we rated this study as having unclear risk of bias.

###### Conclusion and Strength of Evidence

We graded the strength of evidence for a strategy training practitioners to use medication monitoring as low for benefit. The evidence consisted of one observational single study with high risk of study limitations and precise results. The strategy included educational meetings or materials, educational outreach visits, and reminders. Specifically, the study found that establishing an MMTP increases practitioner adherence and appropriate service utilization (Table F-5).

##### Adding Computer-Assisted Training With or Without Ongoing Supervision and Coaching to Practitioners Implementing an EBP

###### Study Description

One cluster RCT^91^ evaluated practitioner training strategies with increasing intensity to implement contingency management (CM) in community mental health centers that serve youth with substance use disorders. CM techniques provide concrete rewards for behaviors incompatible with substance use. The study tested the strategies by randomizing 161 therapists from 10 agencies to one of three training groups: (1) a workshop (WSR) enhanced with access to resources needed to implement CM such as worksheets, therapist scripts, and urine drug screens; (2) WSR plus computer-assisted training (CAT) for 6 months following the workshop (WSR+CAT); and (3) WSR+CAT and ongoing supervision and coaching that included site visits, booster trainings, and biweekly telephone consultations between CM experts and supervisors for 12 months following the workshop (WSR+CAT+SS).

Outcome measures included measures of therapist CM use (the proportion of patients treated for substance use disorders treated with CM), knowledge via the CM Knowledge Test to assess changes in CM knowledge (scaled range 0–100), and adherence via cognitive behavioral (range 0–19) and monitoring subscales (range 0–15) from a revised CM-Therapist Adherence Measure (TAM) measure collected from therapists at baseline and every 2 months for 1 year after baseline. The authors used HLM to analyze the data.

###### Intermediate Outcomes

Therapists in each group (WSR, WSR+CAT, and WSR+CAT+SS) had significant improvements in CM use, knowledge, cognitive behavioral adherence, and monitoring adherence, but there were no significant differences in improvement among groups (Table 11). The authors reported that differences were not significant and significance could not be calculated from raw data given clustering of data.

Table 11 Adding computer-assisted training with or without ongoing supervision and coaching to practitioners implementing an EBP: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Henggeler et al., 2013^91^ Cluster RCT/Unclear bias | G1: Workshop enhanced with ongoing access to CM implementation resources (WSR) G2: WSR plus CAT for 6 months following workshop (WSR+CAT) G3: WSR+CAT plus ongoing support from a CM expert for 12 months following workshop (WSR+CAT+SS) Two components (both professional components—intensity of educational materials and educational outreach visits) differed across study arms (only WSR+CAT+SS had educational outreach visits, and additional educational materials were included in WSR+CAT and WSR+CAT+SS groups) | G1: 52 G2: 53 G3: 56 | Therapist reported CM use | All groups significantly improved during 12-month followup, but no significant differences in improvement among the groups
Henggeler et al., 2013^91^ Cluster RCT/Unclear bias | | | Therapist reported CM knowledge | All groups significantly improved during 12-month followup, but no significant differences in improvement among the groups
Henggeler et al., 2013^91^ Cluster RCT/Unclear bias | | | Therapist reported CM adherence (cognitive behavioral subscale) | All groups significantly improved during 12-month followup, but no significant differences in improvement among the groups
Henggeler et al., 2013^91^ Cluster RCT/Unclear bias | | | Therapist reported CM adherence (monitoring subscale) | All groups significantly improved during 12-month followup, but no significant differences in improvement among the groups

CM = contingency management; EBP = evidence-based practice; G = group; N= number; RCT = randomized clinical trial; WSR = workshop plus resources; WSR+CAT = workshop plus resources plus computer-assisted training; WSR+CAT+SS = workshop plus resources plus computer-assisted training plus supervisory support.

###### Patient Health and Service Utilization Outcomes

Neither study reported patient health and service utilization outcomes, but the first study cited an earlier study for evidence of effectiveness of CM for improving youth substance abuse outcomes.^100^

###### Risk of Bias Considerations

The study provided insufficient information to judge risk of bias on most criteria. Although the authors note randomization at the level of public-sector provider organizations (N=10), the authors did not provide enough information to judge whether the study was fully randomized. For example, they offered no details on sequence generation or allocation concealment. Other unclear aspects of study design and conduct include validity of inclusion and exclusion criteria, blinding of outcome assessors, fidelity of the intervention, potentially concurrent interventions, attrition rate, and potential for crossover or contamination.

###### Conclusion and Strength of Evidence

We graded the strength of evidence of a strategy adding computer-assisted training to practitioners implementing an EBP as insufficient for practitioner use, knowledge, and adherence competence/skills (Table F-6). No information was provided on patient health and service utilization outcomes. The evidence consisted of one trial with medium study limitations and imprecise results arising from small sample sizes. Specifically, the strategy tested increasingly intensive practitioner training strategies to implement CM as compared with the group with lowest intensity, workshop plus resources.

#### Financial or Organizational Change Strategies

Ten studies reported in 11 publications focused on changing systems of care.^13,14,67,68,84–86,89,92–94^ These studies each included at least one financial or organizational component according to the EPOC taxonomy. These components included provider incentives (a financial component); clinical multidisciplinary teams and strategies to “boost morale” by facilitating conditions to improve provider satisfaction with conditions of their work (organizational provider components); and/or quality monitoring, staff organization, and enhanced referral and choice of treatment (organizational structural components). The target of these strategies ranged from primary care clinicians or pediatricians (n=3) to community-based mental health therapists (n=3 with outcomes reported in 4 studies) or substance use providers (n=1) and practitioners in private, for-profit behavioral health organizations providing home-based treatment (n=1), practices (n=1), and organizations (n=1). These studies ultimately targeted patients with attention deficit hyperactivity disorder (ADHD) (n=3), externalizing problems (n=2), substance use problems (n=3), and general mental health problems (n=2 with outcomes reported in 3 studies). We provide further details for each strategy below.

##### Providing Practitioner Access to Practice Guidelines Via an Internet Portal

###### Study Description

One cluster RCT^85^ examined the impact of an ADHD assessment and medication management program, facilitated through an Internet platform to pediatricians in primary care practices. The authors reported that the program was based on the evidence base for the American Academy of Pediatricians guideline recommendations. The trial included 511 children and 49 pediatricians spread across 8 practices. Each matched practice pair (created according to the number of pediatricians and percentage of patients with Medicaid) was randomly allocated to either the strategy group (n=4 practices) or the control group (n=4 practices). The strategy group received the strategy immediately, while the control group received it after 6 months. Intervention practices participated in four 1-hour sessions of training on the new system, including didactic lectures and office flow modification workshops. Practices were then given access to an ADHD Internet portal that allowed parents, teachers, and pediatricians to input information (e.g., rating scales) about patients, after which information was scored, interpreted, and formatted in a report style that was helpful for assessing and treating patients with ADHD. Physicians evaluated their practice behaviors quarterly and addressed underperforming areas. Investigators conducted chart reviews at baseline and at 6-month followup for evidence of documentation of 5 guideline-specific measures. Investigators compared the percentage change in patients for whom each physician used each guideline behavior between baseline and followup between the strategy and control group using intent-to-treat analysis using t-tests. They did not account for clustering, given the small number of practices (n=8). They did not report differences in baseline levels of each outcome.

###### Intermediate Outcomes

The study compared several practitioner adherence and model program fidelity outcomes across study arms. Physicians in the strategy group had a higher mean change in the proportion of using parent ratings for assessment than physicians in the control group, the proportion using teacher ratings for assessment, and the proportion using Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV) ADHD criteria during assessment (Table 12). Pediatricians in the strategy group had greater decreases in the change in the proportion of using outside practitioners for ADHD diagnosis and in the proportion using teacher ratings to monitor treatment responses. The difference in the proportion of pediatricians using parent ratings to monitor treatment responses between the strategy and control group did not reach significance.

Table 12 Providing practitioner access to practice guidelines via an Internet portal: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Epstein et al., 2011^85^/Cluster RCT/Unclear | G1: Internet portal providing practitioner access to practice guidelines G2: Wait-list control All components (5 professional components—distribution of educational materials, educational meetings, patient-mediated interventions, audit and feedback, and reminders’ 1 financial component—provider incentives’ 2 organizational provider-oriented components—clinical multidisciplinary teams) differed across study arms (comparison group strategy contained no components) | G1: 4 practices, 27 pediatricians, 501 patients G2: 4 practices, 22 pediatricians, 245 patients | Difference in mean baseline to 6-month followup change in proportion of practitioners using parent ADHD ratings during assessment | 18.1, 95% CI, 2.05 to 34.2
Epstein et al., 2011^85^/Cluster RCT/Unclear | | G1: 4 practices, 27 pediatricians, 501 patients G2: 4 practices, 22 pediatricians, 245 patients | Difference in mean baseline to 6-month followup change in proportion of practitioners using teacher ADHD ratings during assessment | 16.6, 95% CI, 1.61 to 31.6
Epstein et al., 2011^85^/Cluster RCT/Unclear | | G1: 4 practices, 27 pediatricians, 501 patients G2: 4 practices, 22 pediatricians, 245 patients | Difference in mean baseline to 6-month followup change in proportion of practitioners using DSM-IV criteria during assessment | 29.4, 95% CI, 5.98 to 52.8
Epstein et al., 2011^85^/Cluster RCT/Unclear | | G1: 4 practices, 27 pediatricians, 501 patients G2: 4 practices, 22 pediatricians, 245 patients | Difference in mean baseline to 6-month followup change in proportion of practitioners using an outside practitioner for ADHD diagnosis | −50.0, 95% CI, −70.5 to −29.5
Epstein et al., 2011^85^/Cluster RCT/Unclear | | G1: 4 practices, 27 pediatricians, 501 patients G2: 4 practices, 22 pediatricians, 245 patients | Difference in mean baseline to 6-month followup change in proportion of practitioners using parent ratings of ADHD to monitor treatment responses | 23.2, 95% CI, −1.78 to 48.2
Epstein et al., 2011^85^/Cluster RCT/Unclear | | G1: 4 practices, 27 pediatricians, 501 patients G2: 4 practices, 22 pediatricians, 245 patients | Difference in mean baseline to 6-month followup change in proportion of practitioners using teacher ratings to monitor treatment responses | 32.4, 95% CI, 12.1 to 52.7

ADHD = attention deficit hyperactivity disorder; CI = confidence interval; DSM-IV = Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition; G = group; N = number; RCT = randomized controlled trial.

###### Patient Health and Service Utilization Outcomes

The study did not report any final health or utilization outcomes. The strategy used an EBP (clinical practice guidelines set forth by the American Academy of Pediatrics).^101,102^

###### Risk of Bias Considerations

We rated this study as having unclear risk of bias. The eight participating practices were matched according to number of pediatricians in the practice and the percentage of children on Medicaid; however, the study did not clarify whether other important differences existed in the practitioners or the patients between these practices. In addition, the study did not clarify whether patients were blinded to the strategy or whether outcome assessors were blinded to the outcome status of participants. The trial reported insufficient information to judge risk of bias on some criteria. For example, differences in baseline characteristics between groups are not reported. An RCT is likely to have few differences between groups, but we could not assess the success of the randomization in this study.

###### Conclusion and Strength of Evidence

We graded the strength of evidence on a strategy providing pediatricians with access to ADHD guidelines through an Internet portal as low for benefit. The evidence consisted of a single-cluster RCT, with medium study limitations and imprecise results (Table F-7). The strategy included educational meetings or materials, patient-reported data, audit and feedback, reminders, and quality monitoring. Specifically, the study yielded low strength of evidence for intermediate outcomes of practitioner protocol adherence and program model fidelity The Internet portal has since been adopted in a range of settings.^103^ A case study found that physicians’ interest in adoption stemmed from the desire to improve ADHD care and to earn continuing medical education credits.

##### Adding Weekly Feedback to Practitioners Regarding Patient Symptoms and Functioning

###### Study Description

One cluster RCT^13^ evaluated the addition of weekly feedback of patient mental health symptoms and functioning as rated by youths, caregivers, and clinicians to therapists (the Contextualized Feedback System [CFS]) in addition to standard 90-day feedback. The study hypothesized that this weekly feedback addition would improve mental health treatment effectiveness in a private mental health treatment organization. Clinicians in the control group received only the 90-day feedback. The trial initially randomized 24 sites to the group receiving the additional weekly feedback and 25 sites to the comparison group. Over 40 percent of the sites (21 sites in total, 11 experimental, 10 control) dropped out of the study. The Symptoms and Functioning Severity Scale (SFSS, range 1–5) was scheduled to be completed every 2 weeks, but at least one measure in the battery was scheduled to be collected every week. The actual rate of data collection was lower than planned (mean records per youth: 11±9.2; mean number of weeks participated: 16.5±13.6), resulting in 1,341 SFSS scales from 340 youths, 1,291 SFSS scales from 144 clinicians, and 935 SFSS scales from 383 caregivers.

###### Intermediate Outcomes

Although the study did not specify an intermediate outcome, it reported results pertaining to practitioner adherence (Table 13). Specifically, at the onset of the study, the trial was intended to be a 2×2 factorial design with the two feedback groups described above and the presence or absence of three Web-based modules (on therapeutic alliance, expectations about counseling, and collaborative treatment planning). The study reported that only 31 (the authors note that N=31 was one-third of the sample but do not specify the denominator) practitioners accessed the Web-based module before their first client, indicating failure of practitioner adherence to the Web-based modules. Study authors then analyzed data by the feedback condition (weekly plus cumulative feedback vs. cumulative feedback only). The authors reported no statistical differences in reasons for attrition between experimental and control groups but provided no additional details.

Table 13 Adding weekly feedback to practitioners regarding patient symptoms and functioning: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Bickman et al., 2011^13^ Cluster RCT/High | G1: Weekly and cumulative 90-day feedback of patient symptoms and functioning (CFS) to practitioners G2: Cumulative 90-day feedback only of patient symptoms and functioning (CFS) to practitioners Single difference in the presence of the organizational structural component, frequency of quality monitoring across arms | G1: 13 sites, 167 youths, 169 caregivers, 64 clinicians G2: 15 sites, 173 youths, 214 caregivers, 80 clinicians Total scales analyzed (breakdown by trial arm NR): youth, N=1,341; clinicians, N=1,291; caregivers, N=935 | Youth-reported functional severity Estimated coefficient of membership in feedback group at baseline | 0.02, SE: 0.10, p>0.005
Bickman et al., 2011^13^ Cluster RCT/High | | | Estimated coefficient of slope (time in weeks) | −0.001, SE: 0.002, p<0.0001
Bickman et al., 2011^13^ Cluster RCT/High | | | Estimated coefficient of interaction of membership in feedback group and slope | −0.01, SE: 0.002, p<0.001
Bickman et al., 2011^13^ Cluster RCT/High
Bickman et al., 2011^13^ Cluster RCT/High | | | Clinicians-reported functional severity Estimated coefficient of membership in feedback group at baseline | 0.10, SE: 0.10, p>0.005
Bickman et al., 2011^13^ Cluster RCT/High | | | Estimated coefficient of slope (time in weeks) | −0.005, SE: 0.001, p<0.0001
Bickman et al., 2011^13^ Cluster RCT/High | | | Estimated coefficient of interaction of membership in feedback group and slope | −0.01, SE: 0.002, p<0.0001
Bickman et al., 2011^13^ Cluster RCT/High
Bickman et al., 2011^13^ Cluster RCT/High | | | Caregivers-reported functional severity Estimated coefficient of membership in feedback group at baseline | 0.01, SE: 0.13, p>0.005
Bickman et al., 2011^13^ Cluster RCT/High | | | Estimated coefficient of slope (time in weeks) | −0.003, SE: 0.002, p>0.05
Bickman et al., 2011^13^ Cluster RCT/High | | | Estimated coefficient of interaction of membership in feedback group and slope | −0.01, SE: 0.003, p<.0001

CFS = Contextualized Feedback System; G = group; N = number; NR = not reported; p = p-value; RCT = randomized controlled trial; SE = standard error.

###### Patient Health and Service Utilization Outcomes

The authors conducted an HLM that nested repeated measures within participants, youths within clinicians, and clinicians within sites. They estimated three HLMs for each respondent type. The models accounted for repeated measures at unequal durations within and across respondents using restricted maximum likelihood estimation and baseline differences by race through inclusion of race in the model. The study reported no difference at baseline in SFSS between groups (Table F-8). Over time (the slope coefficient in the model), youths and clinicians reported significant improvement in SFSS scores, but caregivers did not. All three groups reported a higher rate of change in improvement in SFSS in the experimental group as calculated by study authors using the HLM-estimated coefficients measured at the average length of presence in the CFS.

###### Risk of Bias Considerations

As noted above, 21 of 49 sites dropped out of the study after randomization, increasing the potential for high risk of bias. The authors noted that they conducted intention-to-treat analysis but did not specify whether their analysis pertained to all randomized sites or all patients within randomized sites. Although the authors noted no statistically significant differences for attrition, they did not provide details to judge these differences. Additionally, the publication did not provide key details on study design and conduct such as blinding of patients and outcome assessors, method of randomization, allocation concealment, fidelity to protocol, and timing of outcome measurement. Thus, we rated this study as having high risk of bias.

###### Conclusion and Strength of Evidence

We graded the strength of evidence on a strategy to add weekly feedback to practitioners regarding patient symptoms and functioning as insufficient for clinician adherence and low for functional severity (Table F-8). The evidence consisted of one study with a high risk of study limitations and lack of contextual details for poor clinician adherence. The strategy consisted of quality monitoring (and organizational structural component). Although measurement feedback systems like the CFS potentially hold promise in improving clinical and organizational learning, little is known about how therapists use the feedback and when they should use it.^104^ An attempt to widely implement a second generation of the CFS (called Contextualized Feedback and Intervention and Treatment) was not eligible for this review because the study design did not permit us to disentangle the effect of the intervention from its implementation.^105^ The study noted substantial differences in implementation. In one site, the modal implementation score was zero, meaning no respondents completed the questionnaire or no clinician reviewed any feedback reports), suggesting substantial implementation challenges. In the other site, the modal score was above 50 (e.g., respondents completed forms half the time, clinicians viewed the forms half the time). The authors note differences between the sites in the way the feedback was collected (paper vs. electronic forms) and the nature of the supervision, suggesting that even in RCTs of complex systems interventions, factors outside the intervention components in the protocol can influence success and failure.

##### Adding Diagnosis and Treatment Guidelines to a Computer Decision Support System

###### Study Description

One cluster RCT^89^ evaluated the enhancement of a computer decision support system to improve the quality of ADHD diagnosis and treatment patterns, across 4 clinics and 84 patients (2 clinics and 42 patients per group). The strategy group used a previously studied intervention, Child Health Improvement through Computer Automation, with ADHD guidelines embedded in the computer decision support system. The comparison group used this intervention without embedded ADHD guidelines. In addition to adherence to ADHD guidelines before and after the strategy, the study evaluated changes in prescriber behavior and skills, including changes in medication-prescribing patterns and mental health referral rates.

###### Intermediate Outcomes

The study reported several measures of improvements in practitioner adherence to using guideline-based care (Table 14). Children in the computer decision support arm were more likely to have been assessed using formal diagnostic tools than children in the control arm. The authors also reported higher but not statistically significant differences in medication-prescribing patterns, reassessment of symptoms, or mental health referral rates. They noted that the study was underpowered to measure those outcomes. The authors reported a significant increase in the number of reported ADHD symptoms at the time of diagnosis in three out of four symptom domains.

Table 14 Adding diagnosis and treatment guidelines to a computer decision support system: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Carroll et al., 2013^89^ Cluster RCT/Unclear | G1: Computer decision support plus EHR that included diagnosis and treatment guidelines G2: Computer decision support plus EHR without diagnosis and treatment guidelines. All components (2 professional components—patient-mediated intervention and reminders specific to ADHD and 1 organizational structural component—quality monitoring specific to ADHD) differed across study arms (comparison group strategy contained no components) | G1: 2 practices (42 patients) G2: 2 practices (42 patients) | Use of formal diagnostic assessment | Adjusted OR, 8.0; 95% CI, 1.6 to 40.6 p-value not reported Adjusted for age, gender, race/ethnicity, and insurance
Carroll et al., 2013^89^ Cluster RCT/Unclear | | G1: 2 practices (42 patients) G2: 2 practices (42 patients) | Number of core ADHD symptoms noted at baseline (exact N and SD of symptoms not reported by authors) | Estimated mean difference G2-G1: Inattentive symptom (home): −2.1, reported p<0.05 Inattentive (school): −0.9 reported p<0.05 Hyperactive (home): −2.2 reported p<0.05 Hyperactive (school): −1.2 reported p=0.075
Carroll et al., 2013^89^ Cluster RCT/Unclear | | G1: 2 practices (42 patients) G2: 2 practices (42 patients) | Documented medication adjustments | G1=45% G2=33% Calculated OR, 1.652; 95% CI, 0.683 to 3.998; p=0.266; reported p=0.45
Carroll et al., 2013^89^ Cluster RCT/Unclear | | G1: 2 practices (42 patients) G2: 2 practices (42 patients) | Reassessment of symptoms at followup visit | G1=50% G2=33% Calculated OR, 2.00; 95% CI, 0.829 to 4.838; p=0.123, reported p=0.36
Carroll et al., 2013^89^ Cluster RCT/Unclear | | G1: 2 practices (42 patients) G2: 2 practices (42 patients) | Mental health referral | G1=74% G2=55% Calculated OR, 2.323; 95% CI, 0.928 to 5.817; p=0.072, reported p=0.09
Carroll et al., 2013^89^ Cluster RCT/Unclear | | G1: 2 practices (42 patients) G2: 2 practices (42 patients) | Mental health visit | G1=67% G2=48% Calculated OR, 2.195; 95% CI, 0.909 to 5.303; p=0.081, reported p=0.054

ADHD = attention deficit hyperactivity disorder; CI = confidence interval; EHR = electronic health record; G = group; N = number; OR = odds ratio; p = p-value; RCT = randomized controlled trial; SD = standard deviation.

###### Patient Health and Service Utilization Outcomes

Based on reported study data, we calculated wide and overlapping CIs for improvement in visits to mental health specialists in the strategy arm when compared with the control arm (Table 15).

Table 15 Adding IQA to implement an EBP: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Henggeler et al., 2008^93^ CCT/Unclear | G1: IQA system to implement an EBP intervention (CM) G2: Workshop only to implement an EBP intervention (CM) Two components (a financial patient component—patient incentives and an organizational structural component—quality monitoring) differed across study arms (comparison group strategy contained no components) | G1: 18 G2: 12 | Gamma for youth report of therapist use of CM through 4 months postworkshop | Gamma =0.78, SE=0.36, p=0.04
Henggeler et al., 2008^93^ CCT/Unclear | | G1: 18 G2: 12 | Gamma for youth report of therapist use of CM in the following 6-month sustainability period | Gamma =0.12, SE=0.14, p=NS, details NR
Henggeler et al., 2008^93^ CCT/Unclear | | G1: 18 G2: 12 | Gamma for youth report of clinician use of CM monitoring at 4 months | Gamma =0.03, SE=0.04, p=NS (these are single-arm results, between-group differences not reported)
Henggeler et al., 2008^93^ CCT/Unclear | | G1: 18 G2: 12 | Gamma for caregiver report of clinician use of CM monitoring at 4 months | Gamma =0.09, SE=0.10, p=NS (these are single-arm results, between-group differences not reported)
Henggeler et al., 2008^93^ CCT/Unclear | | G1: 18 G2: 12 | Gamma for caregiver report of clinician use of CM at 4 months postworkshop | Gamma =0.79, SE=0.30, p=0.01 linear Gamma=0.18, SE=0.09, p=0.04 quadratic
Henggeler et al., 2008^93^ CCT/Unclear | | G1: 18 G2: 12 | Gamma for caregiver report of clinician use of CM 4 months postworkshop | Gamma=0.05, SE=0.54, p=NS

CCT = controlled clinical trial; CM = contingency management; EBP = evidence-based practice; G = group; IQA = Intensive Quality Assurance; N = number; NR = not reported; NS = not significant; SE = standard error.

###### Risk of Bias Considerations

Some details pertaining to study design and conduct were not reported, such as randomization approach and allocation concealment, baseline differences in clinics, blinding of outcome assessors, and fidelity to the protocol, leading to an unclear risk of bias.

###### Conclusion and Strength of Evidence

We graded the strength of evidence on a strategy to add diagnosis and treatment guidelines to a computer decision support system as low for practitioner uptake of guidelines for diagnostic assessment and for practitioner skills in measuring ADHD symptoms at diagnosis and insufficient for practitioner competence (specifically on reassessment of symptoms at 3 months, adjustment of medications, mental health referral) and for service utilization (visits to mental health specialist) (Table F-9). The evidence consisted of one cluster RCT with medium study limitations, imprecise results with a small number of events, and a large magnitude of effect. The strategy included two professional components, patient-mediated intervention and reminders, and one organizational structural component, quality monitoring.

##### Adding Intensive Quality Assurance To Implement an EBP

###### Study Description

One CCT,^93^ with arms assigned at the therapist level, evaluated different ways of integrating an evidence-based intervention (CM) into an existing treatment (multisystemic therapy [MST]) for adolescent marijuana abuse employed in community settings. The study tested the use of Intensive Quality Assurance (IQA) to promote therapist implementation of CM techniques in a community mental health center setting. CM techniques provide concrete rewards for behaviors incompatible with substance use. All practitioners selected for inclusion in the study had already adopted and implemented an EBP (MST) to ensure that they had experience with implementing new treatments in the past and were amenable to such change.

During the 5-month baseline period, the practitioners could access CM financial resources to facilitate MST treatment goals (the current treatment they used) but had not yet received CM protocol training. At the conclusion of the baseline period, practitioners received CM training materials and attended a 2-day CM workshop. Following the workshop, researchers randomized five supervisors and their eight teams (i.e., some supervisors had multiple teams and in that instance, teams with the same supervisor were randomized to the same condition) to IQA or workshop-only (WSO) groups. During the 4-month postworkshop period and the following 6-month sustainability period, all practitioners continued to have access to the CM financial resources. In addition, the IQA group received weekly expert case consultation on CM cases, incorporated feedback on how to improve CM skills and competencies into their existing clinician development plans, and received quarterly booster training. The WSO group clinicians received phone and email access to a CM expert for consultation upon request during the postworkshop period. Both IQA and control group practitioners could access $150 for each patient to facilitate treatment goals; however, while those in the control group could use these funds to facilitate any aspect of treatment, including but not limited to CM interventions, practitioners in the IQA group were restricted to using these funds only for the CM voucher system that rewarded patients for clean drug screens.

Analyses included data from 18 practitioners in the IQA group and 12 in the WSO group. The study conducted complex analyses of linear and quadratic trajectories of change over time in ratings of therapist adherence, using youth and caregiver ratings on the CM Therapist Adherence Measure. This measure included five items on a 4-point scale to measure CBT techniques and four items on a 3-point scale to measure monitoring techniques. These items were measured on monthly intervals from each family, leading to clustering within clinicians. The analysis used HLM to account for this clustering. Because the study reported only gamma values from these analyses and did not provide sufficient additional information to provide context, our interpretation of their results is limited to the study’s reported p-values.

###### Intermediate Outcomes

The study reported several measures of practitioner adherence and program fidelity. IQA was more effective than control at increasing practitioner implementation of CM cognitive behavioral techniques in the short term, based on youth and caregiver reports (Table 15). The study also reported (in text) that, based on youth reports, the effect of IQA was sustained. However, based on reported p-values and the discussion in the study, these increases did not appear to be sustained at 6 months for both youth and caregiver reports. The study reported no difference by arm for practitioner implementation of CM monitoring techniques at 4 months and did not conduct further analyses at 6 months.

###### Patient Health and Service Utilization Outcomes

The study did not report any patient health and service utilization outcomes but cited an earlier study for evidence of effectiveness of CM for improving youth substance abuse outcomes.^100^

###### Risk of Bias Considerations

The study provided insufficient information to judge risk of bias on most criteria. Although the authors note randomization at the level of the supervisor (N=5) and their teams (N=8), they did not provide enough information to judge whether the study was fully randomized. For example, they offered no details on sequence generation or allocation concealment. They noted that they replaced therapists who left the program within a month, leaving unanswered the question of whether or how the new therapists were trained. Other unclear aspects of study design and conduct include validity of inclusion and exclusion criteria, blinding of outcome assessors, fidelity of the intervention, potentially concurrent interventions, attrition rate, and potential for crossover or contamination.

###### Conclusion and Strength of Evidence

We graded the strength of evidence on a strategy testing an IQA approach to implementing CM vs. a workshop only as insufficient for practitioner adherence and fidelity (Table F-10). The study provided no information on patient health and service utilization outcomes. The evidence consisted of one trial, with unclear risk of bias, high study limitations, and imprecise results. Specifically, the strategy, using a quality monitoring component, found insufficient evidence

##### Collaborative Consultation To Promote the Use of Titration Trials and Periodic Monitoring During Medication Management

###### Study Description

One study^86^ examined the use of a collaborative consultative model to improve the use of titration trials and medication monitoring during medication maintenance for children with ADHD. In this model, mental health experts collect behavioral assessment information from the pediatrician during assessment, a titration trial of medication, or medication maintenance and provided feedback to help guide diagnostic and treatment decisions.

The study randomized by clusters, specifically, by practice. Twelve pediatric practice groups that did not have an on-site psychiatrist or psychologist and did have computerized billing systems were randomized to collaborative consultation (6 practices, 25 pediatricians recruited but data available on 16 pediatricians who saw 59 patients) and control groups (6 practices, 27 pediatricians recruited but data available on 22 pediatricians who saw 87 patients). The study collected outcome data on all patients of enrolled practitioners during the followup period in grades 1 through 5 who presented with an ADHD-related problem but had never been on a stimulant to treat ADHD to collect patient-level outcome data.

Pediatricians in the collaborative consultative service group learned how to use titration trials (to determine optimal dosage) and rating scales (to monitor medication efficacy and side effects during medication maintenance) for all eligible children for whom they elected to prescribe medication to treat ADHD. Control group practitioners did not receive collaborative consultative services and provided children usual care.

Nine pediatricians in the strategy group and five in the control group did not enroll any children. Although the study authors initially conducted HLM analyses, the variance components associated with the pediatric office and individual pediatrician were negligible (variance not reported ) and were therefore dropped from all further analyses.

###### Intermediate Outcomes

Two measures of practitioner adherence/program model fidelity (measured before and after the intervention via practitioner surveys) were compared between study arms. More pediatricians in the strategy group used titration trials than in the control group (Table 16). Both groups improved medication monitoring over time, but the study reported that monitoring did not increase more among pediatricians in the strategy group than in the control group (details not reported).

Table 16 Collaborative consultation to promote the use of titration trials and periodic monitoring during medication management: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Epstein et al., 2007^86^ Cluster RCT/High | G1: Consultative collaborative treatment service to promote the use of titration trials and periodic monitoring during medication management G2: Control Two components (a professional component—audit and feedback and an organizational provider-oriented component—clinical multidisciplinary systems) differed across study arms (comparison group strategy contained no components) | G1 (pediatricians): 16 G2 (pediatricians): 22 | Use of titration trials, a practitioner adherence measure (interaction term from multivariate analysis) | Interaction of group effect and time β=−0.283, SE, 0.09; p<0.01
Epstein et al., 2007^86^ Cluster RCT/High | | G1 (pediatricians): 16 G2 (pediatricians): 22 | Use of medication monitoring (a measure of practitioner adherence) | Time β=0.200; p<0.01, interaction of group and time β NR, but strategy group noted as not having greater increase
Epstein et al., 2007^86^ Cluster RCT/High | | G1 (pediatricians): 16 G2 (pediatricians): 22 | Cited obstacles to implementation of EBPs (a measure of practitioner competence) | Lower odds with overlapping confidence intervals of citing obstacles in 6 of 8 measures (2 reach statistical significance)
Epstein et al., 2007^86^ Cluster RCT/High | G1: Consultative collaborative treatment service to promote the use of titration trials and periodic monitoring during medication management G2: Control Two components (a professional component—audit and feedback and an organizational provider-oriented component—clinical multidisciplinary systems) differed across study arms (comparison group strategy contained no components) | G1 (patients): 59 G2 (patients): 87 | Mean scores for combined parent and teacher ratings of ADHD symptoms NR F score (test statistic for ANOVA comparison of means across groups) for main effect of combined parent and teacher ratings of ADHD symptoms difference between groups at 12 months | F_1,144_=0.05, p=0.83
Epstein et al., 2007^86^ Cluster RCT/High | | G1 (patients): 59 G2 (patients): 87 | Mean scores for combined parent and teacher ratings of ADHD symptoms NR F score (test statistic for ANOVA) for decrease in combined parent and teacher ratings of ADHD symptoms, group × time interaction | F_2,144_=.44, p=0.65

ADHD = attention deficit hyperactivity disorder; G = group; N = number; NR = not reported; p = p-value; RCT = randomized controlled trial.

The study collected one measure of practitioner competence/skills. Our calculated OR for differences in the proportion of pediatricians citing specific obstacles preventing the implementation of evidence-based treatments found lower odds in the strategy arm for all outcomes. These ORs were statistically significant for the cited obstacles of lack of access to medications and lack of time for titration trials only (Appendix E).

###### Patient Health and Service Utilization Outcomes

ADHD scores for children, as rated by parents and teachers (combined in a single analysis), did not differ by group.

###### Risk of Bias Considerations

The study experienced substantial practitioner and patient attrition. For practitioners, the differential rate of engagement was 17.5 percent; 5 of 27 pediatricians in the control group and 9 of 25 in the strategy group did not enroll any children in the study. The study did not offer explanations for differences in the rate of engagement. For patients, of 146 participants selected for followup, 45 had data from all 3 data points. The remaining 101 participants had at least 1 missing data point. The authors used a missing-at-random analysis because their analysis found no differences in DSM-IV–defined ADHD symptomatology at baseline between children with missing data and those who had complete data. Nonetheless, the risk of bias from low practitioner engagement and missing patient data put the study at high risk of bias.

###### Conclusion and Strength of Evidence

We graded the strength of evidence for a collaborative consultation strategy used to promote the use of titration trials and periodic monitoring during medication management as insufficient for practitioner adherence, practitioner competency (cited obstacles to implementing EBPs), or ADHD symptoms. The evidence consisted of one cluster RCT with high study limitations and imprecise results due to small sample sizes. The strategy included audit and feedback and the use of a multidisciplinary team (Table F-11).

##### Paying Practitioners for Performance in Successfully Delivering an EBP

###### Study Description

One study^84^ studied a pay-for-performance (P4P) strategy (medium risk of bias) to improve treatment implementation for adolescent substance use disorders. This cluster randomized trial evaluated the use of a P4P initiative among 986 adolescent patients treated by 120 therapists working in 29 different community-based substance use disorder treatment organizations. Organizations were randomized to an implementation-as-usual (IAU) control condition or to a P4P experimental condition. Therapists across all organizations delivered the same evidence-based treatment using the Adolescent Community Reinforcement Approach (A-CRA), and each organization received standardized funding, training, and coaching from the treatment developers. Therapists in the P4P condition received $50 each month that they demonstrated competence in A-CRA treatment delivery and $200 for each patient who received a specified number of treatment procedures and sessions previously determined to be associated with improved patient outcomes. A therapist-level and patient-level propensity score were used to adjust for biases due to the cluster randomized design (i.e., therapists clustered within organizations and patients clustered within therapists). Adjusted intent-to-treat regression models were used to model two implementation outcomes: (1) number of therapists meeting A-CRA competence (using a Poisson distribution) and (2) whether each patient met target A-CRA (using a Bernoulli distribution) and one QI effectiveness outcome: patient-level remission status as defined in the Cannabis Youth Treatment Study at 6-month followup.^106^ The authors report event rate ratios (for the outcome, “number of therapists”) and ORs for the other two outcomes, as well as 95% CIs for differences between groups.

###### Intermediate Outcomes

Therapists assigned to the P4P condition had significantly higher likelihood of demonstrating A-CRA competence than the IAU therapists (Table 17). Patients working with therapists assigned to the P4P condition were more likely to get target levels of A-CRA treatment procedures and sessions (adherence and fidelity) than patients of therapists assigned to the IAU condition.

Table 17 Paying practitioners for performance in successfully delivering an EBP intervention: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Garner et al., 2012^84^ Cluster RCT/Medium | G1: Paying practitioners for performance (P4P) in successfully delivering an EBP intervention (A-CRA) G2: Implementation of an EBP intervention (A-CRA) as usual Single difference in financial provider component (provider incentives) across study arms (comparison group strategy contained no components) | G1: 14 organizations, 49 therapists G2: 15 organizations, 49 therapists | Demonstration of practitioner competent delivery of all components of at least 1 A-CRA treatment procedure during the same treatment session (A-CRA competence, number of events) | Event rate ratio=2.24, 95% CI, 1.12 to 4.48
Garner et al., 2012^84^ Cluster RCT/Medium | | G1: 14 organizations, 45 therapists, 429 patients G2: 15 organizations, 40 therapists, 507 patients | Demonstration of practitioner delivery of at least 10 of 12 specific A-CRA procedures within the first 14 weeks of treatment and in no fewer than 7 sessions for each patient (adherence to target A-CRA, yes/no) | OR, 5.19, 95% CI, 1.53 to 17.62
Garner et al., 2012^84^ Cluster RCT/Medium | | G1: 14 organizations, 41 therapists, 254 patients G2: 15 organizations, 40 therapists, 346 patients | Final health/patient-centered outcomes: Mental health symptoms, syndromes, or disorders as measured by patient remission at 6-month followup (yes/no) | OR, 0.68; 95% CI, 0.35 to 1.33

A-CRA = Adolescent Community Reinforcement Approach; CI = confidence interval; EBP = evidence-based practice; G = group; N = number; OR = odds ratio; P4P = pay for performance; RCT = randomized controlled trial.

###### Patient Health and Service Utilization Outcomes

The study found no significant difference in the likelihood of remission for adolescents working with therapists in the P4P conditions versus those working with therapists in the IAU condition over a 6-month time period (Table 17).

###### Risk of Bias Considerations

We rated the study as having medium risk of bias because of high rates of patient attrition (20% for the intermediate outcome of percentage of patients getting target levels of A-CRA treatment procedures and sessions and 49% for the patient health outcome of patient remission status).^84^ In addition, blinding of outcome assessors to the outcome status of participants was unclear.

###### Conclusion and Strength of Evidence

We graded the strength of evidence for a P4P strategy seeking to improve the implementation of an EBT to treat adolescents with substance use disorders as moderate. The evidence consisted of a single RCT with medium study limitations and precise results. The strategy comprised a provider incentive component. The study yielded moderate strength of evidence for benefit of P4P on one intermediate outcome (practitioner competence/skill) and low strength of evidence for benefit of P4P on another intermediate outcome (practitioner adherence/program fidelity). Finally, we graded the strength of evidence as low strength for no benefit of P4P on patient health and service utilization outcomes (change in mental health symptoms: remission) (Table F-12).

##### Program To Improve Organizational Culture and Climate

###### Study Description

Two studies with outcomes reported in three publications, conducted by the same group of authors, evaluated the Availability, Responsiveness and Continuity (ARC) program to improve organizational culture and climate. ARC’s ultimate goal is to increase implementation of EBPs^14,67^ by embedding principles of service system effectiveness within an organization; training clinicians to identify and address barriers to delivering effective services; and promoting a collaborative, supportive culture toward service innovation and improvement.^107^ Thus, ARC involves multiple activities—targeted at stakeholders, management, and service practitioners—that are all specifically designed to improve implementation by changing the social context of an organization to improve its ability to adopt effective treatments, strengthen adherence to protocols and strategies, develop therapeutic alliance between providers and patients, and sustain effective interventions.^108^ An ARC specialist works with others to plan and endorse implementation activities, communicate a vision for implementation efforts, set performance standards, facilitate information sharing, identify services barriers, and develop plans to remove service barriers. The strategy targets social, strategic, and technological factors via organizational and interorganizational components, the diffusion of innovation, and technology transfer.^109^

The initial study by this set of authors, published in 2010, used a 2×2 RCT design of an EBP intervention called MST and ARC, resulting in four arms: MST+ARC, MST only, ARC only, and usual care across 14 rural Appalachian counties. The strategy lasted for 12 months and evaluated youth behavior problems, youth placement, and therapist adherence.^14^ Outcomes were measured at 6 and 18 months following baseline. Comparisons to examine the effectiveness of the ARC strategy differed by outcome and are described, below. A second study of 26 community mental health programs for youth from a multisite mental health service system randomized the programs to ARC or usual care and sustained the strategy for 18 months to allow sufficient time to observe organizational change.^67,68^ The first publication from this trial focused on practitioner intermediate outcomes (satisfaction/acceptability).^67^ The second publication from this trial focused on youth outcomes as reported by the youth’s caregiver using the Shortform Assessment for Children, a standardized measure of youth psychosocial functioning (range 0–92).^68^ This study, however, dropped the 8 community health programs that treated young adults (ages 18 to 24) and instead included 18 of the original 26 community health programs that served youth ages 5 to 18. Outcomes were measured every month for 6 months following intake. The study notes that youth who entered care before the programs had completed the entire 18-month implementation of ARC experienced less improvement in the programs assigned to ARC than youth in the programs assigned to the control condition. The outcomes reported in the paper, therefore, were only for youth who started the program after the 18-month implementation of ARC had finished.

###### Intermediate Outcomes

For this review, we focus on comparisons made between the groups that received ARC (ARC and ARC+MST) vs. those that did not (MST only and usual care), as the authors do not present comparisons of intermediate outcomes between the individual study groups. The original study reported no differences (but did not provide details) on any measure of therapist fidelity to MST (therapist adherence as reported by caregiver, therapist rating of supervisor, audio-coded therapist adherence) for the groups receiving ARC versus those that did not receive ARC (Table 18).^14^

Table 18 Program to improve organizational culture and climate: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Glisson et al., 2010^14^ Two-stage RCT/Medium | G1: Program to improve organizational climate and culture with or without MST (ARC+MST and ARC only) G2: No ARC program to improve organizational climate and culture (MST only + usual care) 5 professional components (distribution of educational materials, educational meetings, educational outreach visits, audit and feedback, and one other—training and cognitive models to improve effectiveness) 1 organizational provider-oriented component (satisfaction of providers with conditions of their work) | G1: 291 G2: 305 | Caregiver rating of therapist adherence on the 28-item MST Therapist Adherence Measure—Revised (TAM-R) | No differences in caregiver-reported MST therapist adherence between ARC and non-ARC conditions, details NR
Glisson et al., 2010^14^ Two-stage RCT/Medium | | G1: 291 G2: 307 | Rating of therapist adherence based on audio coding of tapes from therapy sessions (TAM-R) | No differences in audio-coded ratings of therapist adherence between ARC and non-ARC conditions, details NR
Glisson et al., 2010^14^ Two-stage RCT/Medium | | G1: NR by arm G2: NR by arm N overall: 257 (91% of therapists) | Therapist rating of supervisor adherence based on SAM | No differences in SAM ratings of supervisor adherence between ARC and non-ARC conditions, details NR
Glisson et al., 2010^14^ Two-stage RCT/Medium | G1: Program to improve organizational climate and culture, ARC, only G2: Usual care All components (5 professional components—distribution of educational materials, educational meetings, educational outreach visits, audit and feedback, and one other—training and cognitive models to improve effectiveness, 1 organizational provider-oriented component—satisfaction of providers with conditions of their work (comparison group strategy contained no components) | G1: NR G2: NR | Hierarchical modeling coefficient of probability of entering an out-of-home placement in the 18-month followup period | Out-of-home placement lower for ARC group but not significantly so (β= −0.59, 95% CI=−1.17 to 0, p=0.05)
Glisson et al., 2010^14^ Two-stage RCT/Medium | | G1: NR G2: NR | Child Behavior Checklist Scores at 18 months | G1: 57.30 G2: 56.75 G3: 55.30 G4: 55.85 Differences reported as not significant.
Glisson et al., 2012^67^ Cluster RCT/Unclear | G1: Program to improve organizational climate and culture, ARC G2: Control All components (5 professional components—distribution of educational materials, educational meetings, educational outreach visits, audit and feedback, and one other—training and cognitive models to improve effectiveness and 1 organizational provider-oriented component—satisfaction of practitioners with conditions of their work) differed across study arms (comparison group strategy contained no components) | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Morale coefficient; 95% CI, p | G1 vs. G2: 4.761; 95% CI, 2.239 to 7.283; p=0.001
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Job satisfaction coefficient; 95% CI, p | G1 vs. G2: 2.338; 95% CI, 0.929 to 3.747; p=0.003
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Organizational commitment coefficient; 95% CI, p | G1 vs. G2: 2.322; 95% CI, 1.110 to 3.534; p=0.001
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Stress coefficient; 95% CI, p | G1 vs. G2: −1.095; 95% CI, −6.305 to 4.115; p=0.667
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Emotional exhaustion coefficient; 95% CI, p | G1 vs. G2: −0.085; 95% CI, −2.024 to 1.854; p=0.929
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Role conflict coefficient; 95% CI, p | G1 vs. G2: −1.555; 95% CI, −2.999 to −0.111; p=0.036
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Role overload coefficient; 95% CI, p | G1 vs. G2: 0.566; 95% CI, −1.420 to 2.552; p=0.561
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Engagement coefficient; 95% CI, p | G1 vs. G2: 1.591; 95% CI, 0.217 to 2.965; p=0.025
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Personalization coefficient; 95% CI, p | G1 vs. G2: 1.275; 95% CI, 0.298 to 2.252; p=0.013
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Personal accomplishment coefficient; 95% CI, p | G1 vs. G2: 0.398; 95% CI, −0.274 to 1.070; p=0.233
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Functionality coefficient; 95% CI, p | G1 vs. G2: 2.845; 95% CI, 0.356 to 5.334; p=0.027
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Growth and advancement coefficient; 95% CI, p | G1 vs. G2: 1.370; 95% CI, 0.170 to 2.570; p=0.027
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Role clarity coefficient; 95% CI, p | G1 vs. G2: 0.784; 95% CI, −0.292 to 1.860; p=0.145
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Cooperation coefficient; 95% CI, p | G1 vs. G2: 0.585; 95% CI, −0.259 to 1.429; p=0.166
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Rigidity coefficient; 95% CI, p | G1 vs. G2: −2.689; 95% CI, −4.684 to −0.694; p=0.011
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Centralization coefficient; 95% CI, p | G1 vs. G2: −1.874; 95% CI, −2.923 to −0.825; p=0.001
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Formalization coefficient; 95% CI, p | G1 vs. G2: −0.992; 95% CI, −2.103 to 0.119; p=0.077
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Proficiency coefficient; 95% CI, p | G1 vs. G2: 1.154; 95% CI, −0.903 to 3.211; p=0.258
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Responsiveness coefficient; 95% CI, p | G1 vs. G2: 0.305; 95% CI, −0.717 to 1.327; p=0.543
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Competency coefficient; 95% CI, p | G1 vs. G2: 0.720; 95% CI, −0.542 to 1.982; p=0.250
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Resistance coefficient; 95% CI, p | G1 vs. G2: −0.523; 95% CI, −3.194 to 2.148; p=0.689
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Apathy coefficient; 95% CI, p | G1 vs. G2: −1.105; 95% CI, −2.077 to −0.133; p=0.028
Glisson et al., 2012^67^ Cluster RCT/Unclear | | G1: 13 programs (N of clinicians by arm NR) G2: 13 programs (N of clinicians by arm NR) Total n of clinicians: 197 | Suppression coefficient; 95% CI, p | G1 vs. G2: 0.078; 95% CI, −1.536 to 1.692; p=0.921
Glisson et al., 2012^67^ Cluster RCT/Unclear | G1: Program to improve organizational climate and culture, ARC G2: Control All components (5 professional components—distribution of educational materials, educational meetings, educational outreach visits, audit and feedback, and one other—training and cognitive models to improve effectiveness and 1 organizational provider-oriented component—satisfaction of practitioners with conditions of their work) differed across study arms (comparison group strategy contained no components) | 1; 352 caregivers of youth ages 5–18 in 18 programs | Child Behavior Checklist Scores every month for 6 months (following 18 month implementation of ARC by organization) | Effect size=0.29

ARC = Availability, Responsiveness and Continuity; CI confidence interval; EBP = evidence-based practice; G = group; MST = multisystemic therapy; N = number; n = number; NR = not reported; p = p-value; RCT = randomized controlled trial; SAM = Supervisor Adherence Measure. TAM-R = Therapist Adherence Measure—Revised.

The second study evaluated the Organizational Social Context measure for 126 clinicians across 26 programs, with a primary domain for morale (including subdomains of job satisfaction and commitment); three domains for organizational climate, namely engagement (personalization of engagement and personal accomplishment), functionality (growth and advancement, clarity of role, cooperation), and stress (emotional exhaustion, role conflict, role overload); and three domains for organizational culture, namely rigidity (centralization, formalization), proficiency (responsiveness, competency), and resistance (apathy, suppression).^67^ Although all domains were in the expected direction (with the exception of suppression), the study reported statistically significant findings for morale, engagement, functionality, and rigidity only.^67^ The second publication from the second study focused on parent-reported youth problem behaviors at intake and at 1-month intervals for 6 months after intake^68^ and found that youth in the ARC arm had significantly fewer problem behaviors reported at followup than those assigned to the control condition.^68^

###### Patient Health and Service Utilization Outcomes

For the patient health and service utilization outcomes in the original study, differences between the ARC only and usual-care group were reported, but those from the ARC+MST group versus MST-only group were not. This study found that out-of-home placement was lower for youth ARC-only conditions when compared with usual care, but the significance failed to drop below the threshold (Table 19).^14^ The adjusted relative odds of a youth entering an out-of-home placement in a county that received the ARC intervention were lower than the odds of out-of-home placement in a county that did not participate in the ARC intervention, but the difference only approached significance (p=0.05). The study found that child behavior problems (measured by the Child Behavior Checklist Total Problem T Scores) at 6 months did not significantly differ between the ARC-only and usual-care groups. By the end of the 18-month followup, there were no significant differences in child behavior problems.

Table 19 Colocating an EBP program in primary care: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Wildman et al., 2012^94^ CCT/High | G1: Colocation of an EBP program (Triple P) in primary care G2: Enhanced referral to an EBP program (Triple P) Single difference in one organizational structural component (enhanced referrals and choice of treatment) across study arms (comparison group strategy contained no components) | G1: 11,213 G2: 9,704 | Proportion attending first scheduled Triple P appointment | G1: 43/11,213 G2: 12/9,704 OR, 3.10; 95% CI, 1.63 to 5.89
Wildman et al., 2012^94^ CCT/High | | G1: 43 G2: 12 | Mean number of sessions attended (SD) | G1: 3.07 (2.42) G2: 4.08 (2.71) Calculated mean difference: −1.01; 95% CI, −2.60 to 0.58; p>0.2

CCT = controlled clinical trial; CI = confidence interval; EBP = evidence-based practice; G = group; N = number; OR = odds ratio; p = p-value; SD = standard deviation; Triple P = Positive Parenting Program.

The second publication from the second study focused on parent-reported youth problem behaviors at intake and at 1-month intervals for 6 months after intake^68^ and found that youth in the ARC arm had significantly fewer problem behaviors reported at followup than those assigned to the control condition (effect size=0.29).^68^

###### Risk of Bias Considerations

The original study^14^ had a rate of attrition over 20 percent. It also did not offer information on fidelity and outcome assessor blinding and had the potential for recall bias for out-of-home placement. As a result, we rated the study as having medium risk of bias. The followup study replaced 2 of 26 sites that were found ineligible. They did not report key details such as differences in baseline characteristics and controls for the potential differences from replacement, so it was not possible to judge the effect of this alteration on the outcomes.^67^ As a result, we rated the followup study as having unclear risk of bias.

###### Conclusion and Strength of Evidence

Two RCTs reported in three publications tested the ARC program to improve organizational culture and climate. The strategy included educational meetings, educational materials, educational outreach visits, provider satisfaction, and audit and feedback (professional components) and one organizational provider components, improving the satisfaction of providers with their work. We graded the evidence from these studies as low for no benefit for some outcomes and low for benefit for others (medium study limitations, precise results). Only one study, however, provided evidence on each outcome category (Table F-13). One study yielded low strength of evidence that ARC does not improve practitioner adherence to MST. A second yielded low strength of evidence that ARC improves some measures of practitioner satisfaction/acceptability. One study yielded low strength of evidence for no benefit that ARC reduces the rate of out-of-home placement or reduces mean child problem behavior scores when compared with usual care. One study offered low strength of evidence that ARC improves child behavior as compared with usual care in the first 6 months of followup (after the organizations had completed the 18-month implementation of ARC).

##### Colocating an EBP Program in Primary Care Study Description

A single CCT^94^ of high risk of bias evaluated the effect of colocating behavioral health care in primary care, specifically the Positive Parenting Program (Triple P), which has been shown to be effective in clinical trials. The study assigned four community-based, hospital-affiliated primary care pediatric practices in northeastern Ohio to colocated behavioral parent training, provided at the primary care office (the active arm) or enhanced referral to behavioral parent training delivered in settings outside the primary care office (the control arm). Additionally, the study considered the inclusion of a usual-care arm, from seven community-based, hospital-affiliated primary care pediatric practices where patients could be referred to the behavioral parenting program routinely offered at the hospital. Only one family in the usual-care arm sought a referral, so the study authors did not include the usual care arm in the final analyses. Parents in the colocation strategy arm were more likely to be younger and unemployed than parents in the control (enhanced referral) arm. Parental mean age was 31.8 (30.7 in the strategy arm and 34.8 in the control arm). Thirteen parents (59.1%) in the colocated arm and 1 parent (11.1%) in the enhanced-referral condition were unemployed.

Outcomes of interest included rate of attendance of first Triple P appointments by parents, number of sessions attended, parental ratings of child externalizing behavior using the Eyberg Child Behavior Inventory, parent self-rated positive and negative affect as rated by the Positive and Negative Affect Schedule, and self-rated dysfunctional parenting as rated by the Parenting Scale.

###### Intermediate Outcomes

The study evaluated one intermediate outcome: patient access to care. The study found that parents in the strategy arm were more likely to attend their first scheduled Triple P appointment than in the enhanced referral condition (Table 19). The study did not control or adjust for baseline differences in study arms.

###### Patient Health and Service Utilization Outcomes

The study evaluated one patient outcome: health care utilization. Parents in the colocated arm attended fewer Triple P sessions, on average, than the control arm, although the CI around the mean difference is wide and the difference is not statistically significant.

###### Risk of Bias Considerations

We rated this study as having high risk of bias. The authors did not adjust the study results for baseline differences (colocation parents were older and unemployed compared with the control group parents), and between-practice differences in culture were not considered. Little information was given regarding how the practitioners explained the program to patients and whether there other patient, primary care practitioner, or practice attributes differed between groups. Whether all clinics were randomized to a condition, whether outcome assessors were blinded to condition, and levels of attrition also were unclear.

###### Conclusion and Strength of Evidence

A single publication presented data from a strategy on colocating behavioral health care in primary care settings. The strategy involved changing the scope of benefits. We graded the strength of evidence as insufficient for healthcare utilization and low strength of evidence. Other analyses yielded low strength of evidence for patient access to care (Table F-14).

##### Embedding a Behavioral Health Care Practitioner in Primary Care

###### Study Description

A single nonblinded cluster randomized, hybrid implementation and effectiveness trial^92^ with medium risk of bias compared implementation of an EBT between two groups. The EBT, Screening, Brief Intervention, and Referral to Treatment (SBIRT), is an early intervention for substance use. The study compared outcomes for adolescent patients receiving SBIRT from their trained pediatricians with outcomes for adolescents receiving SBIRT from a behavioral health care practitioner (BHCP) working in coordination with their pediatricians. The study also included a usual-care group of pediatricians who did not receive SBIRT training. We do not report on comparisons of the active treatment with usual-care arms because the effects of SBIRT cannot be separated from the effects of the implementation in this study.

Fifty-two pediatricians from a large general pediatrics clinic in an integrated health care system were randomized to one of three SBIRT implementation arms. Patients of these pediatricians, ages 12 to 18 years, were eligible for the study. Each adolescent completed the screening tool, the Teen Well Check Questionnaire, at registration for their well-child visit. The completed forms were stored in their electronic health record (EHR) for review by their pediatricians. Positive screens on the Teen Well Check Questionnaire, as indicated by past-year indication of alcohol, marijuana, or other drug use and/or mood symptoms or suicidality, triggered additional assessment, brief intervention, and referral via the SBIRT protocol that were done during the current visit. In the pediatrician-only group, the pediatrician conducted the assessment, brief intervention, and referrals. In the BHCP group, pediatricians called the BHCP upon encountering a patient who endorsed substance use or mental health risk during screening. The BHCP was invited to come into the examination room to meet with the patient and conduct the assessment, brief intervention, and referral if available, or spoke with the patient to set up a time to conduct the additional SBIRT protocols.

In the two SBIRT groups, investigators trained pediatricians and BHCPs to provide brief interventions that consisted of feedback, advice, and goal setting. If indicated, referrals were made, by the pediatrician or BHCP who completed the SBIRT protocol, to additional substance use or mental health departments within the integrated health care system.

The three outcomes of interest were assessment, brief intervention, and referrals, compared via multivariable logistic regression models adjusted for clustering of patients within pediatricians and patient characteristics (age, sex, and ethnicity).

###### Intermediate Outcomes

Three outcomes of practitioner adherence/program model fidelity were compared across study arms. The study found no differences in the proportion of patients being assessed for substance use between the pediatrician-only and the BHCP groups (Table 20). The BHCP group patients, however, were more likely to receive a brief intervention than the pediatrician-only group patients but less likely than the pediatrician-only group patients to be referred for treatment.

Table 20 Embedding a BHCP in primary care: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Sterling et al., 2015^92^ RCT/Medium | G1: Implementation of an EBP by a pediatrician G2: Implementation of an EBP by an embedded BHCP Single difference in one organizational provider component (use of clinical multidisciplinary teams) across study arms | G1: 584 (14 pediatricians) G2: 671 (16 pediatricians with embedded BHCPs) | Assessment (proportion) | G1: 149/584 (25.5%) G2: 164/671 (24.3%) aOR, 0.93; 95% CI, 0.72 to 1.21
Sterling et al., 2015^92^ RCT/Medium | | G1: 584 (14 pediatricians) G2: 671 (16 pediatricians with embedded BHCPs) | Brief intervention (proportion) | G1: 96/584 (16.4%) G2: 171/671 (25.5%) aOR, 1.74; 95% CI, 1.31 to 2.31
Sterling et al., 2015^92^ RCT/Medium | | G1: 584 (14 pediatricians) G2: 671 (16 pediatricians with embedded BHCPs) | Referral to treatment (proportion) | Proportions for each group not reported aOR, 0.58; 95% CI, 0.43 to 0.78

aOR = adjusted odds ratio; BHCP: behavioral health care provider; CI = confidence interval; EBP = evidence-based practice; G = group; N = number; RCT = randomized controlled trial.

###### Patient Health and Service Utilization Outcomes

The study did not report any patient health and service utilization outcomes but did cite two prior organizations (the National Institute on Alcohol Abuse and Alcoholism and the World Health Organization) that endorse SBIRT provided in primary care as an EBT to reducing substance use among adults.^110,111^

###### Risk of Bias Considerations

We rated this study as having medium risk of bias. The study randomized pediatricians to groups, but the randomization was not blinded. Baseline characteristics of the pediatrician-only patients did not significantly differ from those of the pediatricians with embedded BHCP patients. The outcome assessors also were not blinded. BHCPs in the embedded group were slightly more likely than pediatricians in the pediatrician-only group to attend at least two sessions of SBIRT training (76.5% vs. 47.1%, calculated p=0.08).

###### Conclusion and Strength of Evidence

We graded the strength of evidence on a strategy using embedded BHCPs working with pediatricians to implement an EBT as low for no benefit. The evidence consisted of a single RCT with medium study limitations. We were unable to assess precision. The strategy included a multidisciplinary team component. This nonblinded, cluster randomized trial yielded low strength of evidence that the strategy improves practitioner adherence to brief substance use intervention and lowers referrals to treatment as compared with pediatrician-only implementation groups (Table F-15).

## Finding Recipes for Success

We turned to qualitative comparative analysis (QCA) to understand what combinations of components might serve as recipes for success.

### Inputs

Appendix H illustrates inputs for each condition set and each outcome used in the QCA for each study.

### Models

We examined six models (three different combinations of condition sets with two different outcomes) and chose the model that demonstrated a set relationship with the highest level of consistency and coverage. (The other models did not have a strong set relationship and are not shown.) Our model included the presence or absence of one or more professional components, financial components, organizational provider components, and/or organizational structural components as related to having a significant improvement in a majority of practitioner-, system-, and patient-level intermediate outcomes (i.e., the super outcome).

### Solutions

Our analysis included 17 studies; 12 showed significant improvements (i.e., significant improvement in majority of practitioner, system, or patient intermediate outcomes or at least one patient health or service utilization outcome showing at least low strength of evidence for benefit coded as 1). Five did not.

In the Boolean analysis of the truth table, no conditions were individually necessary; and no necessary combinations occurred. Having a finance component or having a component that included changing the scope or nature of benefits or services and patient choice of treatment were individually sufficient; however, each of these sufficient conditions represent a single study and should not be over-interpreted as a definitive pathway to success.

Analysis of sufficient combinations for achieving significant improvements showed five additional configural solutions, each with 100% consistency. Taken together, the solutions had 83% coverage, accounting for 10 of the 12 studies that demonstrated at least low strength of evidence of benefit for at least one outcome. These solutions were:

- Using clinical multidisciplinary teams and not having an audit and feedback component
- Having educational materials or meetings, patient-mediated interventions, and educational outreach; or
- Having educational materials or meetings, patient-mediated interventions, and reminders; or
- Having educational materials or meetings, educational outreach, and reminders; or
- Having an audit and feedback component and not having educational outreach and not using a clinical multidisciplinary team.

Table 21 displays the solutions, their individual consistency and coverage values, and the total solution consistency and coverage. The QCA yielded seven solutions associated with success, described below and shown in the Venn diagram in Figure 4. Four of the solutions included only one study each. Two solutions included two studies each. And one solution included three studies. Two of the studies that showed benefit did not belong to any of the solutions yielded by the QCA. Of note, one study met criteria for two different solutions associated with success.

Table 21 Sufficient combinations for achieving implementation effectiveness

Sufficient Combination | | Raw Coverage | Unique Coverage | Consistency | Studies included in Combination
1. | Having a financial component | 0.083 | 0.083 | 1.000 | Garner et al., 2012^84^
2. | Changing the scope of patient benefits component | 0.083 | 0.083 | 1.000 | Wildman et al., 2012^112^
3. | Having a clinical multidisciplinary team components with NOT having an audit and feedback component | 0.083 | 0.083 | 1.000 | Sterling et al., 2015^92^
4. | Having an educational materials or meetings component and a patient-mediated intervention component and an educational outreach component | 0.167 | 0.167 | 1.000 | Gully et al., 2008^66^ Study 1 and Study 2;
5. | Having an educational materials or meetings component and a patient-mediated intervention component and a reminders component | 0.167 | 0.083 | 1.000 | Carroll et al,, 2013^89^ Epstein et al., 2011^85^
6. | Having an educational materials or meetings component and an educational outreach component and a reminders component | 0.083 | 0.083 | 1.000 | Ronsley et al., 2012^95^
7. | Having an audit and feedback component with NOT having an educational outreach component and NOT having a clinical multidisciplinary team component | 0.250 | 0.167 | 1.000 | Bickman et al., 2011^13^; Lockman et al., 2009^88^ G1 vs. G3; Epstein et al., 2011^85^
Total solution consistency=1.000
Total solution coverage=0.8333

Figure 4 Venn diagram of QCA findings

QCA = Qualitative Comparative Analysis

Figure 4 is titled “Venn Diagram of QCA Findings”. This figure is described in the Section entitled “Solutions” as follows: “Figure 4 (VENN DIAGRAM OF QCA FINDINGS) depicts the solutions in a Venn diagram. All seven solutions had perfect consistency; however, these solutions accounted for only 10 of the 12 cases that demonstrated improvements in a majority practitioner, system, or patient intermediate outcomes (i.e., .833 total coverage). The first solution included financial components (N=1); solution 2 included changing the scope of benefits (N=1). Solution 3 included a multidisciplinary team but no audit and feedback. Solution 3 included educational materials or meetings and patient-mediated interventions and educational outreach (N=2). Solution 5 included educational materials or meetings and patient-mediated interventions and reminders (N=2). Solution 6 included educational materials or meetings and educational outreach and reminders (N=1). Solution 7 included audit and feedback and no educational outreach visit and no multidisciplinary team (N=3).

All seven solutions had perfect consistency and accounted for 10 of the 12 cases that demonstrated improvements in practitioner, system, or patient outcomes or found low strength of evidence for benefit for at least one patient health or service utilization outcomes (i.e., 0.833 total coverage). The last solution accounted for the most (N=3) studies that achieved improvements; Solutions 1, 2, 3, and 6 accounted for 1 study each. Solutions 4 and 5 each accounted for 2 studies each. These solutions could not account for 2 studies that showed improvements: Glisson et al., 2012^67^ and Lester et al., 2009.^90^ The latter study had an educational materials or meetings component and an educational outreach component only with no patient-mediated intervention, audit and feedback, reminders, financial, having a clinical multidisciplinary team, or changing the scope of patient benefits components. This combination of components is similar to three of the solutions that accounted for 5 studies that showed benefit incorporated the presence of three (instead of just two) different professional components each (educational materials or meetings plus educational outreach plus reminders OR educational materials or meetings plus patient-mediated interventions plus reminders OR educational materials or meetings plus patient-mediated interventions plus educational outreach), but not the other components. The two Glisson studies had the same combination of components and one study showed benefit (2012) while the other did not (2010). We are unable to determine why only one showed benefit.

## Key Question 2 Harms

A single study, focused on general professional training to identify and refer first-episode cases of psychosis, reported harms.^90^

### Key Points

- Only one study reported on the harms of strategies to improve mental health in children and adolescents.
- The study did not find any harms associated with a strategy to train general practitioners to improve identification of first-episode cases of psychosis.

### Detailed Study Description

A single study that examined harms associated with a strategy to improve the mental health care of children and adolescents met our inclusion/exclusion criteria. The study,^90^ described previously, was classified as a professional training strategy. This study found no harms associated with a practitioner education strategy to improve the rates of referral to early intervention services for first-episode psychosis experienced by young people ages 14 to 30 (Table 22). The investigators found no differences between strategy and control practices with respect to patients who reported adverse events (n=0 in both groups, details of specific adverse events measured not reported) and no increase in false-positive referrals from primary care to early-intervention services before and during the study. The authors report that the rate of false-positive referrals within practices “remained between 12.7 percent and 13.4 percent before and during the study” (p. e188); however, differences between groups were not reported.

Table 22 Harms associated with training practitioners to identify and refer cases: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Lester et al., 2009^90^ Stratified cluster RCT/High | G1: Professional training to identify and refer first-episode cases of psychosis G2: Usual care All professional components (educational meetings, local consensus process, educational outreach visits, marketing) differed across arms (comparison group strategy contained no components) | G1: 55 practices (97 patients) G2: 55 practices (82 patients) | Adverse events within 4 months | 0 reported in both groups
Lester et al., 2009^90^ Stratified cluster RCT/High | | G1: 55 practices (97 patients) G2: 55 practices (82 patients) | False-positive referrals from primary care | NR other than that there was no increase, remaining between 12.7% and 13.4% before and during the study

G = group; N = number; NR= not reported; RCT = randomized controlled trial.

### Conclusion and Strength of Evidence

A single publication with high risk of bias presented data from a practitioner education strategy and yielded insufficient evidence for patient harms (i.e., side effects including adverse events and false-positive referral rates) (Table F-16).

## Key Question 3 Moderators

Four studies examined moderators of the effectiveness of strategies on outcomes. Three of these studies examined treatment intensity as a moderator of the effectiveness of professional training of school counselors to prevent children at high risk for aggressive behaviors from developing externalizing problems,^88^ a financial or organizational change of adding weekly feedback to therapists providing home-based mental health care for children and adolescents,^13^ and a financial or organizational change of a collaborative consultative model to improve the use of titration trials and medication monitoring during medication maintenance for children with ADHD.^86^ The other study examined whether fidelity to protocol improved the effectiveness of a P4P strategy to improve treatment implementation of an EBP for adolescent substance use disorders.^84^

### Key Points

- The strength of evidence of the three studies that examined treatment intensity as a moderator varied from having grades of low for benefit (for the association between prevention of externalizing behaviors and patient mental health symptom improvement) to insufficient (for the other two studies that examined treatment intensity as a moderator of the effectiveness of a weekly feedback strategy to improve home-based mental health care and of a collaborative consultative strategy to improve the use of EBPs) due to myriad study limitations and inability to determine the precision of findings.
- The strength of evidence was graded as low for no benefit for the moderating effect of fidelity to the protocol on effectiveness of a P4P strategy to improve treatment implementation of an EBP for adolescent substance use disorders.

### Detailed Study Description

#### Moderating Effects of Intervention Effects—Intensity of the Intervention

##### Study Description

Three studies addressed the moderating effects of higher intensity of the strategy on outcomes. One study^88^ of unclear risk of bias examined the effectiveness of professional training of school counselors to use the CP program with third-grade children at high risk for aggressive behaviors as they transitioned to middle school. Counselors were randomly assigned to one of three conditions: CP-TF, CP-BT, or comparison; thus, the two strategy groups differed with respect to training intensity. CP-TF was more intense and included four components, while CP-BT included two training components. The findings indicated that the CP-TF group had greater decreases in externalizing behavioral problems as rated by teachers than the comparison group (mean difference=G1 vs. G3: OR, 0.66; 95% CI, 0.41 to 0.91), greater decreases in child-rated minor assaults than the comparison group (G1 vs. G3: OR, 0.78; 95% CI, 0.62 to 0.99), and greater improvements in teacher-rated social/academic competence than the comparison group (G1 vs. G3: OR, 1.42; 95% CI, 1.10 to 1.83). None of the outcomes significantly differed for the CP-BT and comparison groups. The authors then compared the outcomes for the CP-TF and CP-BT groups to determine whether improvements in outcomes differed by training intensity. The authors also compared the two strategy groups on provider protocol adherence/program fidelity and patient access to care and treatment engagement intermediate outcomes.

A second study,^13^ categorized as targeting a financial or organizational change, evaluated the addition of weekly feedback to therapists (the CFS) in addition to standard 90-day feedback on symptoms and functional status change of children receiving home-based mental health treatment. Regarding intermediate outcomes, the investigators reported implementation failure in one arm. Regarding patient health and service utilization outcomes, the study reported a higher rate of change in improvement in SFSS in the experimental group (effect sizes of 0.18, 0.24, and 0.27 for youths, clinicians, and caregivers, respectively), calculated by study authors using the HLM-estimated coefficients measured at the average length of stay in the CFS. The authors sought to understand the dose-response effect of the strategy, specifically whether there was an association between the proportion of reports viewed and outcomes (symptoms and functional status).

A third study,^86^ also categorized as targeting a financial or organizational change, examined the use of a collaborative consultative model to improve the use of titration trials and medication monitoring during medication maintenance for children with ADHD. The study found a higher rate of practitioner uptake of titration trials in the strategy arm and no effect (or no consistent effect) of the strategy on uptake of medication monitoring during the maintenance phase of the drug, practitioner competency (measured by cited obstacles to implementing EBPs), or ADHD symptoms. The study then sought to understand the effect of undertaking a titration trial on ADHD symptoms.

##### Intermediate Outcomes

The study on varying training intensity for school counselors^88^ compared the CP-TF and CP-BT groups on practitioner protocol adherence, program model fidelity, patient access to care, and treatment engagement intermediate outcomes (Table 23). The authors reported no significant differences in rates of child sessions scheduled; however, calculated mean differences indicated that the CP-TF group had fewer sessions scheduled for children and for parents than the CP-BT. There were no significant differences between groups with respect to child and parent attendance and parent treatment engagement. For children, however, treatment engagement was significantly better for the CP-TF group than for the CP-BT group. Practitioners in the CP-TF group also had a greater number of contacts with trainers than those in the CP-BT group.

Table 23 Intensity of the strategy as a moderator of the effectiveness of the strategy: Summary of results (intermediate outcomes)

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Lochman et al., 2009^88^ | G1: Professional training plus feedback to implement an EBP intervention (CP-TF) G2: Professional training only to implement an EBP intervention (CP-BT) G3: Control Difference across the three study arms varied: two strategy arms and one control arm—training plus feedback arm—had all five components, training-only arm had educational meetings and marketing components, and control arm had none of these components) | G1: 168 G2: 183 G3: 180 | Calculated mean difference (and 95% CI) in rates of child sessions and parent sessions scheduled (G1–G2) | −3.10 (−3.60 to −2.60) child −0.50 (−0.24 to −0.77) parent
Lochman et al., 2009^88^ | | G1: 168 G2: 183 G3: 180 | Calculated mean difference (and 95% CI) in rates of attendance for child and parent sessions (G1–G2) | 0.01 (−0.08 to 0.11) child −0.04 (−0.12 to 0.05) parent
Lochman et al., 2009^88^ | | G1: 168 G2: 183 G3: 180 | Calculated mean difference (and 95% CI) in number of strategy objectives completed for child and parent sessions (G1–G2) | 0 (−0.21 to 0.21) child 0 (−0.21 to 0.21) parent
Lochman et al., 2009^88^ | | G1: 168 G2: 183 G3: 180 | Calculated mean difference (and 95% CI) in number of contacts of practitioners with trainers (G1–G2) | 18.1 (17.51 to 18.69) practitioner
Lochman et al., 2009^88^ | | G1: 168 G2: 183 G3: 180 | Calculated mean difference (and 95% CI) in ratings of counselors’ engagement with children and with parents (G1–G2) | 0.30 (0.28 to 0.32) children −0.10 (−0.12 to −0.08) parent

CI = confidence interval; CP-BT = Coping Power-Basic Training; CP-TF = Coping Power-Training plus Feedback; G = group; N = number.

##### Patient Health and Service Utilization Outcomes

The study on training intensity for school counselors demonstrated that the more intense strategy, the CP-TF group, had better rated outcomes than the less intense strategy, the CF-BT group, for teacher-rated externalizing behaviors over time, child self-reported assaultive behaviors, and child-rated expectations of the utility of aggression (Table 24).^88^

Table 24 Intensity of the strategy as a moderator of the effectiveness of the strategy: Summary of results (patient health and service utilization outcomes)

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Lochman et al., 2009^88^ | G1: Professional training plus feedback to implement an EBP intervention (CP-TF) G2: Professional training only to implement an EBP intervention (CP-BT) G3: Control Difference across the three study arms varied: two strategy arms and one control arm—training plus feedback arm had all five components, training only arm had educational meetings and marketing components, and control arm had none of these components) | G1: 168 G2: 183 G3: 180 | Mean change in teacher-rated externalizing behaviors over time | CP-TF=0, CP-BT=5, χ^2^2(1)=3.87, p=0.05
Lochman et al., 2009^88^ | | G1: 168 G2: 183 G3: 180
Lochman et al., 2009^88^ | | G1: 168 G2: 183 G3: 180 | Mean change in child self-reported assaultive behaviors | CP-TF=0.18, CP-BT=0.45, χ^2^ (1)=6.23, p=0.01
Lochman et al., 2009^88^ | | G1: 168 G2: 183 G3: 180
Lochman et al., 2009^88^ | | G1: 168 G2: 183 G3: 180 | Mean change for child-rated expectations of the utility of aggression | CP-TF=−0.1, CP-BT=0.1, χ^2^ (1)=5.64, p=0.02
Bickman et al., 2011^13^ RCT/High RoB | G1: Weekly and cumulative 90-day feedback on patient symptoms and functioning to practitioners G2: Cumulative 90-day feedback on patient symptoms and functioning to practitioners only Single difference across arms: frequency of quality monitoring mechanism (weekly feedback to providers and cumulative 90-day feedback vs. 90-day feedback only) (comparison group strategy contained no components) | G1: 13 sites, 167 youths, 169 caregivers, 64 clinicians G2: 15 sites, 173 youths, 214 caregivers, 80 clinicians Total scales analyzed (breakdown by trial arm NR): youth, N=1,341; clinicians, N=1,291; caregivers, N=935 | Youth
Bickman et al., 2011^13^ RCT/High RoB | | | Estimated coefficient of membership in feedback group at baseline | 0.02, SE: 0.10, p>.005
Bickman et al., 2011^13^ RCT/High RoB | | | Estimated coefficient of slope (time in weeks) | −0.001, SE: 0.002, p<.0001
Bickman et al., 2011^13^ RCT/High RoB | | | Estimated coefficient of interaction of membership in feedback group and slope | −0.01, SE: 0.002, p<.001
Epstein et al., 2007^86^ | G1a: Patients whose physicians did conduct a titration trial as part of a collaborative consultative treatment service to promote the use of titration trials and periodic monitoring during medication management program G1b: Patients whose physicians did not conduct a titration trial as part of a collaborative consultative treatment service to promote the use of titration trials and periodic monitoring during medication management program | G1 (patients): 29 G1b (patients): 30 G2 (patients): 87 | Mean scores for combined parent and teacher ratings of ADHD symptoms NR F score for strategy effect on combined parent and teacher ADHD ratings in subgroup of children who received a titration trial in G1 (compliers) | F4,124=3.80, p<0.01
Epstein et al., 2007^86^
Epstein et al., 2007^86^ | G2: Control All (both) components differed across arms (comparison group included neither of these components) | | Reduction in DSM-IV symptomatology | G1a vs. G2: t114=−2.72, p=0.008, effect size=0.25 G1b vs. G2: t57= −3.568, p=0.001, effect size=0.47

ADHD = attention deficit hyperactivity disorder; CP-BT = Coping Power-Basic Training; CP-TF = Coping Power-Training plus Feedback; Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition (DSM-IV); G = group; N = number; NR = not reported; p = p-value; RCT = randomized controlled trial; RoB = risk of bias; SE = standard error.

The study on frequency of feedback to therapists found that effect sizes for symptoms and functional status increased by 50 percent for youth ratings of their own status, to 0.27, and by 66 percent for clinician reports, to 0.40 (p<0.001). The effect size did not increase for caregiver reports of adolescent functioning status.^13^

The study on using titration trials within a study of a collaborative consultative model found that patients whose physicians conducted a titration trial had lower combined parent and teacher ratings of ADHD symptoms but did not have an effect on DSM-IV rated symptomatology.^86^

##### Conclusion and Strength of Evidence

We graded evidence from a single publication that presented data from a cluster RCT as having low strength of evidence for benefit that more intense treatment improved patient access to care and low strength of evidence for no benefit that more intensive treatment improved patient treatment engagement and practitioner protocol adherence/program fidelity in a strategy testing professional training plus feedback (to implement an EBP intervention) versus professional training only (to implement an EBP intervention) versus control (Table F-17). We also graded the strength of evidence as low for benefit that greater training intensity was associated with greater improvements in mental health symptoms (Table F-18). We graded the evidence from the other two publications that examined the moderating effect of training intensity as yielding insufficient strength of evidence for mental health symptoms and functional status.

#### Moderating Effects of Process Characteristics—Fidelity to EBP

##### Study Description

One study^84^ (medium risk of bias) studied a P4P strategy to improve treatment implementation of an EBP for adolescent substance use disorders by comparing a P4P condition to an IAU control condition. The EBP implemented to be used by all therapists was the A-CRA; each organization received standardized funding, training, and coaching from the treatment developers. After finding a significant association between target A-CRA and remission status, the interaction between condition assignment and target A-CRA was examined with respect to patient remission status.

##### Patient Health and Service Utilization Outcomes

Fidelity to the EBP (i.e., meeting target A-CRA) did not significantly moderate the association between treatment group and patient remission status (Table 25).

Table 25 Intensity of the strategy as a moderator of the effectiveness of the strategy: Summary of results

Study Design/Risk of Bias | Study Arms Differences in Strategy Components Across Study Arms | N Analyzed | Outcome Reported by Study and Time Period | Results
Garner et al., 2012^84^ RCT/RoB | G1: Paying practitioners for performance (P4P) for successfully delivering of an EBP intervention (A-CRA) G2: Implementation of an EBP intervention (A–CRA) as usual | G1: 14 organizations, 49 therapists G2: 15 organizations, 49 therapists | Patient health and service utilization outcomes: Mental health symptoms, syndromes, or disorders as measured by patient remission at 6-month followup | Fidelity did not moderate the association between treatment group and patient remission status (no effect sizes reported, p=0.37)

A-CRA = Adolescent Community Reinforcement Approach; EBP = evidence-based practice; G = group; N = number; RCT = randomized controlled trial; RoB = risk of bias; p = p-value; P4P = pay for performance.

##### Conclusion and Strength of Evidence

A single publication presented data from an RCT examining financial incentives provided to the practitioner for successful implementation of an EBT to treat adolescents with substance use disorders. We rated this study as having medium risk of bias. We graded the strength of evidence as low for no benefit: fidelity to the EBP did not moderate the effect of the strategy on patient remission (Table F-19).