# References

1 (2009). O’Connell ME, Boat T, Warner KE, editors. Preventing Mental, Emotional, and Behavioral Disorders Among Young People: Progress and Possibilities.
2 Perou R, Bitsko RH, Blumberg SJ, et al. (2013). Mental health surveillance among children--United States, 2005–2011. MMWR Surveill Summ.
3 Weisz JR, Weiss B, Han SS, et al. (1995). Effects of psychotherapy with children and adolescents revisited: a meta-analysis of treatment outcome studies. Psychol Bull.
4 Dishion TJ, McCord J, Poulin F. (1999). When interventions harm. Peer groups and problem behavior. Am Psychol.
5 Silverman WK, Hinshaw SP. (2008). The second special issue on evidence-based psychosocial treatments for children and adolescents: a 10-year update. J Clin Child Adolesc Psychol.
6 Chorpita BF, Daleiden EL, Ebesutani C, et al. (2011). Evidence-based treatments for children and adolescents: an updated review of indicators of efficacy and effectiveness. Clin Psychol-Sci Pr.
7 Hoagwood K, Burns BJ, Kiser L, et al. (2001). Evidence-based practice in child and adolescent mental health services. Psychiatr Serv.
8 Jensen PS, Goldman E, Offord D, et al. (2011). Overlooked and underserved: “action signs” for identifying children with unmet mental health needs. Pediatrics.
9 Kataoka SH, Zhang L, Wells KB. (2002). Unmet need for mental health care among U.S. children: variation by ethnicity and insurance status. Am J Psychiatry.
10 Saloner B, Carson N, Cook BL. (2014). Episodes of mental health treatment among a nationally representative sample of children and adolescents. Med Care Res Rev.
11 Satcher D. (2008). Report of the Surgeon General’s Conference on Children’s Mental Health: A National Action Agenda.
12 Williams J, Klinepeter K, Palmes G, et al. (2004). Diagnosis and treatment of behavioral health disorders in pediatric practice. Pediatrics.
13 Bickman L, Kelley SD, Breda C, et al. (2011). Effects of routine feedback to clinicians on mental health outcomes of youths: results of a randomized trial. Psychiatr Serv.
14 Glisson C, Schoenwald SK, Hemmelgarn A, et al. (2010). Randomized trial of MST and ARC in a two-level evidence-based treatment implementation strategy. J Consult Clin Psychol.
15 Balas EA, Boron SA. (2000). Managing clinical knowledege for healthcare improvements.
16 Shojania KG, McDonald KM, Wachter RM, et al. (2004). Closing the Quality Gap: A Critical Analysis of Quality Improvement Strategies, Vol. 1: Series Overview and Methodology. Technical Review.
17 Institute of Medicine. (2001). Crossing the Quality Chasm Crossing the Quality Chasm: A New Health System for the 21st Century.
18 McPheeters ML, Kripalani S, Peterson NB, et al. (2012). Quality Improvement Interventions To Address Health Disparities. Closing the Quality Gap: Revisiting the State of the Science.
19 Dorsey S, Pullmann MD, Deblinger E, et al. (2013). Improving practice in community-based settings: a randomized trial of supervision - study protocol. Implement Sci.
20 Schoenwald SK, Sheidow AJ, Letourneau EJ. (2004). Toward effective quality assurance in evidence-based practice: links between expert consultation, therapist fidelity, and child outcomes. J Clin Child Adolesc Psychol.
21 McKibbon KA, Lokker C, Wilczynski NL, et al. (2010). A cross-sectional study of the number and frequency of terms used to refer to knowledge translation in a body of health literature in 2006: a Tower of Babel?. Implement Sci.
22 McCormack L, Sheridan S, Lewis M, et al. (2013). Communication and Dissemination Strategies to Facilitate the Use of Health-Related Evidence.
23 Rabin BA, Brownson RC, Haire-Joshu D, et al. (2008). A glossary for dissemination and implementation research in health. J Public Health Manag Pract.
24 Brownson RC, Colditz GA, Proctor EK. (2012). Dissemination and Implementation Research in Health.
25 Lomas J. (1993). Diffusion, dissemination, and implementation: who should do what?. Ann N Y Acad Sci.
26 Proctor EK, Landsverk J, Aarons G, et al. (2009). Implementation research in mental health services: an emerging science with conceptual, methodological, and training challenges. Adm Policy Ment Health.
27 Aarons GA, Glisson C, Green PD, et al. (2012). The organizational social context of mental health services and clinician attitudes toward evidence-based practice: a United States national study. Implement Sci.
28 Aarons GA. (2004). Mental health provider attitudes toward adoption of evidence-based practice: the Evidence-Based Practice Attitude Scale (EBPAS). Ment Health Serv Res.
29 Glisson C, Landsverk J, Schoenwald S, et al. (2008). Assessing the organizational social context (OSC) of mental health services: implications for research and practice. Adm Policy Ment Health.
30 Mendel P, Meredith LS, Schoenbaum M, et al. (2008). Interventions in organizational and community context: a framework for building evidence on dissemination and implementation in health services research. Adm Policy Ment Health.
31 Aarons GA, Hurlburt M, Horwitz SM. (2011). Advancing a conceptual model of evidence-based practice implementation in public service sectors. Adm Policy Ment Health.
32 Damschroder LJ, Aron DC, Keith RE, et al. (2009). Fostering implementation of health services research findings into practice: a consolidated framework for advancing implementation science. Implement Sci.
33 Meyers DC, Durlak JA, Wandersman A. (2012). The quality implementation framework: a synthesis of critical steps in the implementation process. Am J Community Psychol.
34 Kaplan HC, Provost LP, Froehle CM, et al. (2012). The Model for Understanding Success in Quality (MUSIQ): building a theory of context in healthcare quality improvement. BMJ Qual Saf.
35 Ringeisen H, Henderson K, Hoagwood K. (2003). Context matters: schools and the “research to practice gap” in children’s mental health. School Psych Rev.
36 Rojas Smith L, Ashok M, Dy SM, et al. (2014). Contextual Frameworks for Research on the Implementation of Complex System Interventions. Methods Research Report.
37 Hoagwood K. (2014). Personal communication.
38 Barwick MA, Schachter HM, Bennett LM, et al. (2012). Knowledge translation efforts in child and youth mental health: a systematic review. J Evid Based Soc Work.
39 Novins DK, Green AE, Legha RK, et al. (2013). Dissemination and implementation of evidence-based practices for child and adolescent mental health: a systematic review. J Am Acad Child Adolesc Psychiatry.
40 Moher D, Liberati A, Tetzlaff J, et al. (2009). Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. BMJ.
41 United Nations Development Program. (2014). Human development report.
42 Powell BJ, McMillen JC, Proctor EK, et al. (2012). A compilation of strategies for implementing clinical innovations in health and mental health. Med Care Res Rev.
43 Effective Practice and Organisation of Care (EPOC). (2002). EPOC Taxonomy.
44 White CM, Ip S, McPheeters M, et al. (2009). Using existing systematic reviews to replace de novo processes in conducting Comparative Effectiveness Reviews. Methods Guide for Comparative Effectiveness Reviews.
45 Viswanathan M, Ansari MT, Berkman ND, et al. (2012). Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. Methods Guide for Comparative Effectiveness Reviews.
46 Higgins JP, Altman DG, Gotzsche PC, et al. (2011). The Cochrane Collaboration’s tool for assessing risk of bias in randomised trials. BMJ.
47 Viswanathan M, Berkman ND. (2012). Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol.
48 Sterne JAC, Higgins JPT, Reeves BC, et al. (2014). A Cochrane Risk Of Bias Assessment Tool: for Non-Randomized Studies of Interventions (ACROBAT-NRSI), Version 1.0.0.
49 Cornell JE, Mulrow CD, Localio R, et al. (2014). Random-effects meta-analysis of inconsistent effects: a time for change. Ann Intern Med.
50 West SL, Gartlehner G, Mansfield AJ, et al. (2010). Comparative Effectiveness Review Methods: Clinical Heterogeneity. Methods Research Paper.
51 Berkman ND, Lohr KN, Ansari M, et al. (2013). Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Comparative Effectiveness Reviews.
52 Berkman ND, Lohr KN, Ansari MT, et al. (2014). Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol.
53 Guyatt GH, Oxman AD, Kunz R, et al. (2011). GRADE guidelines 6. Rating the quality of evidence--imprecision. J Clin Epidemiol.
54 Bhandari M, Sprague S, Hanson B, et al. (2004). Health-related quality of life following operative treatment of unstable ankle fractures: a prospective observational study. J Orthop Trauma.
55 Atkins D, Chang S, Gartlehner G, et al. (2011). Assessing the Applicability of Studies When Comparing Medical Interventions. Methods Guide for Comparative Effectiveness Reviews.
56 Booth A, Harris J, Croot E, et al. (2013). Towards a methodology for cluster searching to provide conceptual and contextual “richness” for systematic reviews of complex interventions: case study (CLUSTER). BMC Med Res Methodol.
57 Bates MJ. (1989). The design of browsing and berrypicking techniques for the online search interface. Online Review.
58 Ragin C. (2000). Fuzzy-Set Social Science.
59 Schneider CQ, Wagemann C. (2012). Set-theoretic methods for the social sciences: a guide to qualitative comparative analysis.
60 Kahwati L, Viswanathan M, Golin CE, et al. Identifying configurations of behavior change techniques in effective medication adherence interventions: a qualitative comparative analysis in review.
61 Viswanathan M, Golin CE, Jones CD, et al. (2012). Medication Adherence Interventions: Comparative Effectiveness. Closing the Quality Gap: Revisiting the State of the Science.
62 Ragin CC. (1987). The comparative method: moving beyond qualitative and quantitative strategies.
63 Ragin CC. (1999). Using qualitative comparative analysis to study causal complexity. Health Serv Res.
64 Ragin CC. (2008). Redesigning social inquiry: fuzzy sets and beyond.
65 Kahwati L, Jacobs S, Kane H, et al. Using qualitative comparative analysis in a systematic review of a complex intervention in review.
66 Gully KJ, Price BL, Johnson MK. (2008). Increasing abused children’s access to evidence-based treatment: diffusion via parents as consumers. Child Maltreat.
67 Glisson C, Hemmelgarn A, Green P, et al. (2012). Randomized trial of the Availability, Responsiveness, and Continuity (ARC) organizational intervention with community-based mental health programs and clinicians serving youth. J Am Acad Child Adolesc Psychiatry.
68 Glisson C, Hemmelgarn A, Green P, et al. (2013). Randomized trial of the Availability, Responsiveness and Continuity (ARC) organizational intervention for improving youth outcomes in community mental health programs. J Am Acad Child Adolesc Psychiatry.
69 Bjorknes R, Manger T. (2013). Can parent training alter parent practice and reduce conduct problems in ethnic minority children? A randomized controlled trial. Prev Sci.
70 Kjobli J, Hukkelberg S, Ogden T. (2013). A randomized trial of group parent training: reducing child conduct problems in real-world settings. Behav Res Ther.
71 Grupp-Phelan J, McGuire L, Husky MM, et al. (2012). A randomized controlled trial to engage in care of adolescent emergency department patients with mental health problems that increase suicide risk. Pediatr Emerg Care.
72 Myers K, Vander Stoep A, Lobdell C. (2013). Feasibility of conducting a randomized controlled trial of telemental health with children diagnosed with attention-deficit/hyperactivity disorder in underserved communities. J Child Adolesc Psychopharmacol.
73 Hogue A, Dauber S. (2013). Assessing fidelity to evidence-based practices in usual care: the example of family therapy for adolescent behavior problems. Eval Program Plann.
74 Asarnow JR, Jaycox LH, Duan N, et al. (2005). Effectiveness of a quality improvement intervention for adolescent depression in primary care clinics: a randomized controlled trial. JAMA.
75 Asarnow JR, Jaycox LH, Tang L, et al. (2009). Long-term benefits of short-term quality improvement interventions for depressed youths in primary care. Am J Psychiatry.
76 Ngo VK, Asarnow JR, Lange J, et al. (2009). Outcomes for youths from racial-ethnic minority groups in a quality improvement intervention for depression treatment. Psychiatr Serv.
77 Wells KB, Tang L, Carlson GA, et al. (2012). Treatment of youth depression in primary care under usual practice conditions: observational findings from Youth Partners in Care. J Child Adolesc Psychopharmacol.
78 Henggeler SW, McCart MR, Cunningham PB, et al. (2012). Enhancing the effectiveness of juvenile drug courts by integrating evidence-based practices. J Consult Clin Psychol.
79 Liddle HA, Dakof GA, Henderson C, et al. (2011). Implementation outcomes of Multidimensional Family Therapy-Detention to Community: a reintegration program for drug-using juvenile detainees. Int J Offender Ther Comp Criminol.
80 Weisz JR, Southam-Gerow MA, Gordis EB, et al. (2009). Cognitive-behavioral therapy versus usual clinical care for youth depression: an initial test of transportability to community clinics and clinicians. J Consult Clin Psychol.
81 Bradshaw CP, Mitchell MM, Leaf PJ. (2010). Examining the effects of schoolwide positive behavioral interventions and supports on student outcomes: Results from a randomized controlled effectiveness trial in elementary schools. J Posit Behav Interv.
82 Bradshaw CP, Pas ET, Goldweber A, et al. (2012). Integrating school-wide positive behavioral interventions and supports with tier 2 coaching to student support teams: The PBISplus model. Adv School Mental Health Promot.
83 Kolko DJ, Baumann BL, Herschell AD, et al. (2012). Implementation of AF-CBT by community practitioners serving child welfare and mental health: a randomized trial. Child Maltreat.
84 Garner BR, Godley SH, Dennis ML, et al. (2012). Using pay for performance to improve treatment implementation for adolescent substance use disorders: results from a cluster randomized trial. Arch Pediatr Adolesc Med.
85 Epstein JN, Langberg JM, Lichtenstein PK, et al. (2011). Use of an Internet portal to improve community-based pediatric ADHD care: a cluster randomized trial. Pediatrics.
86 Epstein JN, Rabiner D, Johnson DE, et al. (2007). Improving attention-deficit/hyperactivity disorder treatment outcomes through use of a collaborative consultation treatment service by community-based pediatricians: a cluster randomized trial. Arch Pediatr Adolesc Med.
87 Beidas RS, Edmunds JM, Marcus SC, et al. (2012). Training and consultation to promote implementation of an empirically supported treatment: a randomized trial. Psychiatr Serv.
88 Lochman JE, Boxmeyer C, Powell N, et al. (2009). Dissemination of the Coping Power program: importance of intensity of counselor training. J Consult Clin Psychol.
89 Carroll AE, Bauer NS, Dugan TM, et al. (2013). Use of a computerized decision aid for ADHD diagnosis: a randomized controlled trial. Pediatrics.
90 Lester H, Birchwood M, Freemantle N, et al. (2009). REDIRECT: cluster randomised controlled trial of GP training in first-episode psychosis. Br J Gen Pract.
91 Henggeler SW, Chapman JE, Rowland MD, et al. (2013). Evaluating training methods for transporting contingency management to therapists. J Subst Abuse Treat.
92 Sterling S, Kline-Simon AH, Satre DD, et al. (2015). Implementation of screening, brief intervention, and referral to treatment for adolescents in pediatric primary care a cluster randomized trial. JAMA Pediatrics.
93 Henggeler SW, Sheidow AJ, Cunningham PB, et al. (2008). Promoting the implementation of an evidence-based intervention for adolescent marijuana abuse in community settings: testing the use of intensive quality assurance. J Clin Child Adolesc Psychol.
94 Wildman BG, Langkamp DL. (2012). Impact of location and availability of behavioral health services for children. J Clin Psychol Med Settings.
95 Ronsley R, Rayter M, Smith D, et al. (2012). Metabolic monitoring training program implementation in the community setting was associated with improved monitoring in second-generation antipsychotic-treated children. Can J Psychiatry.
96 Ringle VA, Read KL, Edmunds JM, et al. (2015). Barriers to and facilitators in the implementation of cognitive-behavioral therapy for youth anxiety in the community. Psychiatr Serv.
97 Beidas RS, Edmunds J, Ditty M, et al. (2014). Are inner context factors related to implementation outcomes in cognitive-behavioral therapy for youth anxiety?. Adm Policy Ment Health.
98 Chadwick Center for Children and Families. (2004). Closing the quality chasm in child abuse treatment: identifying and disseminating best practices.
99 Lochman JE, Boxmeyer C, Powell N, et al. (2006). Masked intervention effects: Analytic methods for addressing low dosage of intervention. New Directions for Evaluation.
100 Henggeler SW, Halliday-Boykins CA, Cunningham PB, et al. (2006). Juvenile drug court: enhancing outcomes by integrating evidence-based treatments. J Consult Clin Psychol.
101 American Academy of Pediatrics, Committee on Quality Improvement, Subcommittee on Attention-Deficit/Hyperactivity Disorder. (2000). Clinical practice guideline: diagnosis and evaluation of the child with attention deficit/hyperactivity disorder. Pediatrics.
102 American Academy of Pediatrics, Subcommittee on Attention-Deficit/Hyperactivity Disorder, Committee on Quality Improvement. (2001). Clinical practice guideline: treatment of the school-aged child with attention deficit/hyperactivity disorder. Pediatrics.
103 Epstein JN, Langberg JM, Lichtenstein PK, et al. (2013). The myADHDportal.com Improvement Program: an innovative quality improvement intervention for improving the quality of ADHD care among community-based pediatricians. Clin Pract Pediatr Psychol.
104 Bickman L, Kelley SD, Athay M. (2012). The technology of measurement feedback systems. Couple Family Psychol.
105 Bickman L, Douglas SR, De Andrade AR, et al. (2015). Implementing a measurement feedback system: a tale of two sites. Adm Policy Ment Health.
106 Dennis M, Godley SH, Diamond G, et al. (2004). The Cannabis Youth Treatment (CYT) study: main findings from two randomized trials (Structured abstract). J Subst Abuse Treat.
107 Glisson C, Williams NJ. (2015). Assessing and changing organizational social contexts for effective mental health services. Annu Rev Public Health.
108 Glisson C. (2002). The organizational context of children’s mental health services. Clin Child Fam Psychol Rev.
109 Glisson C, Schoenwald SK. (2005). The ARC organizational and community intervention strategy for implementing evidence-based children’s mental health treatments. Ment Health Serv Res.
110 Johnston LD, O’Malley PM, Bachman JG, et al. (2011). Monitoring the Future national survey results on adolescent drug use: Overview of key findings, 2010.
111 World Health Organization, Settings. (2010). mhGAP Intervention Guide for Mental, Neurological and Substance Use Disorders in Non-Specialized Health.
112 Stice E, South K, Shaw H. (2012). Future directions in etiologic, prevention, and treatment research for eating disorders. J Clin Child Adolesc Psychol.
113 Lester H, Allan T, Wilson S, et al. (2003). A cluster randomised controlled trial of patient-held medical records for people with schizophrenia receiving shared care. Br J Gen Pract.
114 Okelo SO, Butz AM, Sharma R, et al. (2013). Interventions to modify health care provider adherence to asthma guidelines: a systematic review. Pediatrics.
115 James AC, James G, Cowdrey FA, et al. (2015). Cognitive behavioural therapy for anxiety disorders in children and adolescents. Cochrane Database Syst Rev.
116 Wang PS, Lane M, Olfson M, et al. (2005). Twelve-month use of mental health services in the United States: results from the National Comorbidity Survey Replication. Arch Gen Psychiatry.
117 Collins KA, Westra HA, Dozois DJ, et al. (2004). Gaps in accessing treatment for anxiety and depression: challenges for the delivery of care. Clin Psychol Rev.
118 Bryant J, Passey ME, Hall AE, et al. (2014). A systematic review of the quality of reporting in published smoking cessation trials for pregnant women: an explanation for the evidence-practice gap?. Implement Sci.
119 Berg-Schlosser D, De Meur G. (2009). Comparative research design: Case and variable selection. Rihoux Benoit RC, Ragin C, editors. Configurational comparative methods: qualitative comparative analysis (QCA) and related techniques.
120 Chorpita BF, Regan J. (2009). Dissemination of effective mental health treatment procedures: maximizing the return on a significant investment. Behav Res Ther.
121 Effective Practice and Organisation of Care (EPOC). (2015). EPOC Taxonomy.
122 Powell BJ, Waltz TJ, Chinman MJ, et al. (2015). A refined compilation of implementation strategies: results from the Expert Recommendations for Implementing Change (ERIC) project. Implement Sci.
123 Rycroft-Malone J, Burton CR. (2011). Is it time for standards for reporting on research about implementation?. Worldviews Evid Based Nurs.
124 Newhouse R, Bobay K, Dykes PC, et al. (2013). Methodology issues in implementation science. Med Care Res Rev.
125 Pinnock H, Epiphaniou E, Sheikh A, et al. (2015). Developing standards for reporting implementation studies of complex interventions (StaRI): a systematic review and e-Delphi. Implement Sci.
126 Curran GM, Bauer M, Mittman B, et al. (2012). Effectiveness-implementation hybrid designs: combining elements of clinical effectiveness and implementation research to enhance public health impact. Med Care.