# Methods

The methods for this systematic review follow the Methods Guide for Effectiveness and Comparative Effectiveness Reviews from the Agency for Healthcare Research and Quality (AHRQ; available at http://www.effectivehealthcare.ahrq.gov/methodsguide.cfm). The PRISMA (Preferred Reporting Items for Systematic Reviews and Meta-Analyses) checklist facilitated the preparation and reporting of the systematic review.^40^

## Topic Refinement and Protocol Review

The Evidence-based Practice Centers (EPCs) developed this topic and Key Questions (KQs) through a public process. The topic was nominated within AHRQ and subsequently developed and refined by our EPC. Initially, a panel of Key Informants gave input on the KQs to be examined; AHRQ then posted these questions on the Effective Health Care Web site for public comment from September 15, 2014, through October 6, 2014. We revised the KQs in response to comments.

We then drafted a protocol for the systematic review and recruited a panel of technical experts to provide high-level content and methodological expertise throughout the development of the review. The final protocol was posted on the Effective Health Care Web site at http://effectivehealthcare.ahrq.gov/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=2030 on December 30, 2014, and registered on PROSPERO (Registration number: CRD42015024759). Following release of our draft report and peer review, we amended our protocol to include additional review and analysis strategies suitable for complex interventions.

## Literature Search Strategy

### Search Strategy

We systematically searched, reviewed, and analyzed the scientific evidence for each of our three KQs. We began with a focused MEDLINE® search for eligible interventions using a combination of medical subject headings (MeSH®) and title and abstract keywords, limiting the search to human-only studies (Appendix A) (from inception through January 14, 2016). We also searched the Cochrane Library, PsycINFO, and CINAHL (Cumulative Index to Nursing and Allied Health Literature) using analogous search terms. These searches included randomized controlled trials (RCTs), controlled clinical trials (CCTs), and systematic reviews. We selected these databases based on preliminary searches and consultation with content experts. We conducted quality checks to ensure that the search identified known studies (e.g., studies identified during topic nomination and refinement). If we did not identify the known studies, we revised and reran our searches.

In addition, we searched the gray literature (information that is unpublished and not controlled commercially) for studies relevant to this review and included studies that met all the inclusion criteria and contain enough methodological information to assess risk of bias. Sources of gray literature include ClinicalTrials.gov, the World Health Organization’s International Clinical Trials Registry Platform, the National Institutes of Health Research Portfolio Online Reporting Tools, the Database of Promoting Health Effectiveness Reviews, and CMS.gov. To avoid retrieval bias, we manually searched the reference lists of landmark studies and background articles on this topic to look for any relevant citations that our electronic searches might have missed.

### Inclusion and Exclusion Criteria

We specified our inclusion and exclusion criteria based on the populations, interventions, comparators, outcomes, timing, and settings (PICOTS) identified through the topic refinement exercise (Table 1).

Table 1 Inclusion/exclusion criteria for strategies to improve mental health services for children and adolescents

Category | Inclusion | Exclusion
Population | Health care systems, organizations, and practitioners that care for children and adolescents or mixed (child and adult) populations with mental health problems | Health care systems, organizations, and practitioners that care only for adults 18 years of age or older Health care systems, organizations, and practitioners that care for children and adolescents with only developmental disorders
Interventions (Strategies) | - Quality improvement strategies (e.g., strategies targeting systems and practitioners of mental health care to children and adolescents with the goal of improved quality of care); - Implementation strategies (e.g., strategies to integrate evidence-based practice [EBP] interventions that meet National Registry of Evidence-based Programs and Practices [NREPP] inclusion criteria with the goal of changing practice patterns); - Dissemination strategies (e.g., strategies to enhance the adoption and implementation of evidence-based interventions that meet NREPP inclusion criteria) | Interventions targeting only patients, only drug interventions (although strategies to implement or disseminate drug interventions would qualify), and interventions not otherwise described in inclusion criteria
Comparator | Any control strategy, including usual care or different variants of the same intervention | None
Outcomes | Intermediate outcomes (at least one intermediate outcome is required for KQs 1, 3) Patient; - access to care; - satisfaction; - treatment engagement; - therapeutic alliance with practitioner; Practitioner; - satisfaction with or acceptability of approach; - protocol adherence/program model fidelity; - competence or skills; System or organization; - feasibility; - uptake; - timeliness; - penetration; - sustainability; - resources (including costs); Patient health and service utilization outcomes (at least one of these outcomes is required for KQs 1 and 3 unless the strategy uses an intervention that is an EBP); - Change in mental health status, including symptom change, response, remission, relapse, and recurrence; - Coexisting physical health conditions, substance use problems, developmental disorders, other mental health problems; Mortality Socialization skills and behavior Functional status Quality of life Service utilization (e.g., visits, hospitalizations) Harms of strategy Patient; - lower treatment engagement or more dropouts; - negative impact on therapeutic relationship; - side effects of EBP incorporated into strategy (e.g., adverse events, suicidality); - patient dissatisfaction with care; Practitioner; - burnout or exhaustion; - turnover; - resistance to the intervention; System or organization; - cost; - failure to sustain the EBP; - resistance to change | All outcomes not otherwise specified
Timing of outcome measurement | All | None
Settings | Outpatient settings serving children and adolescents with mental health problems (primary care, specialty care, emergency rooms, community mental health centers, integrated care settings, federally qualified health centers, schools, homes) | Inpatient or residential treatment settings, drug treatment programs, jails or prisons
Geographic setting | Countries with a very high Human Development Index (HDI)^41^ | Countries with high, medium, low, or very low HDI
Publication language | English | All other languages
Study design | KQs 1, 3 (benefits); - RCTs; - CCTs; - Systematic review and meta-analyses; - Cohort studies; - Interrupted time series; - Case-control studies; KQs 2, 3 (harms):; - RCTs; - CCTs; - Systematic review and meta-analyses; - Cohort studies; - Interrupted time series; - Case-control studies | Case series Case reports Nonsystematic reviews Cross-sectional studies Before and after studies without time-series data Other designs without a control or comparison group
Publication type | Any publication reporting primary data | Publications not reporting primary data

CCT = controlled clinical trial; EBP = evidence-based practice; D = dissemination; HDI = Human Development Index; I = implementation; KQ = Key Question; NREPP = National Registry of Evidence-based Programs and Practices; QI = quality improvement; RCT = randomized controlled trial.

We included quality improvement (QI), implementation, and dissemination strategies that targeted systems, organizations, or practitioners of mental health care to children and adolescents ages 18 years or younger, who were already experiencing mental health symptoms. We did not include strategies such as the implementation of educational interventions for reading disorders. We also limited our review of implementation strategies to those focusing on evidence-based practice (EBP) interventions. For defining EBPs, we relied on the minimum requirements set forth by the Substance Abuse and Mental Health Services Administration’s (SAMHSA’s) National Registry of Evidence-based Programs and Practices (NREPP) (www.nrepp.samhsa.gov). These criteria specify that the intervention needs to have produced one or more positive behavioral outcomes in at least one study using an experimental or quasi-experimental design with results published in a peer-reviewed journal or similar publication. In addition, implementation materials, training and support resources, and quality assurance procedures for these interventions need to be ready for use by the public. Because we view the NREPP criteria as a liberal definition of “evidence,” we do not anticipate missing studies with a basic level of proven effectiveness.

We use the term “strategy” to reference the total sum of components used to target health care systems and/or practitioners to improve the quality of care for children and adolescents with mental health problems. We use the term “intervention” to denote a specific EBP used as part of a strategy. Examples of types of included strategies are outlined below.

1. QI: strategies targeting systems and providers of mental health care to children and adolescents with the goal of improved quality of care. Examples of QI strategies include the following:^16,18^
  a. Organization or system targets: changes to the organization including case management, changing from paper to computer systems, increased staffing, changes in reimbursement schemes
  b. Clinician targets: audit and feedback, facilitated relay of clinical data to providers, pay for performance, and provider reminder systems
2. Implementation: strategies used to adopt and integrate EBPs (defined based on the minimum criteria set forth by SAMHSA’s NREPP) into routine care (e.g., strategies to integrate evidence-based health interventions and change practice patterns). Examples of implementation strategies that vary by method of implementation facilitation include the following:
  a. Planning
  b. Educating
  c. Financing
  d. Restructuring
  e. Managing quality
  f. Attending to policy contexts^42^
3. Dissemination: strategies used to disseminate evidence through increasing access to EBPs, people’s motivation to use and apply EBPs (defined based on the minimum criteria set forth by SAMHSA’s NREPP), or people’s ability to use and apply EBPs. Examples of such approaches include the following:
  a. Increasing the reach of the evidence (e.g., social media, interpersonal outreach)
  b. Increasing people’s motivation to use and apply the evidence (e.g., use of opinion leaders, champions, social networks)
  c. Increasing people’s ability to use and apply the evidence (e.g., additional resources, skills building)
  d. Using a multipronged approach with any of these three dissemination strategies (e.g., social marketing, academic detailing)^22^

Because strategies tended to be complex in nature and the number and types of components that varied between the treatment arm and comparison group arm differed by study, we also recorded components of each strategy by study arm according to the Effective Practice and Organisation of Care (EPOC) taxonomy (Appendix B).^43^ Because many of the comparison groups also contained several components, we marked the components contained in each study arm. This allowed us to fully describe the numerous components that were being combined and tested in each strategy, as well as enabled us to determine whether the study arms differed by a single or multiple components.

We required each included study to report at least one intermediate outcome in a minimum of one of three major categories: (1) practitioner intermediate outcomes (satisfaction, adherence, fidelity, competence), (2) system intermediate outcomes (feasibility, uptake, timeliness, penetration, sustainability, costs), and (3) patient intermediate outcomes (access to care, satisfaction, engagement, therapeutic alliance). This requirement helped ensure that each included study demonstrated impact based on its stated goals of improving quality or implementing or disseminating evidence-based interventions. We also required each study to report at least one patient health or service utilization outcome (change in mental health status, comorbid conditions, mortality, socialization skills and behavior, functional status, quality of life, service utilization) if the strategy was not implementing or disseminating an EBP intervention (i.e., an intervention with proven effectiveness).

For all KQs, we excluded study designs without comparison groups to ensure that our pool of included studies provided strong evidence on the causal link between the strategy and outcomes. We also required that the comparator enabled examination of the strategy effectiveness. That is, we excluded studies in which the strategy (system, organizational, practitioner targets) and the intervention being tested both differed between groups, because the effectiveness of the QI, implementation, or dissemination strategy could not be isolated from the baseline intervention effects.

For KQ 1 studies of benefits and KQ 3 studies of moderators of benefits, we had planned to limit our evidence base to RCTs (standard, clustered, stepped-wedge), CCTs (not randomized), systematic reviews, or meta-analyses. We also planned to consider other designs—specifically, cohort studies (prospective, retrospective, and historical control), interrupted time-series, and case-control studies that met all other inclusion and exclusion criteria—if we found sparse evidence to answer these KQs using trials and systematic reviews (with or without meta-analyses). For KQ 2 and KQ 3 studies of moderators of harms, we included experimental studies noted above, interrupted time series, and observational evidence from prospective cohort studies, retrospective cohort studies, and case-control studies that met all other inclusion and exclusion criteria.

Our exclusion of non-English-language studies is based on limitations of time and resources. However, we examined English-language abstracts of non-English-language studies to assess the potential size of the literature that would be missed through this approach.

## Moderators

We searched for studies with information on the following seven moderators of effectiveness or harms. Categories 2 through 6 are consistent with the Consolidated Framework for Implementation Research framework defined earlier.

1. Patient characteristics, such as age, gender, race and ethnicity, cognitive ability, diagnosis and severity of mental health problem, coexisting conditions, and cotreatments;
2. Intervention characteristics, such as complexity; manualized or not; intensity, frequency or duration; and adjustment of intervention to fit context;
3. Outer setting, such as external policy, incentives, availability of alternative care systems;
4. Inner setting or organizational factors, such as type of outpatient setting, structure or size, culture, implementation climate, and readiness of organization for implementation;
5. Characteristics of involved individuals such as type, knowledge, beliefs, self-efficacy, leadership, education, certifications, and years of practice of practitioners or characteristics of parents/caregivers;
6. Process characteristics, such as fidelity to the planned strategy, fidelity to the EBP, use of champions, and supervision or oversight; and
7. Other components, such as length of followup.

## Study Selection

Two trained research team members independently reviewed all titles and abstracts identified through searches for eligibility against our inclusion and exclusion criteria. Studies marked for possible inclusion by either reviewer underwent a dual, independent full-text review. For studies without adequate information to determine inclusion or exclusion, we retrieved the full text and then made the determination. We tracked all results in an EndNote^®^ bibliographic database (Thomson Reuters, New York, NY).

We retrieved and reviewed the full text of all articles included during the title and abstract review phase. Two trained team members independently reviewed each full-text article for inclusion or exclusion based on the eligibility criteria described above. If both reviewers agreed that a study did not meet the eligibility criteria, we excluded the study. If the reviewers disagreed, conflicts were resolved by discussion and consensus or by consulting a third member of the review team. All results were tracked in an EndNote database. We also recorded the main reason that each excluded full-text publication did not satisfy the eligibility criteria (Appendix C).

## Data Extraction

For studies that met our inclusion criteria, trained reviewers abstracted important information into evidence tables. We designed data abstraction forms (in AHRQ’s Systematic Review Data Repository) to gather pertinent information from each article. Data recorded included the strategies (including evidence-based interventions), characteristics of the target(s) of the specific strategy (such as systems, organizations, and clinicians), comparators, settings, characteristics of the children or adolescents with mental health problems, study designs, analysis methods, and results. A second member of the team reviewed all data abstractions for completeness and accuracy.

For systematic reviews with or without meta-analyses, we planned to use the five-step process described in the AHRQ Methods Guide^44^ to assess the relevance and quality of the systematic review and to determine how to use the information provided. We intended then to either incorporate existing systematic reviews into this one or use them to replace all or part of the de novo process or refine our search strategy only if they were fully relevant and of high quality. Reviews that did not meet these criteria would be used to cross-check references.

## Risk of Bias Assessment

To assess the risk of bias of studies, two independent reviewers used predefined, design-specific criteria based on guidance in the Methods Guide (Appendix D).^45^ We resolved conflicts by consensus or by consulting a third member of the team. For RCTs, we relied on the risk of bias tool developed by the Cochrane Collaboration.^46^ We assessed the risk of bias of observational studies using questions from an item bank developed by RTI International^47^ and A Cochrane Risk Of Bias Assessment Tool for Non-Randomized Studies of Interventions (ACROBAT-NRSI).^48^ Minimum eligibility criteria for systematic reviews included an explicit description of search strategy used and determination that the search strategy was adequate, application of predefined eligibility criteria and risk of bias assessment for all included studies, and synthesis of the results presented.

In general terms, a study with no identifiable flaws has a low risk of bias. A study with medium risk of bias is susceptible to some bias but probably not sufficient to invalidate its results. A study with high risk of bias has significant methodological flaws (stemming from, for example, serious errors in design or conduct) that may invalidate its results. We considered the risk of bias for each relevant outcome of a study. When studies did not report sufficient detail to assess the validity of the design or study conduct, we judged the risk of bias to be unclear.

## Data Synthesis

We had planned that if we found five or more similar studies that use a common design (all RCTs or all cohort) for a comparison of interest, we would consider quantitative analysis (i.e., meta-analysis) of the data from those studies.^49^ We also planned to consider conducting mixed treatment comparisons meta-analysis using Bayesian methods to compare interventions with one another if we were able to identify a sufficient number of studies with a common comparator (e.g., waitlist). For all analyses, we intended to use random-effects models to estimate pooled or comparative effects if quantitative analyses were warranted. For all outcomes, we present relative risks or mean differences, with confidence intervals, whenever calculable. For outcomes with multiple measures, we present forest plots (Appendix E).

To determine whether quantitative analyses were appropriate, we assessed the clinical and methodological heterogeneity of the studies under consideration following established guidance.^50^ We did this by qualitatively assessing the PICOTS of the included studies, looking for similarities and differences.

## Strength of the Body of Evidence

We graded the strength of a body of evidence based on the updated guidance in the Methods Guide.^51,52^ The AHRQ EPC approach incorporates five key domains: study limitations (includes study design and aggregate risk of bias), consistency, directness, precision of the evidence, and reporting bias. It also considers other optional domains that may be relevant for some scenarios, such as a dose-response association, plausible confounding that would decrease the observed effect, and strength of association (magnitude of effect). These domains are particularly relevant for observational studies. Thus, we considered these domains in addition to the five key domains for observational studies included in our review.

Two reviewers assessed each domain for each key outcome and resolved any differences by consensus discussion. Senior members of the review team (including at least one subject matter expert and one methodologist) graded the strength of evidence.

Grades reflect the confidence that the reviewers have that various estimates of effect are close to true effects with respect to the KQs in a systematic review. Table 2 defines the four grades.

Table 2 Definitions of the grades of overall strength of evidence^51^

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable (i.e., another study would not change the conclusions).
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

Risk of bias assessments for individual studies feed into the rating for the first of the strength of evidence domains, study limitations. Specifically, we rated bodies of evidence comprising trials with a high risk of bias as having high study limitations. Medium or unclear risk of bias studies resulted in medium study limitations. Low risk of bias studies resulted in low study limitations. In keeping with GRADE and strength of evidence guidance, we rated observational studies as having high study limitations.^52,53^

As described above, study design and study limitations together set the baseline strength of evidence grade. Other domains then could either reduce or increase the grade. A body of evidence with high study limitations, with no other reasons to increase confidence (dose-response, large magnitude of effect, plausible confounding) or decrease it (inconsistency, imprecision, indirectness, reporting bias) would generally have a low strength of evidence grade. A body of evidence with low study limitations, with no reasons to decrease confidence (inconsistency, imprecision, indirectness, reporting bias), would generally have a high strength of evidence grade. In other words, although study design and study limitation provide a baseline judgment of strength of evidence, each of four additional sources of uncertainty (inconsistency, imprecision, indirectness, reporting bias) serve to further reduce the strength of evidence grade.

For each source of uncertainty, we consistently used the following rubric to evaluate its effect on the overall strength of evidence across outcomes. Specifically, for indirectness, we rated intermediate outcomes as direct, rather than indirect, evidence. For this systematic review, these outcomes can be interpreted as direct measures of process change. Regarding consistency, we rated it as unknown for bodies of evidence with single studies; the rating of unknown consistency did not lower the overall grade. We relied on established guidance to judge precision.^54^ Regarding imprecision, we specified the reasons for our judgment in footnotes to strength of evidence tables (small sample size or event rate, particularly when considering the optimum information size for the specific outcome, confidence intervals crossing the line of no difference or very wide confidence intervals). We downgraded the overall strength of evidence by two levels when we found multiple reasons for imprecision. We upgraded the evidence by one level for factors such as large magnitude of effect. Strength of evidence tables for each study are shown in Appendix F.

## Applicability

We accessed applicability of the evidence following guidance from the Methods Guide.^55^ We used the PICOTS framework to explore factors that affect applicability. Some factors relevant to the generalizability of our findings include the following:

- Patient characteristics in the study do not match typical characteristics of patients receiving mental health care.
- The study’s health care delivery setting in the system or organization is not generalizable to typical settings.
- The nature of the comparison usual care group is not typical of the type of mental health care rendered in the system or organization or provided by practitioners.
- The types of practitioners in the organization the study employed does not match those in typical mental health care settings.
- The implementation of particular EBP interventions is not feasible in typical care settings.
- The intensity of the QI, implementation, or dissemination strategy employed by the study is not feasible to apply in practice.
- The timing of the strategy would be difficult to implement in typical care settings.

## Peer Review and Public Commentary

Experts in QI, implementation, and dissemination strategies to improve the mental health care of children and adolescents were invited to provide external peer review of the draft systematic review. AHRQ staff and an Associate Editor reviewed the draft systematic review before it went out for peer review. The EPC Associate Editors are leaders in their respective fields and are actively involved as directors or leaders at their EPCs. Their role is to assess adherence to established methodology and guidelines for EPC-based research. The draft report was posted on the AHRQ Web site from September 16, 2015, to October 13, 2015, to elicit public comment. We revised the report in response to reviewer comments, expanded the analysis strategies, and noted any resulting revisions to the text in the “Disposition of Comments Report.” This disposition report will be made available 3 months after the final systematic review is posted on the AHRQ Web site.

## Additional Analyses in Response to Peer Review and Public Commentary

In response to feedback from peer reviewers and public commenters seeking additional contextual and actionable information on the complex interventions included in this review, we added two new sources of information (systematic searches and review of related publications and direct contact of study investigators) and conducted one additional method of analysis (qualitative comparative analysis). Our primary intent in conducting these additional analyses was to identify evidence or hypotheses on the success or failure of interventions.

### Searches for Related Publications

Methodologists have suggested that single studies from complex interventions rarely contain information on how these interventions may work. Additional search approaches of related publications (known as “cluster searching”) may identify sibling (multiple publications on the same study) or kinship studies (publications from a common antecedent study or common theoretical foundation).^56^ Although several strategies can assist with identifying related publications,^57^ we focused on searches of authors and interventions (Appendix A). In reviewing the yield at the title and abstract stage, we used our formal inclusion and exclusion criteria with the exception of the study design criterion, because we were particularly interested in qualitative studies, evaluations of interventions, and theoretical studies. When evaluating full-text reviews, we matched full text to the likely original publication to understand cluster relationships and relevance of the findings to the original study.

### Outreach to Authors

We also contacted study authors to obtain information about critical components for strategies of included studies. As part of a parallel project to better understand the uses and limitations of trial registries for data on outcomes, we reached out to study authors to elicit their views on critical components of included interventions (Appendix G). We listed differences between intervention arms and asked authors which of those differences was critical to investigators wishing to replicate their study.

### Qualitative Comparative Analysis

Using the dataset abstracted for the primary synthesis, we used qualitative comparative analysis (QCA) to examine set relationships between combinations of strategy components and improvements in outcomes. QCA is a theory-driven approach that is particularly suited to understanding complex causal patterns within and across cases. QCA uses formal logic, a branch of mathematics, to examine combinations of conditions (in our study, components of a complex intervention) and their relationship to an outcome. Individual conditions and combinations of conditions can be necessary, sufficient, or both to the outcome. Necessary conditions (and combinations of conditions) are antecedent to the outcome: the outcome cannot occur in the absence of the necessary condition. Sufficient conditions (and combinations of condition) guarantee the outcome (i.e., when the condition is present, the outcome is also present).^58,59^ For example, access to evidence-based interventions is necessary for uptake of evidence-based interventions, but it may not be sufficient for uptake; other variables may be necessary as well (e.g., administrative support for clinical staff).

QCA can accommodate qualitative data and quantitative data within the same analysis and offers a systematic way for evaluating causal complexity because it is based on formal logic and set theory, not statistical theory. Traditional variable-oriented methods typically deconstruct the unit of analysis into its component variables and then assess statistical correlations among one or more variables, but this may not be the best approach for complex interventions. QCA can identify multiple “recipes” or sufficient combinations for achieving an outcome; in other words, one size does not fit all. For example, in Kahwati et al.’s application of QCA to a systematic review on medication adherence, the authors found several combinations of behavioral techniques in included studies that led to improved adherence.^60,61^ Several authors describe QCA methods in greater detail.^59,60,62–65^ We based our methods on the approach used by Kahwati et al. in a recent QCA of medication adherence studies.^60,65^ We included as many of the studies in this review as possible, but we recognized this may not be feasible or always appropriate (e.g., when a study did not report a particular outcome).

Specific analytic steps are described in Appendix H.