# Introduction

## Background

### Condition

Approximately one in five children and adolescents living in the United States has one or more mental, emotional, or behavioral health disorders according to the Diagnostic and Statistical Manual of Mental Disorders, Fourth Edition criteria in any given year.^1^ These disorders contribute to problems with family, peers, and academic functioning. They may exacerbate coexisting conditions (including other mental and substance use disorders and chronic health conditions) and may reduce quality of life. They also increase the risk of involvement with the criminal justice system and other risk-taking behaviors and suicide.^2^

### Strategies To Improve Mental Health in Children

Several key publications in the mid- to late-1990s suggested that usual care in children’s mental health had, at best, no^3^ and sometimes harmful effects.^4^ Since then, mental health interventions that improve children and adolescents with mood disorders, anxiety disorders, disruptive behavior disorders, psychotic disorders, eating disorders, and substance use disorders have been tested to varying degrees of benefit.^5,6^

Despite advances in the evidence base,^5,7^ some outcomes for children with mental health problems remain suboptimal because of issues with access to care and the failure of systems and providers to adopt established quality improvement (QI) strategies and interventions with proven effectiveness (e.g., evidence-based practices [EBPs]). Studies using nationally representative data on U.S. adolescents show that only approximately one in five children with mental health problems receives services, and only one-third of treatment episodes are considered minimally adequate (at least four visits with psychotropic medication or at least eight visits without psychotropic medication).^8–10^ The current health care system continues to provide fragmented care to children and adolescents in numerous uncoordinated systems, rendering inefficient the delivery of needed services.^11^ Moreover, clinicians (particularly primary care practitioners) may lack the time, knowledge, or training to identify and treat or refer patients with mental health problems.^12^

Given the gap between observed and achievable processes and outcomes, one way to improve the mental health care of children and adolescents is to adopt QI strategies and develop strategies to implement or disseminate interventions with known effectiveness. Such strategies target changes in the organization and delivery of mental health services.^13,14^ They seek to improve the quality of care and patient outcomes by closing the gap between research evidence and practice.^15–17^

In keeping with recent Agency for Healthcare Research and Quality (AHRQ) reviews with a similar focus,^18^ we view QI strategies as “any intervention aimed at reducing the quality gap for a group of patients representative of those encountered in routine practice.”^16, p.13^ For this review, we focus on QI strategies targeting practitioners (e.g., via education, training, and supervision) and organizations (e.g., via financial incentives, regulation, and policies) that provide mental health care to children and adolescents, with the ultimate goal of improving both the process and outcomes of that care.^19,20^

Some investigators consider implementation and dissemination strategies as a particular subset of initiatives to improve the quality of care. However, the field of implementation and dissemination is so new that the conceptual framework and terminology in relationship to QI efforts have not been fully standardized yet.^21^ We do not take a position on the taxonomy of these terms but refer in the remainder of this report to these strategies as QI, implementation, and dissemination.

Implementation strategies can be differentiated from dissemination strategies.^22–25^ Implementation is “the use of strategies to integrate evidence-based health interventions (e.g., EBPs) and change practice patterns within specific settings.”^22, p.2^ Dissemination is “the active and targeted distribution of information and interventions to a specific public health or clinical practice audience via determined channels using planned strategies,” with “the intent to spread knowledge and associated evidence-based interventions to enhance the adoption and the implementation of the information or intervention.”^22, p.2^

The taxonomy used by the international Cochrane Review Group’s Effective Practice and Organisation of Care (EPOC) Group, which studies complex strategies designed to improve health care professionals’ practice and the organization of health care services, classifies these strategies by whether they include one or more professional, financial, organizational, and regulatory components. Strategies that ultimately strive to improve practice and organization of services typically include various forms of continuing education for providers; quality assurance projects; and financial, organizational, or regulatory interventions that can enable health care professionals to deliver services more effectively and efficiently.

The ultimate goal of these strategies is to improve patient health and service utilization outcomes for children and adolescents with mental health problems. Intermediate outcomes in this context include changes to health care systems, organizations, and practitioners that provide mental health care. Targeting multiple, interrelated, nested levels such as the macro environment (e.g., state), organization or system (e.g., specialty mental health clinic), program (e.g., selected intervention), practitioners (e.g., clinicians), and patients (e.g., children or adolescents and their families) typically increases the effectiveness and sustainability of a particular strategy.^26,27^ For instance, changes in intermediate outcomes such as practitioners’ attitudes^28^ or organizational climate^29^ may influence the successful adoption of and fidelity to EBPs. These practices in turn influence patient health outcomes, such as behavior or quality of life.

### Potential Moderators of Strategy Effectiveness

Several frameworks guide investigations of how certain variables, including contextual factors, influence the effectiveness of the QI, implementation, or dissemination strategy.^30–34^ For example, factors such as the diversity of outpatient settings, which may include schools, primary care, specialty mental health, emergency rooms, and, increasingly, homes for children’s mental health services, may influence the generalizability and applicability of QI, implementation, or dissemination efforts. The organizational factors of the clinical setting may influence outcomes, and many have argued that these unique factors should be examined within the context of QI, implementation, and dissemination studies.^35,36^

One framework commonly used to study implementation research, the Consolidated Framework for Implementation Research (CFIR),^32^ comprises five major domains:

1. intervention characteristics (e.g., strength of the evidence base behind the intervention);
2. “inner setting” (e.g., culture, leadership, and engagement of health care organizations);
3. “outer setting” (e.g., patient needs and resources, external policies and incentives);
4. characteristics of involved individuals (e.g., professional training, experience or characteristics of parents/caregivers); and
5. process by which implementation is accomplished (e.g., plan, evaluate, and reflect).

This CFIR framework can be applied to research on effective implementation of mental health strategies for children and adolescents to begin to understand salient contextual factors.^37^ We used the CFIR as an organizing framework for moderators of strategy effectiveness. In addition to the five domains of the CFIR described above, we added another category of moderators, namely, characteristics of the patient.

## Scope and Key Questions

### Rationale for Evidence Review

The increasing interest in strategies to improve professional practice and delivery of effective mental health services for children and adolescents with mental health problems indicates that the existing body of evidence on these strategies stands poised for an objective systematic review. Decisionmakers are in critical need of information about these approaches to improve children’s mental health care. A better understanding of the comparative benefits, harms, and modifiers of the available strategies to achieve these improvements may help guide a wide array of interests, particularly for practitioners and administrators of care facilities, organizations, and health systems. Such information will also prove important for those making insurance coverage and other policy decisions for these patients with mental health care needs.

This review focuses on evidence about strategies that aim to improve the quality of mental health care rather than evidence about the efficacy or effectiveness of specific interventions. We concentrate on efforts that target practitioners or organizations/systems that care for children and adolescents with mental health problems.

### Proposed Contributions to the Evidence Base

Two recent systematic reviews have addressed this topic. In 2012, Barwick and colleagues examined knowledge translation interventions and strategies related to the delivery, organization, or receipt of child and youth mental health services.^38^ Most studies focused on practitioner or teacher training for behavior change. This systematic review excluded studies of children with substance abuse. In 2013, Novins and colleagues focused on the implementation and dissemination of mental health EBPs, including substance abuse, for children and adolescents.^39^ Our review updates the evidence while considering a broader definition of QI, implementation, and dissemination strategies and a wider array of mental health care needs of children and adolescents than studied in prior reviews.

### Scope of the Review

As reflected in our Key Questions (KQs) and analytic framework below, we have three primary aims for this review. First, we will increase knowledge about the effectiveness of QI, implementation, and dissemination strategies that seek to improve the mental health care of children and adolescents. Second, we will examine harms associated with these strategies. Third, we will attempt to determine whether effectiveness or harms vary in subgroups based on system, organizational, practitioner, or patient characteristics.

Based on feedback from our Key Informants, we did not attempt to review studies that focused on strategies that target systems, organizations, or providers who treat children and adolescents who have only developmental disorders, because of heterogeneity in strategies used and types of systems involved in their care.

Ultimately, this review will inform mental health clinicians, health care system and organization administrators, policymakers, and researchers about effective ways to improve care for children and adolescents with mental health problems.

### Key Questions

KQ 1 What is the effectiveness of QI, implementation, and dissemination strategies employed in outpatient settings by health care practitioners, organizations, or systems that care for children and adolescents with mental health problems to improve:
  a. intermediate patient, provider, or system outcomes
  b. patient health and service utilization outcomes?^a^
KQ 2 What are the harms of these mental health strategies?
KQ 3 Do characteristics of the child or adolescent or contextual factors (e.g., characteristics of patients, practitioners, organizations, or systems; intervention characteristics; setting; or process) modify the effectiveness or harms of strategies to improve mental health care and, if so, how?

### Analytic Framework

Figure 1 depicts the patient populations, interventions, comparators, outcomes, and timing of outcomes assessment (PICOTs) and KQs in relation to these PICOTs.

Figure 1 Analytic framework for strategies to improve mental health care in children and adolescents

EBP = evidence-based practices; KQ = Key Question.

Figure 1 is titled “Analytic framework for strategies to improve mental health care in children and adolescents.” This figure depicts the Key Questions (KQs) within the context of the populations, interventions, comparisons, outcomes, and settings (PICOTS) framework described in the previous section. The framework begins on the left with our population of interest: health care systems, organizations, and providers who care for children and adolescents with mental health problems. A solid horizontal arrow starts from the population and extends right. Above the first part of the thick horizontal arrow is the intervention: dissemination, implementation, or quality improvement strategy. The solid horizontal arrow then leads to intermediate outcomes to illustrate the pathways from the strategy to patient-, provider-, and system-level intermediate outcomes. A dotted horizontal line leads from intermediate outcomes to a final box on the far right of the framework and depicts final health or patient-centered outcome improvements (KQ1). An overarching solid arrow connects the strategy to the patient outcome box on the far right to illustrate the question: what is the effectiveness of dissemination, implementation, and quality improvement strategies employed in outpatient settings by health care providers, organizations, or systems that care for children and adolescents with mental health problems to improve final health or patient-centered outcomes (KQ 1)? As illustrated by the solid vertical arrow below the intervention box, interventions may result in harms (KQ 2). To illustrate whether the effectiveness or harms of mental health strategies (KQ 3) are modified by patient or intervention characteristics, outer or inner context, the characteristics of involved individuals, or the process the framework includes a box of modifiers at the lowest level of the framework that extends from the left to the far right. From the modifiers box, three solid vertical arrows extend upward to the population, the strategy, intermediate outcomes box, and the final health or patient-centered outcomes box.

## Organization of This Report

We describe our methods, and we present our key findings in Results. In Discussion, we discuss our findings; we also examine the limitations of the evidence base and this review, clarify gaps in the knowledge base, and offer recommendations for future research. References follow the final section.

The main report has several appendixes, as follows: A, search strategies; B, EPOC taxonomy tables; C, excluded studies; D, risk of bias tables; E, forest plots; F, strength of evidence; G, transparency of reporting; and H, qualitative comparative analysis. Evidence tables can be accessed at http://srdr.ahrq.gov/projects/530.

a We revised KQ 1 and the outcome specified in our protocol slightly for clarity. We replaced the term “health care providers” with “health care practitioners” to indicate that this particular phrase refers to individuals rather than systems or institutions. We also replaced “final outcomes” with “patient health and service utilization outcomes” for clarity.