# Peer Reviewers

Prior to publication of the final evidence report, EPCs sought input from independent Peer Reviewers without financial conflicts of interest. However, the conclusions and synthesis of the scientific literature presented in this report do not necessarily represent the views of individual reviewers.

Peer Reviewers must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential nonfinancial conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential nonfinancial conflicts of interest identified.

The list of Peer Reviewers follows:

- Marc S. Atkins, Ph.D.
  Departments of Psychiatry and Psychology
  Institute for Juvenile Research
  Dissemination and Implementation Research and Policy Program
  UIC Center for Clinical Translational Science
  University of Illinois at Chicago
  Chicago, IL
- Leonard Bickman, Ph.D.
  Psychological Sciences
  Vanderbilt University
  Nashville, TN
- Tumani Coker, M.D., M.B.A.
  Assistant Professor of Pediatrics
  David Geffen School of Medicine and Mattel Children’s Hospital at UCLA
  Associate Director of Health Services Research
  UCLA Children’s Discovery and Innovation Institute
  Natural Scientist, RAND
  Los Angeles, CA
- Embry Howell, Ph.D.
  The Urban Institute, Health Policy Center
  Washington, DC
- Mark Weist, Ph.D.
  Department of Psychology
  University of South Carolina
  Columbia, SC