# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Jeffrey A. Buck, Ph.D.^*^
  Center for Clinical Standards & Quality
  Centers for Medicare & Medicaid Services
  Baltimore, MD
- Kimberly Eaton Hoagwood, Ph.D.
  Department of Child and Adolescent Psychiatry
  New York University
  New York, NY
- Aaron T. Hogue, Ph.D.
  National Center on Addiction and Substance Abuse
  New York, NY
- Louise Johnson, M.S.
  Division of Children, Adolescents and Their Families
  South Carolina Department of Mental Health
  Columbia, SC
- Kelly Kelleher, M.D., M.P.H.^*^
  The Research Institute at Nationwide Children’s Hospital
  Columbus, OH
- Michael P. Kelly, Ph.D., Hon FRCP, FRCPE, FFPH^*^
  Institute of Public Health
  University of Cambridge
  Cambridge, UK
- Douglas K. Novins, M.D.^*^
  Division of Child & Adolescent Psychiatry
  Department of Psychiatry
  University of Colorado School of Medicine
  Aurora, CO

* Provided input on Draft Report.