# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Kenneth S. Fink, M.D., M.G.A., M.P.H.
  Med-QUEST Division, State of Hawaii
  Department of Human Services
  Kapolei, HI
- Darcy Gruttadaro, J.D.
  National Alliance on Mental Illness
  Arlington, VA
- Kimberly Eaton Hoagwood, Ph.D.
  Department of Child and Adolescent Psychiatry
  New York University
  New York, NY
- Louise Johnson, M.S.
  Division of Children, Adolescents and Their Families
  South Carolina Department of Mental Health
  Columbia, SC
- Kelly Kelleher, M.D., M.P.H.
  The Research Institute at Nationwide Children’s Hospital
  Columbus, OH
- Bryan Samuels, M.P.P.
  Chapin Hall Center for Children at the University of Chicago
  Chicago, IL
- Mark Weist, Ph.D.
  Department of Psychology
  University of South Carolina
  Columbia, SC