# Acknowledgments

The authors gratefully acknowledge the following individuals for their contributions to this project and deeply appreciate their considerable support, commitment, and contributions: Christine Chang, M.D., M.P.H., our AHRQ Task Order Officer; Denise Dougherty, Ph.D., AHRQ Senior Advisor; Charlotte Mullican, M.P.H., AHRQ Senior Advisor; Richard A. Epstein, Ph.D., M.P.H., our Associate Editor; RTI International–University of North Carolina EPC staff—Carol Woodell, B.S.P.H., EPC Project Manager; Daniel Jonas, M.D., M.P.H., EPC Co-Director; Christiane Voison, M.S.L.S., Librarian; Heather Ringeisen, Ph.D., Scientific Reviewer; Emmanuel Coker-Schwimmer, M.P.H., research assistant; Catherine Grodensky, M.P.H., research assistant; Claire Baker, B.S., research assistant; Sharon Barrell, M.A., editor; Laura Small, B.A., editor; and Loraine Monroe, publications specialist.