# Discussion

This section first summarizes key findings and strength of evidence for each Key Question (KQ). These sections are followed by discussions of limitations of the review, limitations of the evidence base, and gaps in the evidence that may benefit from future research, and by our overall conclusions.

## Key Findings and Strength of Evidence

### Key Question 1 Effectiveness of Strategies To Improve Mental Health Care for Children and Adolescents

#### Overview

The strategies included in this review were heterogeneous and difficult to categorize. We encountered a large degree of uncertainty and overlap when classifying the examined strategies as quality improvement (QI), implementation, and dissemination (our initial taxonomy). We then shifted to the Effective Practice and Organisation of Care (EPOC) taxonomy to identify individual components and groups of components.^43^ This taxonomy allowed us to group strategies in two categories: (1) professional training strategies with professional components only or (2) financial or organizational change strategies with at least one financial or organizational component in addition to professional components. Most strategies were complex and included multiple (from two to seven) components.

Table 26 describes interventions and summarizes the evidence for included studies. We graded the strength of evidence of 28 outcomes for professional training strategies and of 19 for financial or organizational change strategies.

Table 26 Strategies to improve mental health of children and adolescents: Summary table

Strategy, Study | Designs, N | Target Condition and Ages of Youth | Comparisons | Component of the Strategy | Major Findings | Strength of Evidence From Results | Reasons for Strength of Evidence
Training practitioners with or without feedback to implement an EBP Beidas et al., 2012^87^ | Cluster RCT, 115 therapists | Anxiety Ages 8–17 years | Augmented active learning vs. routine professional training workshop | Educational meetings or materials | No differences between arms for practitioner satisfaction with approach, protocol adherence, or practitioner skill | Low for no benefit for practitioner satisfaction, adherence, and skill | Low risk of bias, small sample size, imprecise results
Training practitioners with or without feedback to implement an EBP Beidas et al., 2012^87^ | Cluster RCT, 115 therapists | Anxiety Ages 8–17 years | Computerized routine training vs. routine professional training workshop | Educational meetings or materials | No differences between arms for practitioner protocol adherence or program model fidelity, or skill; computerized training group practitioners less satisfied than routine training group practitioners | Low for no benefit for practitioner satisfaction, adherence, and skill | Low risk of bias, small sample size, imprecise results
Adding weekly feedback to practitioners regarding patient symptoms to practitioners Bickman et al., 2011^13^ | Cluster RCT, N of clinicians unclear, 340 youth, 144 clinicians, 383 caregivers | General mental health problem (children who receive home-based mental health treatment) Mean age = 15 years | Weekly and cumulative 90-day feedback vs. cumulative 90-day feedback only on patient symptoms and functioning to practitioners | Audit and feedback | Two-thirds of practitioners did not view Web module | Insufficient for practitioner adherence | High study limitations, unknown precision for adherence
Adding weekly feedback to practitioners regarding patient symptoms to practitioners Bickman et al., 2011^13^ | Cluster RCT, N of clinicians unclear, 340 youth, 144 clinicians, 383 caregivers | General mental health problem (children who receive home-based mental health treatment) Mean age = 15 years | Weekly and cumulative 90-day feedback vs. cumulative 90-day feedback only on patient symptoms and functioning to practitioners | Audit and feedback | Membership in the weekly feedback group increased the rate of decline in functional severity scale by 0.01 (range: 1 to 5, higher scores indicate greater severity) | Low for benefit for functional severity | High study limitations, precise results for symptoms
Adding diagnosis and treatment guidelines to a computer decision support system Carroll et al., 2013^89^ | Cluster RCT, 84 patients | General mental health problem (children who receive home-based mental health treatment) Mean age = 15 years | Computer decision support plus electronic health record (EHR) that included diagnosis and treatment guidelines vs. computer decision support plus EHR only | Educational meetings or materials Patient-reported data Reminders Quality monitoring | Practitioner adherence improved through uptake of guidelines for diagnostic assessment (aOR, 8.0; 95% CI, 1.6 to 40.6); more reporting of 3 of 4 symptom domains at diagnosis | Low for benefit for practitioner adherence and program model fidelity | Medium study limitations, imprecise results with small number of events, large magnitude of effect
Adding diagnosis and treatment guidelines to a computer decision support system Carroll et al., 2013^89^ | Cluster RCT, 84 patients | General mental health problem (children who receive home-based mental health treatment) Mean age = 15 years | Computer decision support plus electronic health record (EHR) that included diagnosis and treatment guidelines vs. computer decision support plus EHR only | Educational meetings or materials Patient-reported data Reminders Quality monitoring | No statistically significant differences on practitioner adherence through reassessment of symptoms at 3 months, adjustment of medications, and mental health referral | Insufficient for practitioner adherence (reassessment of symptoms) at 3 months, adjustment of medications, and referral | Medium study limitations, imprecise results (CIs cross the line of no difference)
Adding diagnosis and treatment guidelines to a computer decision support system Carroll et al., 2013^89^ | Cluster RCT, 84 patients | General mental health problem (children who receive home-based mental health treatment) Mean age = 15 years | Computer decision support plus electronic health record (EHR) that included diagnosis and treatment guidelines vs. computer decision support plus EHR only | Educational meetings or materials Patient-reported data Reminders Quality monitoring | Visit to a mental health specialist calculated OR: 2.195; 95% CI, 0.909 to 5.303; p=0.081; reported p-value in study=0.054 | Insufficient for service utilization | Medium study limitations, imprecise results (CIs cross the line of no difference)
Providing practitioner access to practice guidelines via an Internet portal Epstein et al., 2011^85^ | Cluster RCT, 746 patients | Attention deficit hyperactivity disorder (ADHD) Ages 6 to 12 years | Internet portal providing practitioner access to practice guidelines vs. wait-list control | Educational meetings or materials Patient-reported data Audit and feedback Reminders Quality monitoring | Strategy appeared to improve 4 of 5 examined outcomes that measured practitioner protocol adherence and program model fidelity outcomes ( mean change in proportion of patients who received targeted, evidence-based ADHD care outcomes between groups ranged from 16.6 to −50), but estimates were very imprecise, with large CIs | Low for benefit for practitioner protocol adherence and program model fidelity | Medium study limitations, imprecise (wide CIs)
Collaborative consultation to promote the use of titration trials and periodic monitoring during medication management Epstein et al., 2007^86^ | Cluster RCT, 38 practitioners, 144 patients | ADHD Mean age = 7 years | Collaborative consultation treatment service to promote the use of titration trials and periodic monitoring during medication management vs. control | Audit and feedback Multidisciplinary team | Practitioner adherence/fidelity as measured by use of titration trials β=−0.283; SE, 0.09; p<0.01 and by use of medication monitoring trials: p=NS, details NR | Insufficient for practitioner adherence and fidelity | High study limitations, imprecise results (small sample size)
Collaborative consultation to promote the use of titration trials and periodic monitoring during medication management Epstein et al., 2007^86^ | Cluster RCT, 38 practitioners, 144 patients | ADHD Mean age = 7 years | Collaborative consultation treatment service to promote the use of titration trials and periodic monitoring during medication management vs. control | Audit and feedback Multidisciplinary team | Lower odds with overlapping confidence intervals of practitioner citing obstacles to implementation of EBP in 6 of 8 measures (2 reached statistical significance) | Insufficient for practitioner competence/skills | High study limitations, imprecise results (small sample size)
Collaborative consultation to promote the use of titration trials and periodic monitoring during medication management Epstein et al., 2007^86^ | Cluster RCT, 38 practitioners, 144 patients | ADHD Mean age = 7 years | Collaborative consultation treatment service to promote the use of titration trials and periodic monitoring during medication management vs. control | Audit and feedback Multidisciplinary team | F score for decrease in combined parent and teacher ratings of ADHD symptoms for group × time interaction: F_2, 144_ = 0.44, p=0.65 | Insufficient for patient change in mental health symptoms | High study limitations, imprecise results (small sample size)
Paying practitioners for performance in successfully implementing an EBP Garner et al., 2012^84^ | Cluster RCT, 49 therapists, 936 patients | Substance use disorders Mean age = 16 years | Paying practitioners for performance in successfully delivering an EBP intervention vs. implementation as usual | Provider incentives | Therapists in the P4P group were over twice as likely to demonstrate implementation competence compared with IAU therapists (Event Rate Ratio, 2.24; 95% CI, 1.12 to 4.48) | Moderate for benefit for practitioner competence | Medium study limitations, precise results
Paying practitioners for performance in successfully implementing an EBP Garner et al., 2012^84^ | Cluster RCT, 49 therapists, 936 patients | Substance use disorders Mean age = 16 years | Paying practitioners for performance in successfully delivering an EBP intervention vs. implementation as usual | Provider incentives | Patients in the P4P condition were more than 5 times as likely to meet target implementation standards (i.e., to receive specific numbers of treatment procedures and sessions) than IAU patients (OR, 5.19; 95% CI, 1.53 to 17.62) | Low for benefit for practitioner adherence and program fidelity | Medium study limitations, imprecise results (wide CIs)
Paying practitioners for performance in successfully implementing an EBP Garner et al., 2012^84^ | Cluster RCT, 49 therapists, 936 patients | Substance use disorders Mean age = 16 years | Paying practitioners for performance in successfully delivering an EBP intervention vs. implementation as usual | Provider incentives | No statistically significant differences between groups OR, 0.68; 95% CI, 0.35 to 1.33 | Low for no benefit for patient change in mental health symptoms | Medium study limitations, precise results
Program to improve organizational climate and culture Glisson et al., 2010^14 a^ | Two-stage RCT, 596 youth, 257 therapists | Externalizing behaviors (youth referred to juvenile court with behavioral or psychiatric symptoms that require intervention) Ages 9–17 years | Program to improve organizational climate and culture vs. u_s_ual care | Educational meetings or materials Educational outreach visits Provider satisfaction initiative Audit and feedback | Details NR but does not demonstrate improvements in any measure of adherence by strategy group for any ARC vs. no ARC comparison | Low for no benefit for practitioner adherence | Medium study limitations, precise results
Program to improve organizational climate and culture Glisson et al., 2010^14 a^ | Two-stage RCT, 596 youth, 257 therapists | Externalizing behaviors (youth referred to juvenile court with behavioral or psychiatric symptoms that require intervention) Ages 9–17 years | Program to improve organizational climate and culture vs. u_s_ual care | Educational meetings or materials Educational outreach visits Provider satisfaction initiative Audit and feedback | Difference in out-of-home placements and child behavior problem scores at 18 months between ARC-only and usual-care groups did not meet statistical significance (p=0.05). | Low for no benefit for patient change in mental health symptoms at 18 months | Medium study limitations, precise results (small sample size), CIs likely overlap
Program to improve organizational climate and culture Glisson et al., 2012^67,68^ | Cluster RCT 352 caregivers of youth ages 5–18 in 18 programs | General mental health problems Ages 8–24 years | Program to improve organizational climate and culture vs. usual care | Educational meetings or materials Educational outreach visits Provider satisfaction initiative Audit and feedback | Trends toward improvement in all domains; nonoverlapping CI for some domains showing significant improvements (p<0.05) for ARC group vs. usual care | Low for benefit for practitioner satisfaction | Medium study limitations, imprecise results (small study sample)
Program to improve organizational climate and culture Glisson et al., 2012^67,68^ | Cluster RCT 352 caregivers of youth ages 5–18 in 18 programs | General mental health problems Ages 8–24 years | Program to improve organizational climate and culture vs. usual care | Educational meetings or materials Educational outreach visits Provider satisfaction initiative Audit and feedback | Lower problem behavior scores for youth in the ARC group compared with those in the control group during first 6 months of followup (following 18-month organizational implementation), effect size=0.29 | Low for benefit for patient change in mental health symptoms | Medium study limitations, imprecise results (small study sample)
Training nurses to educate parents about EBPs Gully et al., 2008^66^ | Interrupted time series in Study 1, 172 parents or caregivers; RCT in Study 2, 51 parents or caregivers | General mental health symptoms (children suspected of abuse during forensic medical examinations) Ages 2–17 years | Protocol to train nurses to educate parents about EBPs vs. typical services | Educational meetings or materials Educational outreach visits Patient-reported data | Strategy improved parent ratings of access to care (mean difference between groups ranged from 0.08 to 2.1 points in Study 1 and 0.6 to 1.9 in Study 2) (scale=1–5) | Low for benefit for patient access to care | High risk of bias, consistent, direct, precise results
Training nurses to educate parents about EBPs Gully et al., 2008^66^ | Interrupted time series in Study 1, 172 parents or caregivers; RCT in Study 2, 51 parents or caregivers | General mental health symptoms (children suspected of abuse during forensic medical examinations) Ages 2–17 years | Protocol to train nurses to educate parents about EBPs vs. typical services | Educational meetings or materials Educational outreach visits Patient-reported data | Improved parent ratings of satisfaction of care by a mean of 0.4 in Study 1 and 0.9 in Study 2 (scale=1–5) | Low for benefit for patient satisfaction | High risk of bias, consistent, direct, precise results
Training nurses to educate parents about EBPs Gully et al., 2008^66^ | Interrupted time series in Study 1, 172 parents or caregivers; RCT in Study 2, 51 parents or caregivers | General mental health symptoms (children suspected of abuse during forensic medical examinations) Ages 2–17 years | Protocol to train nurses to educate parents about EBPs vs. typical services | Educational meetings or materials Educational outreach visits Patient-reported data | Improved parent ratings of treatment engagement by a mean of 0.9 in Study 1 and 2.5 in Study 2 (scale=1–5) | Low for benefit for treatment engagement | High risk of bias, consistent, direct, precise results
Training nurses to educate parents about EBPs Gully et al., 2008^66^ | Interrupted time series in Study 1, 172 parents or caregivers; RCT in Study 2, 51 parents or caregivers | General mental health symptoms (children suspected of abuse during forensic medical examinations) Ages 2–17 years | Protocol to train nurses to educate parents about EBPs vs. typical services | Educational meetings or materials Educational outreach visits Patient-reported data | Improved parent ratings of therapeutic alliance by a mean of 0.4 in Study 1 and 0.9 in Study 2 (scale=1–5) | Low for benefit for therapeutic alliance | High risk of bias, consistent, direct, precise results
Adding intensive quality assurance to implement an EBP Henggeler et al., 2008^93^ | Controlled clinical trial, 30 practitioners, N of caregiver and patient reports and monthly data points NR | Substance use disorders (adolescents with marijuana abuse) Ages 12–17 years | Intensive Quality Assurance (IQA) system vs. workshop only to implement an EBP intervention | Quality monitoring | Study does not provide sufficient detail to judge magnitude of effect on practitioner adherence to cognitive behavioral therapy and monitoring techniques | Insufficient for practitioner adherence and fidelity | High study limitations, imprecise results
Adding computer-assisted training with or without ongoing supervision and coaching to practitioners implementing an EBP Henggeler et al., 2013^91^ | Cluster RCT; 161 therapists | Substance use disorders Ages 12–17 years | Workshop and resources (WSR) vs. WSR and computer-assisted training (WSR+CAT) to implement an EBP intervention | Educational meetings or materials | No statistically significant difference between groups for use, knowledge, and adherence | Insufficient for additional benefit of WSR+CAT vs. WSR comparison group for practitioner use, knowledge, and adherence | Medium study limitations, imprecise, small sample sizes, cannot determine whether CIs cross line of no difference
Adding computer-assisted training with or without ongoing supervision and coaching to practitioners implementing an EBP Henggeler et al., 2013^91^ | Cluster RCT; 161 therapists | Substance use disorders Ages 12–17 years | WSR vs. WSR+CAT and supervisory support (WSR+CAT+SS) to implement an EBP intervention | Educational meetings or materials Educational outreach visits | No statistically significant difference between groups for use, knowledge, and adherence | Insufficient for additional benefit of WSR+CAT+SS vs. WSR comparison group on practitioner use, knowledge, and adherence competence/skills | Medium study limitations, imprecise, small sample sizes, cannot determine if CIs cross line of no difference
Training practitioners to identify and refer cases Lester et al., 2009^90^ | Cluster RCT; 110 practices, 179 patients | Psychosis (adolescents and adults with first-episode psychosis) Ages 14–30 years | Professional training to identify and refer cases vs. usual care | Educational meetings or materials Educational outreach visits | Relative risk (RR) of referral to early intervention after first contact: 1.20, 95% CI, 0.74 to 1.95, p=0.48 | Insufficient for patient access to care | High study limitations, imprecise results
Training practitioners to identify and refer cases Lester et al., 2009^90^ | Cluster RCT; 110 practices, 179 patients | Psychosis (adolescents and adults with first-episode psychosis) Ages 14–30 years | Professional training to identify and refer cases vs. usual care | Educational meetings or materials Educational outreach visits | No statistically significant differences between groups in changes in patient mental health status | Insufficient for patient change in mental health symptoms | High study limitations, imprecise results
Training practitioners to identify and refer cases Lester et al., 2009^90^ | Cluster RCT; 110 practices, 179 patients | Psychosis (adolescents and adults with first-episode psychosis) Ages 14–30 years | Professional training to identify and refer cases vs. usual care | Educational meetings or materials Educational outreach visits | Patients in the professional training group averaged 223.8 fewer days for time from the first decision to seek care to the point of referral to an early intervention service than patients in the control group | Low for benefit for service utilization | High study limitations, imprecise results
Training practitioners to identify and refer cases Lester et al., 2009^90^ | Cluster RCT; 110 practices, 179 patients | Psychosis (adolescents and adults with first-episode psychosis) Ages 14–30 years | Professional training to identify and refer cases vs. usual care | Educational meetings or materials Educational outreach visits | No adverse events were reported, no significant between-group differences for false-positive referral rates from primary care | Insufficient for patient harms | High study limitations, unknown precision
Training practitioners with and without feedback to implement an EBP Lochman et al.,2009^88^ | Cluster RCT, 511 patients | Externalizing behaviors (children at risk for aggressive behaviors) Ages: third-grade students | Professional training plus feedback (CP-TF) to implement an EBP intervention vs. control | Educational meetings or materials Audit and feedback | Students in CP-TF group had fewer behavioral problems as rated by teachers (beta=−0.41, SE=0.16, p=0.01) than controls but no significant difference in teacher ratings or parent ratings | Low for no benefit for changes in mental health status | Medium study limitations, precise results
Training practitioners with and without feedback to implement an EBP Lochman et al.,2009^88^ | Cluster RCT, 511 patients | Externalizing behaviors (children at risk for aggressive behaviors) Ages: third-grade students | Professional training plus feedback (CP-TF) to implement an EBP intervention vs. control | Educational meetings or materials Audit and feedback | Students in CP-TF group had fewer minor assaults (e.g., hitting or threatening to hit a parent, school staff, or student) as reported by the child (beta=−0.25, SE=0.12, p=0.03) and social/academic competence as reported by the teacher (beta=0.35, SE=0.13, p=0.01) compared with controls | Low for benefit for change in socialization skills and behaviors | Medium study limitations, precise results
Training practitioners with and without feedback to implement an EBP Lochman et al.,2009^88^ | Cluster RCT, 511 patients | Externalizing behaviors (children at risk for aggressive behaviors) Ages: third-grade students | Professional training only to implement an EBP intervention (CF-BT) vs. control | Educational meetings or materials | No significant difference in behavioral problems as rated by teachers or parents or student-reported assaults between CP-BT and control groups | Low for no benefit for changes in mental health status | Medium study limitations, precise results
Training practitioners with and without feedback to implement an EBP Lochman et al.,2009^88^ | Cluster RCT, 511 patients | Externalizing behaviors (children at risk for aggressive behaviors) Ages: third-grade students | Professional training only to implement an EBP intervention (CF-BT) vs. control | Educational meetings or materials | No significant differences in social/academic competence as reported by the teacher, nor were any significant differences found between groups on social skills as rated by parents. | Low for no benefit for change in socialization skills and behaviors | Medium study limitations, precise results
Training practitioners to use a patient medication monitoring program Ronsley et al., 2012^95^ | Interrupted time series Health care practitioners for 2,376 patients | Psychosis Ages <19 years (mean age = 11) | Patient medication monitoring training program for practitioners vs. usual care | Educational meetings or materials Educational outreach visits Reminders | 38.3% of patients had a metabolic monitoring and documentation tool (MMT) in the charts after program implementation; drop in the prevalence of second-generation antipsychotic prescribing from 15.4% in the pre-metabolic monitoring training program (MMTP) period to 6.4% in the post-MMTP period (p<0.001) | Low for benefit for practitioner adherence | High study limitations, precise outcomes
Training practitioners to use a patient medication monitoring program Ronsley et al., 2012^95^ | Interrupted time series Health care practitioners for 2,376 patients | Psychosis Ages <19 years (mean age = 11) | Patient medication monitoring training program for practitioners vs. usual care | Educational meetings or materials Educational outreach visits Reminders | Increased metabolic monitoring over time (level of change varied by type of monitoring) | Low for benefit for patient service utilization | High study limitations, precise outcomes
Embedding a behavioral health care practitioner in primary care Sterling et al., 2015,^92^ | Cluster RCT, 47 pediatricians with 1,871 eligible patients | Varied conditions among children attending a pediatric primary care office Ages 12–18 | Pediatrician only vs. embedded behavioral health care practitioner (BHCP) implementation of an EBP | Multidisciplinary teams | No significant differences in substance use assessment between study arms (aOR, 0.93; 95% CI, 0.72 to 1.21); patients in the embedded BHCP group more likely than those in the pediatrician-only group to receive brief intervention (aOR=1.74, 95%CI, 1.31 to 2.31); patients in the BHCP group less likely to receive a referral to a specialist than patients in the primary-care-^b^ only group (aOR=0.58, 95%CI, 0.43 to 0.78) | Low for no benefit for practitioner adherence (2 of 3 adherence outcomes were statistically significant) | Medium study limitations, unable to assess precision
Colocating an EBP program in primary care Wildman et al., 2009^94^ | Controlled clinical trial, 4 pediatric practices, 20,917 children with primary care visit | Externalizing behavior problems Ages 2–12 years | Colocation of a behavioral health EBP parenting program in primary care vs. enhanced referral to a behavioral health EBP parenting program in a location external to the practice. | Changing the scope of benefits | OR for attending first EBP visit, 3.10; 95% CI, 1.63 to 5.89 | Low for benefit for patient access to care | High study limitations, precise results
Colocating an EBP program in primary care Wildman et al., 2009^94^ | Controlled clinical trial, 4 pediatric practices, 20,917 children with primary care visit | Externalizing behavior problems Ages 2–12 years | Colocation of a behavioral health EBP parenting program in primary care vs. enhanced referral to a behavioral health EBP parenting program in a location external to the practice. | Changing the scope of benefits | No improvement in mean number of sessions attended (calculated mean difference: −1.01; 95% CI, −2.60 to 0.58) | Insufficient for patient service utilization | High study limitations, precise results

a Four study groups were examined: ARC+MST, ARC only, MST only, and usual care. Comparisons were ARC only vs. usual care or any ARC (combined ARC+MST and ARC only) vs. no ARC (combined MST and usual care), as noted.

b Fewer referrals seen as improvement because this outcome indicates that the practitioner was able to give brief intervention without referral to behavioral health specialists.

ADHD = attention deficit hyperactivity disorder; aOR = adjusted odds ratio; ARC = Availability, Responsiveness and Continuity; CBT = cognitive behavioral therapy; CI = confidence interval; CP-TF = Coping Power training plus feedback; EBP = evidence-based practice, EHR = electronic health record; IAU = implementation as usual; IQA = Intensive Quality Assurance; MMT = metabolic monitoring program; MMTP = metabolic monitoring training program; MST = multisystemic therapy; N = number; NR = not reported; NS = not significant; OR = odds ratio; p = probability; RCT = randomized controlled trial; RR = relative risk; P4P = pay for performance; SE = standard error; WSR = workshop plus resources; WSR+CAT = workshop plus resources plus computer-assisted training; WSR+CAT+SS = workshop plus resources plus computer-assisted training plus supervisory support.

A majority of strategies had at least some evidence of effectiveness. Twelve studies demonstrated benefit; of these 11 had at least 1 outcome rated as low for benefit, and 1 study had a single outcome rated as moderate for benefit.

The strongest evidence in the review comes from a study of pay for performance. Therapists in the pay-for-performance group were more than twice as likely to demonstrate implementation competence as were the implementation-as-usual therapists (moderate strength of evidence of benefit).^84^ Other outcomes for which we found evidence of benefit (low strength of evidence of benefit) included:

1. Improved practitioner adherence to evidence-based practice (EBPs) or guidelines from training practitioners to monitor metabolic markers,^95^ providing computer decision support plus electronic health records (EHRs) that included diagnosis and treatment guidelines,^89^ and offering an Internet portal for practitioner access to practice guidelines;^85^
2. Improved practitioner morale, engagement, and stress from a program to improve organizational climate and culture;^67^
3. Improved patient access to care, parent satisfaction, treatment engagement, and therapeutic alliance from training nurses to educate parents about EBPs;^66^
4. Improved patient functional status from weekly feedback on patient symptoms and functioning to practitioners;^13^ and
5. Improved service utilization from training practitioners about monitoring medications^95^ and appropriately identifying and referring patients.^90^

Only four strategies (1 one study each) consistently provided insufficient or evidence of no benefit across all reported outcomes. These included:

1. A strategy testing augmented active learning versus computerized routine learning versus routine practitioner workshop to implement an EBP,^87^
2. A collaborative consultation treatment service to promote the use of titration trials and periodic monitoring during medication management versus control,^86^
3. An Intensive Quality Assurance system versus a workshop to implement an EBP intervention,^93^ and
4. Use of additional computerized-assisted training or computerized training plus supervisory support to implement an EBP versus using a workshop and resources only.^91^

The studies varied with respect to the numbers and types of active components; i.e., we observed considerable differences in components in treatment group strategies and comparison group strategies. In some studies, the treatment group contained several components and the comparison group contained none of those components. In other studies, both the treatment and comparison groups tested strategies with multiple components, with varying numbers of differences in components across arms. Because both arms often received active interventions, the Hawthorne effect may explain lack of effectiveness. We did not find any consistent patterns of effectiveness involving the number of active components. That is, we did not find that studies that employed strategies with a single active component had any better or any worse effect on outcomes than those that employed multiple active components.

Additional heterogeneity arose from several other sources and precluded any quantitative synthesis of our findings. Except for two studies reported in one publication^66^ and two trials (three publications) reporting variants of a similar intervention,^14,67,68^ none of the other studies tested similar strategies. The outcomes of the studies varied widely. Similarly, settings differed greatly (community-based hospitals and clinics, general practice and primary care, home-based mental health systems, schools). Finally, the targets of each strategy, such as practitioners, practices, or systems, also differed considerably.

The absence of evidence on several factors of interest further limited our conclusions. We found no evidence of studies examining several intermediate outcomes, particularly system-level intermediate outcomes. We also identified no studies that measured final patient health outcomes such as co-occurring conditions or mortality. We also found no evidence of strategies testing several components of the EPOC taxonomy, including any regulatory components, and little evidence on strategies with financial components.

Of the 17 studies in our review, one study had low risk of bias and three had medium risk of bias. We rated seven as having unclear risk of bias and six as having high risk of bias. Various issues with study design, attrition, and incomplete information reported by study authors precluded most of these studies from having a low or medium risk of bias.

The uncertain or high risk of bias of most of these studies affected the overall strength of evidence grades, as did the fact that we mainly had only single studies for each strategy examined.

### Key Question 2 Harms Associated With Strategies To Improve Mental Health Care for Children and Adolescents

Only one study evaluated the harms associated with strategies to improve mental health care for children and adolescents (Table 27). We graded the strength of evidence as insufficient for harms associated with a professional training strategy to improve access to early intervention for adolescents and young adults with psychosis. The study reported no adverse events or between-group differences in false-positive referrals from primary care to early-intervention services. Of note, no other studies reported on any of the harms we identified a priori for patients, providers, or organizations (Table 28).

Table 27 Summary of evidence of harms associated with strategies to improve mental health care among children and adolescents (Key Question 2)

Outcome Category, Outcome Number of Studies; n of Individuals Results | Active Strategy Component | Strength of Evidence (Domain-Specific Ratings)
Patient: Adverse events 1 RCT; 110 practices, 79 patients^90^ No adverse events reported. | Educational meetings, local consensus process, educational outreach visits, marketing | Insufficient for professional training to identify and refer cases vs. treatment as usual (high study limitations, imprecise results)
Patient: False-positive referrals 1 RCT; 110 practices, 79 patients^90^ No between-group differences in false-positive referrals from primary care to early-intervention services | Educational meetings, local consensus process, educational outreach visits, marketing | Insufficient for professional training to identify and refer cases vs. treatment as usual (high study limitations, imprecise results)

RCT=randomized controlled trial; vs. = versus.

Table 28 Evidence about harms (Key Question 2)

A Priori Harms | Evidence Identified in the Review
Patient
Lower treatment engagement or increased dropouts (or both) | None
Negative impact on therapeutic relationship | None
Side effects of an evidence-based practice incorporated into strategy (e.g., adverse events, suicidality) | 1 study (adverse events, false-positive referrals from primary care to early-intervention services)
Patient dissatisfaction with care | None
Provider
Burnout or exhaustion | None
Turnover | None
Resistance to strategy | None
Organization
Cost | None
Failure to sustain evidence-based practice | None
Resistance to change | None
Resistance to strategy | None

### Key Question 3 Moderators of the Effectiveness of Strategies To Improve Mental Health Care for Children and Adolescents

Overall, we found evidence on four strategies that examined moderators of the effectiveness of strategies to improve mental health care for children and adolescents (Table 29). Three examined whether training intensity influenced the degree of effectiveness; of these, two strategies were graded as having insufficient strength of evidence. The third strategy had low strength of evidence for benefit for patient intermediate outcomes (access to care) and patient health and service utilization outcomes (change in mental health status).

Table 29 Moderators of the effectiveness of strategies to improve mental health care among children and adolescents (Key Question 3)

Moderator Outcome Category, Outcome Number of Studies; n of Individuals Results | Active Strategy Component | Strength of Evidence (Domain-Specific Ratings)
Training intensity Patient: Patient access to care 1 RCT; 110 practices, 79 patients^88^ More intensive training improved access to care ratings (sessions scheduled) for both children and parents. | Professional training plus feedback: Educational training, educational meetings, educational outreach visits, marketing, and online access and project coordinator Professional training only: Educational meetings and marketing | Low for benefit for moderating effect of training intensity on professional training plus feedback to implement an EBP intervention vs. professional training only to implement an EBP intervention vs. control (medium study limitations, precise results)
Training intensity Patient: Treatment engagement 1 RCT; 110 practices, 79 patients^88^ Groups did not differ significantly. | Professional training plus feedback: Educational training, educational meetings, educational outreach visits, marketing, and online access and project coordinator Professional training only: Educational meetings and marketing | Low for no benefit for moderating effect of training intensity on professional training plus feedback to implement an EBP intervention vs. professional training only to implement an EBP intervention vs. control (medium study limitations, precise results)
Training intensity Practitioner: Protocol adherence/program fidelity 1 RCT; 110 practices, 79 patients^88^ Groups did not differ significantly. | Professional training plus feedback: Educational training, educational meetings, educational outreach visits, marketing, and online access and project coordinator Professional training only: Educational meetings and marketing | Low for no benefit for moderating effect of training intensity on professional training plus feedback to implement an EBP intervention vs. professional training only to implement an EBP intervention vs. control (medium study limitations, precise results)
Training intensity Patient health and service utilization: Mental health symptoms 1 RCT; 511 patients^88^ More intensive training was associated with greater improvements in mental health symptoms. | Professional training plus feedback: Educational training, educational meetings, educational outreach visits, marketing, and online access and project coordinator Professional training only: Educational meetings and marketing | Low for benefit for moderating effect of training intensity on professional training plus feedback to implement an EBP intervention vs. professional training only to implement an EBP intervention vs. control (medium study limitations, precise results)
Training intensity Patient health and service utilization: Mental health symptoms 1 RCT; N of practitioners unclear^13^ Effect sizes for child and parent ratings of symptoms improved significantly in the more intensive training group. | Weekly feedback to providers and cumulative 90-day feedback vs. 90-day feedback only | Insufficient for moderating effect of training intensity on weekly and cumulative 90-day feedback vs. cumulative 90-day feedback only on patient symptoms and functioning to practitioners (high study limitations, unknown precision)
Training intensity Patient health and service utilization: Mental health symptoms 1 RCT; 197 practitioners in 26 programs^86^ Reduction in mental health symptoms in the compliers group was significantly greater than that seen in the control group (t(114)=−2.72, p=0.008, effect size=0.25) and in the noncomplier group (t(57)=−3.568, p=0.001, effect size=0.47). | Audit and feedback and clinical multidisciplinary teams | Insufficient for moderating effect of training intensity on collaborative consultation treatment service to promote the use of titration trials and periodic monitoring during medication management vs. control (high study limitations, imprecise results [small sample size])
Training intensity Patient health and service utilization: Functional status 1 RCT; 49 therapists and 936 patients^84^ Fidelity to EBP (meeting target A-CRA) had no effect on the association between treatment group and patient remission status. | Provider incentives | Low for no benefit for moderating effect of fidelity to EBPs on paying practitioners for performance in successfully delivering an EBP intervention vs. IAU (medium study limitations, precise results)
Training intensity Patient health and service utilization: Functional status 1 RCT; N of practitioners unclear^13^ Effect sizes for child and parent ratings of functional status improved significantly in the more intensive training group | Weekly feedback to providers and cumulative 90-day feedback versus 90-day feedback only | Insufficient for moderating effect of training intensity on weekly and cumulative 90-day feedback vs. cumulative 90-day feedback only on patient symptoms and functioning to practitioners (high study limitations, unknown precision)

A-CRA = Adolescent Community Reinforcement Approach; EBP = evidence-based practice; IAU = implementation as usual; N or n = number; NA = not available; RCT = randomized controlled trial.

Therapists receiving more intensive training had greater improvements in ratings of patient access to care (sessions scheduled) for both children and parents and greater improvements in patients’ mental health symptoms (i.e., less externalizing behaviors) than therapists receiving less intensive training. We were unable to combine the findings from these studies because of the heterogeneity in the strategies being tested.

A fourth study examined the moderating effects of fidelity to the EBP (meeting target Adolescent Community Reinforcement Approach [A-CRA]) used as part of the strategy. We graded the strength of evidence as low for no benefit for moderating the effect of the strategy, patient health outcome, and patient remission status.

We did not find studies that examined most of our previously-specified list of moderators such as patient characteristics, intervention characteristics other than training intensity, factors of the outer or inner setting/organizational factors, characteristics of involved individuals, process characteristics other than fidelity to the training, or other moderators such as length of followup (Table 30).

Table 30 Evidence about moderators

A Priori Harms Outcomes | Evidence Identified in the Review
Patient characteristics (age, gender, cognitive functioning, diagnosis/severity of mental health problem, comorbid conditions, cotreatments, race/ethnicity) | None
Intervention characteristics (complexity, manualized or not, intensity/frequency/duration, adjustment of intervention to fit context) | 3 studies (intensity only)
Outer setting (external policy, incentives, availability of alternative care systems) | None
Inner setting/organizational factors (type of outpatient setting, structure/size, culture, implementation climate, readiness of organization for implementation) | None
Characteristics of involved individuals (provider type, knowledge, beliefs, self-efficacy, leadership, education, certifications, accreditation policies, standards, and years of practice) | None
Process characteristics (fidelity to the planned strategy, fidelity to the EBP, use of champions or supervision/oversight) | 1 study (fidelity to the EBP only)
Other: Length of followup | None

EBP = evidence-based practice.

## Finding Solutions for Success

We employed qualitative comparative analysis (QCA) to understand what intervention components were present in successful strategies. We found seven solutions or recipes (with perfect consistency (i.e., each solution always resulted in success) that accounted for 10 of the 12 cases that demonstrated either improvements in a majority of practitioner-, system-, or patient-level intermediate outcomes tested or at least low strength of evidence for benefit of at least one patient health or service utilization outcome (i.e., 83% total coverage).

The seven solutions included: (1) a financial incentive, (2) a change in the scope of patient benefits, (3) use of a clinical multidisciplinary team without an audit and feedback component, (4) use of educational materials or meetings plus educational outreach and reminders, (5) use of educational materials or meetings plus patient-mediated interventions plus reminders, 6) use of educational materials or meetings plus patient-mediated interventions plus educational outreach, or (7) use of audit and feedback without an educational outreach component and without a clinical multidisciplinary team component. This last solution is unusual because the absence of components are necessary parts of the recipe for success. We cannot explain why the absence of educational outreach components are part of the seventh solution.

Closer examination of each of these solutions sheds light on successful strategies. For solution 1 above, the Garner et al. study indicated that provider financial incentives, i.e., paying practitioners for successfully implementing an EBP, improved outcomes.^84^ The Wildman et al. study (solution 2) assigned primary care pediatric practices to co-located behavioral parent training to make referrals to behavioral health care providers easier.^94^ Looking at solutions 3 and 7 together (four studies), we found that strategies that contained audit and feedback or used clinical multidisciplinary teams, but that did not have both components, had beneficial outcomes, although the combination of audit and feedback plus no use of clinical multidisciplinary teams also required not having an educational outreach component). The single study in solution 3 (clinical multidisciplinary teams and no audit and feedback), by Sterling and colleagues,^92^ determined that using an embedded behavioral health care practitioner (BHCP) to implement an EBP led to better patient adherence outcomes than using only a primary care provider to implement an EBP. The three studies in solution 7 consisted of having an audit and feedback component, but no clinical multidisciplinary teams and no educational outreach. The Bickman study^13^ examined the addition of weekly feedback on patient symptoms and functioning to usual cumulative 90-day feedback received by practitioners; the Lochman study^88^ tested the use of professional training plus feedback to implement an EBP intervention; and the 2011 Epstein study^85^ examined the use of an Internet portal to provide practitioner access to practice guidelines. Solutions 4, 5, and 6 revealed that a mix of educational materials or meetings plus at least two other professional components (including either educational outreach, patient-mediated interventions, or reminders) produced beneficial outcomes.

## Findings in Relationship to What Is Already Known

This systematic review contributes to the literature on QI, implementation, and dissemination strategies targeting systems and organizations or practitioners of mental health care to children and adolescents. Our review updates the literature while simultaneously targeting especially critical aspects of mental health issues for children and adolescents.

First, we included studies published through January 14, 2016. Two recent systematic reviews had already addressed this topic but stopped short of 2012. Barwick et al. (2012)^38^ examined 12 studies of knowledge translation interventions and strategies related to the delivery, organization, or receipt of child and youth mental health services that had been published between 2001 and 2009.^38^ All 12 studies reported statistically significant changes in behaviors from knowledge translation, although the quality of studies was limited by insufficient or unclear reporting and small sample sizes. The authors also noted that the behaviors were largely self-reported rather than observed, and several studies involved simulated situations rather than real-world settings. Novins et al. in 2013 examined studies of dissemination and implementation EBPs for managing patients with mental health or substance abuse problems that had been published between 1991 and December 2011.^39^ These authors reported that a majority of the included articles were observational rather than experimental and that the strongest empirical evidence existed for fidelity monitoring and supervision. Both prior reviews called for additional studies on these topics because of the dearth of sufficient evidence in this field.

Second, our inclusion criteria were narrower than those in the earlier reviews. Both previous reviews had included studies that focused on teacher training for behavior change; by contrast, we focused primarily on mental health practitioners. In addition, our review focused on strategies for a relatively narrower mental health population. For example, we excluded studies about children with developmental disabilities, including autism, because of the heterogeneity in strategies used and types of systems involved in their care; the Barwick et al. review had included studies in which the primary mental health population had been diagnosed with autism. We also examined only studies of youth with mental health symptoms; we excluded prevention studies focused on populations not currently experiencing mental health symptoms. Novins et al. had included several preventative studies such as those in a child welfare setting, where presumably many of the children were at risk for developing mental health symptoms. Barwick et al. excluded studies of children with substance abuse; by contrast, like Novins et al., we included studies of youth with substance abuse as the primary diagnosis. The age range of the targeted mental health populations also differed between this review and prior reviews. Barwick et al. had defined youth more broadly, including studies with youth up to age 24 years. Our study focused on studies examining samples primarily comprising children through 18 years of age.

With respect to study design, of the 17 studies identified in our review, 13 were RCTs. Two studies were clinical controlled trials; one was an interrupted time series design; and one was cohort study with a historical control. Barwick et al. also had included studies with quasi-experimental designs (n=4); Novins et al.’s review was even broader in scope, including descriptive and qualitative studies.

Third, our review included a broader range of strategies. We reviewed (a) implementation strategies used to adopt and integrate EBPs into routine care and (b) dissemination strategies used to make evidence more easily available through increasing access to EBPs or raising people’s motivation or ability to use and apply EBPs. We also attempted to include only studies for which we could distinguish the effects of the strategy of interest from the underlying EBP. In addition, we also examined QI strategies, which had not been explicitly included in the prior systematic reviews. Our study also highlighted the overlap between the definition of QI and the concepts used in studies of implementation or dissemination (or both).

Fourth, unlike other reviews, we attempted to understand the moderating effects of different variables on effectiveness or harms. Moderators of interest included the following: (a) patient characteristics such as age, gender, race, cognitive ability, diagnosis, severity, coexisting conditions and cointerventions; and (b) intervention characteristics, such as complexity, manualized or not, intensity, frequency, and duration. Little evidence is available about the influence of these types of sociodemographic, health, or program factors, which emphasized the need for future studies to examine such variables explicitly.

The two prior reviews and our review each concluded that some evidence of efficacy of these strategies can be found, however, the field is new and additional research is needed to help translate research into practice. Nevertheless, the field was and remains too new to draw definitive conclusions, and all three reviews agree that additional research is needed. Such research should include well-designed studies with better and more complete reporting of methods.

Numerous well-designed clinical trials of mental health interventions for youth exist, of course. Nonetheless, knowledge of how to best implement and disseminate these interventions remains limited for at least three principal reasons. One is simply the limited number of studies of strategies conducted to date; another is the high risk of bias in the studies that we identified and included; and the third is the overall weak strength of evidence, particularly for benefits.

## Applicability

### Population

The studies in this review focused on strategies to improve care for children with mental health and substance abuse problems. Investigations involving children with developmental disorders, such as autism and learning disabilities, were excluded because such patients are often treated through different service systems than child mental health. Most studies (13) involved mental health disorders; 4 additional studies focused on substance use disorders. Ages of patients in these studies ranged mainly from 2 years to 18 years. In addition, two studies that focused on psychosis also included young adults because this is the age of first incidence of psychosis in most cases. Because the majority of studies employed cluster randomization techniques, they generally did not restrict eligible patients to a narrow spectrum of disorder; patients are generally representative of larger populations.

Providers of the target strategies were clinicians with various types of health professional training (e.g., psychiatrists, psychologists, and nurses). Studies that focused on strategies delivered by professionals outside the health field, such as teachers, were excluded. Providers and health care systems featured in the studies included in this review were representative of those delivering care in the community: all studies describe community practitioners, primary care clinics, or public-sector health care providers.

In sum, these findings apply to professionally trained health practitioners who treat children and adolescents with mental health or substance use disorders (or both).

### Interventions and Comparators

This review included QI, implementation, and dissemination strategies delivered by practitioners in typical outpatient settings. All strategies reviewed were aimed at health practitioners (e.g., training them) or at settings or systems (e.g., implementing a new medical management system). Studies generally adopted a multipronged effort, often requiring changes in behavior or process for many different participants in the health care delivery process. Although the time commitment and intensity of these strategies varied substantially, the nature of this review is such that all included strategies require at least some degree of structural change. These findings may best apply to systems of care that have some degree of internal control to be able to adopt and enforce change.

In over half the studies, investigators described the comparison arm as care as usual and did not report any specific strategies employed in the comparison arms. The other studies compared a more intense intervention with a less intense intervention. Because “care as usual” can vary substantially, we cannot comment on whether comparisons (whether characterized as “care as usual” or a “less intense intervention”) fully represent the array of current practice.

Most authors did not report or respond to queries about the availability of their materials for replication (Appendix G). A small minority reported that materials were available on a public Web site. Without easily accessible replication materials, the resource implications of adopting strategies in other settings are unknown.

### Outcomes

Because study investigators examined a limited number of moderators and outcomes, the applicability of these findings and the transportability of these strategies to other settings remain unknown. Only one study examined system uptake; no other system intermediate outcomes such as feasibility, timeliness, penetration, sustainability, and resources (including costs) were explored. With respect to harms, only one study examined such a study result—in this case, patient side effects associated with a tested strategy. Four studies examined “moderators,” namely, training intensity or fidelity to protocol (or both).

Thus, our findings reflect information chiefly about possible positive effects of the various strategies, virtually nothing about the possible negative effects of such strategies, and extremely little or nothing about factors that might moderate or enhance such effects (such as characteristics of patients or clinicians, length of followup, or other components of the interventions or the study designs).

### Settings

Included studies had been set in schools, mental health clinics, and primary care practices. In general, studies testing the implementation of an EBP did so in these typical care settings. Other than two studies set in the United Kingdom and Canada, all others were set in the United States. KQ 1 results did not vary noticeably across settings. KQ 2 findings on the risk for inappropriate referral from primary care^113^ may be more applicable for primary care settings than for, say, schools or clinics. One study measured the impact of placing behavioral health care in a larger health-based care system on patients’ or parents’ access to evidence-based care. Such colocation may increase access to effective child mental health services. For many health care systems, this may be an achievable, structural change that, once in place, could have lasting impact. By and large, our findings are pertinent for most settings in the United States in which this type of care for these populations would be rendered.

## Implications for Clinical and Policy Decisionmaking

This body of evidence is relatively recent and small, often consisting of a single study each on multiple and diverse clinical areas and intervention strategies within child mental health. Across included studies, the strength of evidence for any intermediate outcome was rated moderate in one instance and low or insufficient for the remainder. We did not find moderate strength of evidence for any patient health and service utilization outcomes (system or patient level).

For providers or health care organizations looking for an evidence basis for deciding whether to support or expand QI, implementation, or dissemination strategies, our findings suggest (1) some confidence that provider financial incentives can improve competence in implementing EBPs; (2) weak confidence that strategies with educational meetings, materials, and outreach programs can be successful in combination with reminders or providing practitioners with newly collected clinical information in improving intermediate or health outcomes; and (3) weak confidence that educational materials or meetings (or both) or only educational materials and outreach components do not improve intermediate or health outcomes. Funders may be particularly interested in our findings of low or insufficient evidence as potential areas to fund new research.

The overall lack of strong evidence needs to be interpreted in the context of the general development of research in children and adolescent health care. Even in arguably more mature QI research areas among children and adolescents such as intensive care, infectious disease, and pulmonary disease, QI strategies can change provider behavior but system- and patient-level changes may be difficult to demonstrate. For example, Okelo et al. published a large review of 68 QI strategy studies that all aimed to improve provider adherence to evidence-based asthma protocols. These authors found notably more evidence for changing process outcomes than for changing patient-level outcomes.^114^

Furthermore, mental health research, especially for children and adolescents, poses notably greater challenges than the rest of health care for a variety of complex reasons (e.g., barriers in studying children; the difficulty of studying brain and behavior; stigma, low levels of research funding; complications of long-term followup as children age). It follows that QI research, at least for these populations, might well lag some other fields of investigation in depth, breadth, or robustness.

Given the paucity of evidence for strategies for improving mental health in children, a question that arises is whether QI, implementation, or dissemination strategies that have been tested and then reported in the adult literature might apply to children. The clinical and social context of child mental health can be very different from that of adults. Attributes specific to children such as their dependence on adult caregivers, the primacy of school environments, treatment needs, and diagnoses (e.g., attention deficit disorder, conduct disorder, oppositional defiant disorder, developmental disabilities) result in tailored responses from providers and organizations. Nonetheless, evidence on strategies that are somewhat removed from the clinical context (such as pay for performance) can translate more easily from the adult context to the child context. Strategies that are closely intertwined with specific patient attributes or behaviors, interventions, organizational providers, or settings (e.g., portal for physicians to access patient self-reported outcomes as the basis for calibrating medications) may not easily translate from the adult to the child context.

Our limited findings with respect to QI may also speak to the widely recognized gap between established EBPs in mental health and the limited number of practitioners or organizations actually providing those EBPs. For example, cognitive behavioral therapy (CBT) is the widely accepted EBP for treating patients with childhood anxiety. A recent Cochrane review of CBT for childhood anxiety included 1,955 subjects from 41 studies.^115^ Meanwhile, in the community, a minority of children with an anxiety disorder actually receive any treatment,^116^ let alone CBT specifically.^117^

A constraint to this field may simply be that an insufficient body of clinicians and organizations delivers EBPs in order to be able to test implementation or dissemination strategies. One clinical and policy implication, then, is the need for basic dissemination and infrastructure development for the delivery of EBPs, in combination with other strategies to ensure both access to and incentives for uptake of EBPs.

QI concepts in child health and child mental health are becoming fixtures of modern clinical practice and continuing professional education, despite the shortcomings of evidence in the area. For example, the American Board of Pediatrics requires its members to demonstrate periodic participation in QI exercises with their own patients. Clinicians in child mental health are increasingly working in or for “accountable care organizations” (ACAs). These practitioners and these organizations will be increasingly eager for guidance on using EBPs efficiently and effectively. If ACAs require evidence of high-quality care in child mental health, then they are going to need access to a robust QI evidence base. Such a QI evidence base will need to be developed against a backdrop of health systems that provide already established EBPs far more than they currently do.

## Limitations of the Systematic Review Process

Challenges in this systematic review arose from the sparse amount of prior literature on this topic that limited defining many of the details of our review a priori. Specifically, we struggled with (1) defining the strategy of interest, (2) constructing the search strategy, and (3) applying prespecified inclusion/exclusion criteria.

Regarding defining the strategy of interest, we did identify pragmatic definitions of QI, implementation, and dissemination that various systematic reviews or others had applied previously. We found, however, that applying them to this review was difficult. The lack of consistency in the terminology in the published literature meant that using descriptors such as “QI,” “implementation,” or “dissemination” selected by study authors did not (necessarily) conform to our a priori definitions of these types of studies or to the other similarly labeled studies in the field. As a result, we used the EPOC taxonomy to characterize strategies by their primary focus of their components and, thereby, to simplify both analysis and presentation. As noted in our description of our review methodology, we required multiple reviews of each included article and, on one occasion, outreach to authors to ensure that we interpreted the study correctly.

Regarding searches, we ran multiple iterations over a period of 6 months. We initially mirrored the search strategy in a previously published review.^39^ However, we had to make substantial changes to capture concepts or terms that were not indexed by the National Library of Medicine’s medical subject headings.

Regarding the application of prespecified inclusion and exclusion criteria, attempts to specify the population criteria to ensure greater homogeneity of included strategies posed challenges when we came to review the evidence. For example, we had one criterion specifying that the system or clinic render care for children and adolescents with existing mental health issues (rather than deal only with the risk of mental health issues), but it proved difficult to apply in some cases. To limit the inadvertent loss of relevant articles in a field with inconsistent use of terminology and inadequate indexing, we did not automatically exclude prevention studies in our searches. As a consequence, we found numerous studies with inadequate reporting that required judgment on whether the system addressed children and adolescents who were (only) at risk of or who were actually experiencing mental health problems. For example, we encountered studies of adolescents in juvenile drug courts. Although the authors did not specify what proportion of adolescents experienced mental health issues, we relied on the clinical and substantive expertise of the team to judge that adolescents in juvenile drug courts would likely have substance abuse issues or externalizing behavior problems.

We included a broad range of eligible comparators in our protocol (usual care or any other QI, implementation, or dissemination strategy). In reviewing full-text studies, we encountered otherwise eligible studies in which the intervention combined both a patient-level intervention and a system-level strategy to implement or disseminate that intervention. In such cases, the use of a usual-care arm did not permit the authors to draw conclusions about the effect of the implementation or dissemination strategy apart from the underlying intervention.^74–80,118^

Our inclusion and exclusion criteria were designed to capture QI, implementation, and dissemination studies across a range of strategies. Because of our criteria, all variants of a particular strategy may not have been captured along the timeline of its development and application in practice. Reviews focusing on a single strategy can evaluate variants of that strategy without using stringent criteria and construct a qualitative narrative about the arc of the development and implementation of that strategy, but such reviews cannot speak to QI, implementation, or dissemination in general. In other words, we traded a depth of understanding about the development and application of individual strategies for breadth in included strategy types.

## Limitations of the Evidence Base

We found relatively few studies of effectiveness of strategies to improve the mental health care of children and adolescents, although evidence emerged that some are effective in improving both intermediate and patient health outcomes and resource use measures. Only one study focused on system-level intermediate outcomes; none focused on the costs of these strategies.

The lack of a common language to describe even a basic concern such as the primary purpose of the strategies (QI, implementation, or dissemination) hindered our evidence synthesis. Strategies varied greatly in the number of components. The reporting on these components was not always clear enough to describe the strategy adequately or to enable us to understand fully the relative importance of component parts. Studies often offered limited descriptions of “usual-care” arms (relative to the detailed descriptions of experimental arms). Even with limited reporting, we found wide differences in the number, intensity, and differences in services offered in “usual-care” arms. These differences sharply limited our ability to make statements about the overall effectiveness of these strategies as a class.

Only one study examined harms. Additionally, although the field generally acknowledges the vast array of potentially influential moderators in implementation research,^32^ we uncovered only four studies on two moderators. The paucity of evidence on issues such as fidelity and adoption further limited our understanding of the minimum changes in strategy that might be needed to achieve meaningfully different process or health outcomes.

We rated several outcomes as insufficient or, at best, low strength of evidence for several reasons: the underlying heterogeneity or limited number of studies on specific strategy types, system or practitioner targets, or child or adolescent conditions. In some instances, our grades were limited by the high risk of bias in included studies; these ratings arose because of high attrition rates, failure to adjust analyses for baseline levels of key outcomes or clustering within practitioners or clinics, and failure to account for missing data.

Our ability to derive firm conclusions on the effectiveness of included strategies was also hindered by methodological and reporting issues in the literature. The strategies of relevance to this review generally required that study arms be defined at a systems level to reflect pragmatic considerations (e.g., the intervention changes a system characteristic) or to avoid contamination (e.g., a provider exposed to a new QI strategy may have difficulty applying the strategy selectively to some patients). Observational studies in general are more constrained than RCTs in their ability to make causal assertions because of the risk of confounding; observational studies of systems interventions have an additional burden of accounting for secular and unmeasured financial or organizational changes that may influence outcomes. Cluster randomized trials with clearly specified protocols allow interventions to be allocated appropriately at the systems level, with the potential to avoid the constraints of confounding and unmeasured cointerventions. However, the analyses of results from these trials required controls for clustering. These analyses (which typically require hierarchical linear modeling) were complex but investigators often did not report them well enough to permit an independent evaluation of the effect size,^88^ precision of the effect,^67,86,89,90^ or risk of bias.^88,89^

As documented in Table 31, QI, implementation, and dissemination trials often failed to report on basic elements of study design and conduct; this was true especially for sequence generation, allocation concealment, fidelity to the intervention, and the risk of contamination or crossover. Such lacunae in reporting occurred in all study design types, regardless of their underlying rigor and complexity.

Table 31 Studies with insufficient reporting on risk of bias domains

Domain with Insufficient Reporting to Assess Risk of Bias | Number and Type of Studies
Eligibility criteria | 2 nonrandomized studies,^93,94^ 2 trials^89,91^
Randomization sequence generation | 6 trials^13,14,66,86,88,89,91^
Allocation concealment | 7 trials^13,14,66,67,86,88,89,91^
Similarity of baseline characteristics | 2 nonrandomized studies,^93,94^ 8 trials^66,67,85,87–91^
Fidelity to intervention | 4 nonrandomized studies,^66,93–95^ 8 trials^13,14,66,86,88–92^
Overall attrition | 3 nonrandomized studies,^66,93,94^ 7 trials^13,14,66,67,84,86,90^
Attrition by study arm (differential attrition) | 2 nonrandomized studies,^93,94^ 5 trials^67,86,88,90,91^
Risk of contamination or crossover | 4 nonrandomized studies,^66,93–95^ 13 trials^13,14,66,67,84–92^

Finally, our proposed analyses reflect some limitations of QCA. First, models can be used to investigate only a few conditions of interest because QCA examines each possible combination of conditions; this property exponentially increases with each addition (e.g., 5 conditions yields 32 possible combinations, 6 conditions yields 64 possible conditions). Thus, combinations that have no data (i.e., have never been studied) cannot be analyzed. Another limitation is that the strategies themselves need to be at least somewhat comparable,^119^ allowing for investigation of only high-level components consistent across strategies.

For this analysis, we included 17 studies that met the criteria for the systematic review. Of the possible 256 combinations from our studies, 242 had no studies; thus, we had substantial limited diversity in our sample of cases. We managed this challenge by assessing different QCA solutions. Adding new studies with new evidence could introduce a new solution to showing significant improvements.

## Contributions of Novel Analytic Approaches to Addressing Complex Interventions in Systematic Reviews

To address the limitations of the systematic review process and evidence base relevant to our review, we had to expand on traditional methods to assess the effectiveness of strategies to implement or disseminate evidence-based interventions for child mental health or to improve the quality of care. The complexity of both the evidence-based interventions and the implementation and dissemination strategies themselves, coupled with the absence of information on critical components, created challenges in our analysis. We sought to identify additional information about the critical components of each strategy by (1) searching for “sibling studies” (e.g., searches of related publications of the same intervention or same authors as the index publication) and searches of related publications by authors and (2) reaching out to investigators to understand what they believed to be the critical component of the strategy. We then used these findings to extract meaning from the synthesis through QCA, which helped us to cluster studies by common attributes in a way that adequately captured the multidimensional nature of these strategies.

### Contributions From Searches of Related Publications

As noted earlier in this report, we found 1,158 studies and reviewed 33 in full text. Six articles then contributed to our understanding of included strategies. Of these, three helped us flesh out descriptions of the interventions.^99,104,105^ In three instances, we found explanations or insights on the barriers and facilitators to the strategy in the review^96,97^ or a subsequent iteration of the strategy^103^ that did not meet inclusion criteria for our review.

In addition to these six publications, one article provided information on yet other outcomes to an already included study,^68^ and one article met our inclusion criteria and was included as a full citation.^91^ We evaluated the indexing terms for both articles that contributed such additional data. In one instance,^68^ we constructed an add-on to ensure that we had not missed any other relevant citations (and we had not). As suggested by these numbers, the yield, relative to the volume of searches, is modest. The effort did not produce similar extensions of understanding for all included strategies: we were able to add insights for only four included strategies.^13,85,87,88^ In our view, the most important contribution of this approach is that it helped us identify a new study^91^ and gave us additional outcomes data for an already included study.^68^ Through these findings, this approach also helped alert us to a potential gap in our search strategies.

### Contributions From Outreach to Investigators

As noted above, not all study teams published ancillary findings that could help us identify critical components. Outreach to investigators appeared to be a promising avenue to filling information gaps.

We contacted individual principal investigators to identify critical components of their particular strategies. Two principal investigators were deceased; we reached out to alternates. As noted in the results section, we received t responses for 10 of 17 studies and identified differences between study arms. Because of the limited response rate, we were unable to use the data from this exercise as a way to sort and cluster interventions for analysis.

Although we hoped to fill information gaps using such outreach, we found that authors who had not published ancillary works were less likely to respond to our inquiries (5/12) than authors who had published findings in ancillary works (5/5).^13,85,87,88^ This finding suggests that a post hoc attempt to identify important information about strategies is likely to be of limited value. As investigative teams disband or shift focus over time, the kind of information that we needed is likely to be harder to come by if it is not published along with the main findings of the study. Our experience suggests that journals should require all investigators of QI, implementation, and dissemination studies to identify routinely the critical components of their strategies so that subsequent groups of researchers can replicate or build on their findings in other settings.

### Contribution From Qualitative Comparative Analysis

Our QCA analysis was instrumental in identifying common attributes across several low strength of evidence findings, specifically that educational meetings, materials, and outreach programs can be successful in combination with reminders or providing practitioners. QCA is not constrained by reporting of ancillary findings or responses on interview questions, but it requires a sufficient number of cases and a small number of conditions to run meaningful analyses. We limited our ability to comment on successful solutions to the 12 cases demonstrating benefit and distilled the wide range of intervention components into a smaller number of conditions to meet these requirements.

Furthermore, we could not meaningfully address the full range of nuance and complexity of these interventions. Our application of QCA yielded insights on solutions (recipes for success) that we could not have obtained through traditional systematic review methods. However, these insights required substantial effort; the tasks include creating transparent decision rules for whether to “count” a component as part of the strategy, dually applying these rules through a careful and exhaustive read of the included publication and ancillary documents, using a theoretical framework to regroup components, testing multiple models, and validating the results of the models against the raw data of the publication.

Insights from QCA are hypothesis generating rather than hypothesis confirming. Adding new cases to the body of evidence can produce new recipes and new insights. QCA may be useful when traditional systematic review methods provide limited insights and hypothesis-generating insights have value.

## Research Recommendations

The evidence base is marked by a small number of studies on diverse strategies and outcomes focusing on intermediate and health outcomes and resource use; we had very few studies on harms or moderators. Some additional research is forthcoming: a review of clinicaltrials.gov yielded three ongoing trials that may be applicable to future reviews on the topic (NCT02097355, NCT01829308, NCT02271386). The first trial is examining the impact of a Web-based patient management and monitoring system (Integrated Clinical Information Sharing System) that was designed to track patients’ disease symptoms and response to therapy over time in child and adolescent patients with attention deficit hyperactivity disorder (ADHD), asthma, autism, depression, or epilepsy (or combinations of these disorders) (NCT02097355). The second trial is documenting the impact of implementing two evidence-based intervention strategies (i.e., Screening, Brief Intervention, and Referral to Treatment, with, e.g., generalist versus specialist referral) on the outcomes of adolescent alcohol, tobacco, other drug use, and HIV risk behaviors (NCT01829308). The third trial is investigating the impact of educating and supporting primary care providers in the implementation of EBPs for ADHD (NCT02271386). All three studies will fill some of the evidence gaps by providing additional quantitative data on the effectiveness of strategies to improve intermediate and patient-centered outcomes. We outline specific suggestions for future studies in Table 32.

Table 32 Future research recommendations to better understand strategies to improve the mental health care of children

Focus Areas for New Research | Specific Research Recommendations
Strategies | Trials of Financial strategies Regulatory strategies Combination strategies such professional training with audit and feedback or reminders and collaborative care
Moderators of successful strategies | Patients, practitioners, organizations, or systems characteristics Intervention characteristics Setting characteristics Characteristics of the implementation process
Outcomes | Benefits for patients as well as implementation outcomes, particularly when the implementation strategy allows for changes in the underlying intervention Harms Appropriately timed outcome measures that allow time for change to occur Changes sustained over time
Reporting | Critical components of strategies Extent of fidelity to or adaptation of original intervention Crossover and contamination Details about design and conduct of complex studies, particularly cluster randomized trials
Other | Comparative effectiveness of strategies Resources needed to implement strategy Strategies for areas lacking adequate mental health services

Third-party payers are paying increasing attention to quality metrics, as health care systems move to accountable care models. We found no studies on regulatory components and just one study testing a financial component, specifically pay for peformance.^85^ Our findings of moderate strength of evidence of benefit for a pay-for-performance approach and low strength of evidence of benefit for strategies that include professional training coupled with organization change such as audit and feedback or reminders were limited to the specific clinical contexts of the included trials. These promising solutions require confirmation and further investigation across different populations, clinical conditions, and settings. In addition to expanding the modest body of evidence thus far on professional training and financial or organizational change strategies, new studies should additionally evaluate regulatory and financial components to support the needs of ACAs in the near future.

Our review highlights the fact that the current state of the evidence does not give clinicians and health plan administrators a definitive understanding of best methods to introduce EBPs successfully into clinical settings. Future research efforts should evaluate variations of such programs according to patient, provider, organization, systems, and setting characteristics. A better understanding of these variables can impede or promote the implementation and dissemination of EBPs.

For example, Chorpita et al.^120^ point out the need to address challenges that clinical providers face, such as concerns about how an EBP might address comorbidity, because much of clinical practice occurs in generalist settings in which the typical presenting patient has more than one type of problem or diagnosis. In such situations, the clinicians’ perception of whether the treatment will be effective can be an important variable. They also note that better understanding of the social processes relevant to dissemination is crucial; they argue that the social influence process is at least in part responsible for the success (or lack of it) of implementation of different mental health treatments for children. Moreover, understanding more about training procedures and trainer characteristics is necessary to determining how best to change therapist practices. Similarly, understanding trainee characteristics is called for if those advocating change are going to be able to recognize barriers to clinicians’ use of treatment strategies. Considering variables such as these will provide a framework to guide the development of QI and implementation or dissemination strategies. New taxonomies that are continually emerging, such as the revised EPOC taxonomy^121^ and the recently published findings from the Expert Recommendations for Implementing Change (ERIC) project,^122^ also will advance the field by clarifying the conceptual models that underlie this research.

We did not find evidence on the majority of the outcomes that we specified a priori. Of particular note, seven strategies (two from a single publication) relied on EBPs; for that reason, these investigators did not report patient health outcomes.^66,85,87,91–93^ When researchers maintain fidelity to the original intervention, the assumption that the same level of effectiveness will occur in a new trial is reasonable and leads to an efficient use of research funds. Unfortunately, not all studies measured fidelity adequately. New strategies relying on EBPs must, at a minimum, report on fidelity so that practitioners and policymakers can judge whether the strategy is, in fact, a new intervention rather than implementation or dissemination of an existing intervention. We found insufficient evidence on the unanticipated harms of these strategies.

Future research in this area requires appropriately timed outcome measures. One potential explanation for the lack of consistent demonstration of effectiveness across the included studies could be that studies reported on outcomes too early, before strategies had a chance to take effect. The included studies generally measured systems outcomes over the course of the intervention. One study measured adherence to CBT after 3 months of consultation,^87^ and a second measured referrals to early intervention services at 4 months after intervention.^90^ Although a third trial measured outcomes at 6 months from baseline, the intervention was ongoing for some portion of that period.^85^ Studies generally measured patient outcomes within 6 months of completion of the trial, with two exceptions that measured outcomes at 18^14^ and 24 months,^88^ respectively.

The risk of crossover or contamination is of particular concern in systems strategies, but only one study explicitly provided information on the risk of crossover or contamination. As noted earlier, very few studies offered information on fidelity or on unanticipated changes. Information on pragmatic issues related to implementation (fidelity, adaptation, and minimum elements necessary to achieve change) may not necessarily require new studies on strategies with existing information; support of analyses done with data from existing studies may fill some of these gaps.

The majority of included studies appropriately used cluster RCTs. Cluster RCTs, like pragmatic trials, need more resources than standard RCTs, and they are harder to complete than conventional studies. An additional consideration of cluster RCTs relates to reporting. The studies we found were marked by poor reporting or failure to report key details of the strategy or differences across study arms. Concerns about the inadequacies of reporting have been noted elsewhere in the literature.^123,124^ A recent tool, the StaRI (standards for reporting implementation studies of complex interventions) offers standards for reporting implementation studies that, if adopted widely, can significantly improve the utility of these studies and hasten the pace of translation of evidence into practice.^125^

Hybrid designs that blend effectiveness and implementation in the same study may be an important way to meet the immediate need for empirical evidence to guide clinical decisions and policies at the organization or system level.^126^ Such use could accelerate the translation of research findings into practice.

Although the failure to use EBPs can lead to gaps between potential and achieved outcomes, closing such gaps requires more than just using an array of EBPs. What continues to be unknown is how to bridge the gap in the context of the finite resource of time allocated for a patient encounter. As expectations for documenting or checking off quality metrics for each action within a patient encounter increase, the risk of errors of omission or commission increases. For new information to be actionable, more evidence is needed on the relative merits of each action or strategy.

More research is needed on strategies for the QI, implementation, and dissemination of EBPs in psychotherapy treatments as well as medication treatments of mental illness in youth. Other important targets include the development of dissemination strategies for introducing mental health care into areas lacking in mental health care, for example, very rural areas with fewer mental health providers. In these areas especially, targeting primary care providers may be essential.

## Conclusions

The evidence does not permit us to have a high degree of confidence about the efficacy of any one strategy. Nonetheless, our findings may have relevance for policymakers who do not require a high level of causal certainty (for example, in commissioning pilot studies). Our findings suggest that several approaches can improve both intermediate and final health outcomes and resource use. Twelve of the 17 included studies significantly improved at least one such outcome or measure. Moderate strength of evidence (from one RCT) supported using provider financial incentives (such as pay for performance) to improve the competence with which clinicians can implement EBPs.^84^ We found inconsistent evidence on strategies involving educational meetings, materials, and outreach; these programs appeared to be successful in combination with reminders or providing practitioners with newly collected clinical information. We also found low strength of evidence for no benefit for initiatives that included only educational materials or educational meeting components (or both) or only educational materials and outreach components.^87,88,90,91^

In addition to differences in strategies tested and their specific components, the heterogeneity in clinical conditions of the children and adolescents in these studies, in the various types of practitioners, and in the settings precluded definitive conclusions about the effectiveness of any one particular strategy. We were unable to judge the potential for harms associated with these approaches that might mitigate benefits; the single study reporting on harms yielded too little insights on this problem. The available evidence from four studies on two moderators does not permit us to make generalizations about the circumstances under which these strategies might work optimally.