# Appendix H Qualitative Comparative Analysis

Specific analytic steps are described below:

1. Specifying the configural questions. For this review, we asked “what combination of intervention components is present in studies demonstrating improved implementation, dissemination, quality improvement?”
2. Identifying cases for use in analysis. All included studies had at least two arms but did not always provide information on arm-specific improvements. Therefore, we could not include each arm in each study as a case; rather, each case constituted a comparison between two study arms. A study with three arms provided two cases for analysis.
3. Specifying and calibrating condition sets. In this step, we planned to examine several causal conditions. Specifically, we focused on intervention components as defined by the taxonomy used by the international Cochrane Review Group’s EPOC Group to classify complex strategies designed to improve health care professionals’ practice and the organization of health care services.^1^ We classified studies based on whether study arms differed with respect to at least one professional component (e.g., distribution of educational materials, educational meetings, audit and feedback), at least one financial component (provider financial components such as provider incentives and provider grants or allowances and patient financial components such as patient incentives), and at least one organizational component (both provider-oriented organizational components such as clinical multidisciplinary teams and provider satisfaction, as well as structural organizational components such as changes in scope and nature of benefits and services, staff organization, and presence and organization of quality monitoring mechanisms). With 17 included studies, we needed to limit the number of conditions we could test. Because QCA examines all possible combinations of conditions, adding conditions to a model increases the number of possible combinations exponentially (by 2 to the kth power, where k is the number of conditions. Thus, 3 conditions produce 8 combinations, 4 conditions produce 16 combinations, and so on).
  a. In QCA, condition (and outcome) sets are calibrated by establishing thresholds and decision rules for membership in a condition. In a crisp set, a value of 1 indicates that a case is fully in the condition set; a value of 0 indicates that a case is fully out of a condition set. In keeping with the definition of cases as comparisons between two arms, we defined conditions as differences between two arms. We used the EPOC taxonomy to classify main intervention components, dually and independently, and resolved conflicts after consensus. A value of 0 indicated there was no difference between the arms in that component. A value of 1 meant that the arms varied in that component. For example, cases assigned a condition value of 1 for financial components had at least one financial component (such as pay for performance) that the control arm did not have. Table H-1 illustrates the criteria used to assess each condition set. Two models with different outcomes but the same set of tested components were tested. We used crisp sets (0 vs. 1) instead of fuzzy sets, which can have continuous values, because the conditions of interest aligned with a dichotomous scoring.
  b. We tested models defined by the presence or absence of at least one educational materials or meetings component, at least one educational outreach component, at least one patient-mediated intervention component, at least one audit and feedback component, at least one reminders component, at least one financial component, at least one changing clinical multidisciplinary teams component, and at least one changing the scope of patient benefits component.
4. Specifying and calibrating outcome set. We assessed “having evidence of improvement” as our outcome set. Table H-3 illustrates the criteria used to assess each outcome. We evaluated two outcomes to test in our models that contained the condition sets defined above:
  a. A majority of practitioner-, system-, and patient-level intermediate outcomes showing statistically significant improvement between study arms and showing at least low strength of evidence for benefit
  b. A super outcome defined as having a majority of practitioner-, system-, and patient-level intermediate outcomes showing statistically significant improvement between study arms OR at least one patient health or health care utilization outcome showing at least low strength of evidence for benefit between study arms
  As with calibration of the condition set, we dually and independently calibrated each outcome set and resolved conflicts after consensus. We assigned a value of 1 (fully in the set of achieving our outcome of interest), indicating evidence of improvement. We assigned a value of 0 (fully out of the set of achieving implementation effectiveness as defined by our outcome of interest, indicating no evidence of improvement) to cases that did not demonstrate a statistically significant improvement in outcome between arms.
5. Constructing and analyzing the truth table. The truth table, the key analytic device in QCA, helps determine which combinations of conditions occur consistently with improvement. We used R Set Methods and QCA packages^2^ to identify solutions (i.e., combinations of conditions that are necessary or sufficient for the outcomes). This analysis also included examination of parameters of fit: consistency and coverage. Consistency assesses whether the causal pathway produces the outcome regularly (“the degree to which the empirical data are in line with a postulated subset relation”);^3, p. 324^ in crisp sets, consistency indicates the proportion of cases that achieved an outcome in an individual solution or across solutions for total solution consistency. Coverage determines the empirical relevance of a solution and quantifies the variation in causal pathways to an outcome (analogous to variance explained, or how well the solutions explain outcomes across all included cases). The results of a QCA analysis are statements of necessity and sufficiency, expressed as text, as solution formulas, or in tabular or graphic formats. We assessed each individual condition for necessity and sufficiency, examined the necessary and sufficient combinations of conditions that resulted in significant improvements, and calculated consistency and coverage. In our analysis of combinations, we ran the conservative, intermediate, and parsimonious solutions, as well as the negation of the outcome. We implemented a .80 consistency level for including combinations in the final minimization; we also tested for robustness at 0.75 and 0.90. As is typical in QCA practice, we report the intermediate solution. The conservative and parsimonious solutions, which are a subset and a superset (respectively) of the intermediate solution, are available on request.
6. Making sense of the results. We returned to the included studies to evaluate the identified solutions and understand the contextual elements that might explain these solutions.

Table H-1 Condition and outcome definitions and calibration specifications for QCA intervention components and outcomes

Condition or Outcome | Definition | Calibration
Condition: Study arms differed by the presence of a specific professional component: Educational materials or meetings | Differences between arms include at least one professional educational materials or meetings component; component is a major part of strategy tested in the study | Fully In (score=1.0): At least one professional educational materials/meetings component differs between study arms. Fully Out (score=0.0): No professional educational materials/meetings components differ between study arms
Condition: Study arms differed by the presence of a specific professional component: Educational outreach visits | Differences between arms include at least one professional educational outreach visits component; component is a major part of strategy tested in the study | Fully In (score= 1.0): At least one professional educational outreach visits component differs between study arms Fully Out (score=0.0): No professional educational outreach components differ between study arms
Condition: Study arms differed by the presence of a specific professional component: Audit and feedback | Differences between arms include at least one professional audit and feedback component; component is a major part of strategy tested in the study | Fully In (score=1.0): At least one professional audit and feedback component differs between arms Fully Out (score=0.0): No professional audit and feedback components differ between study arms
Condition: Study arms differed by the presence of a specific professional component: Reminders | Differences between arms include at least one professional reminders component; component is a major part of strategy tested in the study | Fully In (score=1.0): At least one professional reminders component differs between study arms Fully Out (score=0.0): No professional reminders components differ between study arms
Condition: Study arms differed by the presence of at least one financial component | Differences between arms include at least one financial component; component is a major part of strategy tested in the study | Fully In (score=1.0): At least one financial component differs between study arms Fully Out (score=0.0): No financial components differ between study arms
Condition: Study arms differed by the presence of having clinical multidisciplinary teams (an organizational-provider component) | Differences between arms include at least one clinical multidisciplinary teams component; component is a major part of strategy tested in the study | Fully In (score=1.0): At least one clinical multidisciplinary teams component differs between study arms Fully Out (score=0.0): No clinical multidisciplinary teams components differ between study arms
Condition: Study arms differed by the presence of a changing the scope of patient benefits component | Differences between arms include at least one changing the scope of patient benefits component; component is a major part of strategy tested in the study | Fully In (score=1.0): At least one changing the scope of patient benefits component differs between study arms Fully Out (score=0.0): No changing the scope of patient benefits components differ between study arms
Outcome: Significant improvement in majority of practitioner, system, or patient intermediate outcomes | Between-arm intermediate outcome differs statistically significantly between intervention and control (or more vs. less intense arms) for a majority of intermediate outcomes tested | Fully In (score= 1.0): A majority of practitioner-, system-, and patient-level intermediate outcomes showed statistically significant improvements Fully Out (score=0.0): A majority of intermediate outcomes tested did not show statistically significant improvements across study arms
Outcome: Significant improvement in majority of practitioner, system, or patient intermediate outcomes [underlined: OR] significant improvement in majority of patient or health care utilization outcomes | Between-arm outcome differs statistically significantly between intervention and control (or more vs. less intense arms) for a majority of intermediate outcomes tested OR for majority of patient/health care utilization outcomes tested | Fully In (score=1.0): A majority of practitioner-, system-, and patient-level intermediate outcomes [underlined: OR a majority of patient/health care utilization outcomes] showed statistically significant improvements Fully Out (score=0.0): A majority of intermediate outcomes [underlined: AND] patient/health care utilization outcomes tested did not show statistically significant improvements across study arms

QCA = Qualitative Comparative Analysis.

Table H-2 QCA inputs for each condition set and outcome examined for each included study (Part 1)

Study Authors | Fully In (score=1.0): At least one educational materials or educational meeting component differs between study arms Fully Out (score=0.0): No educational materials or meetings components differ between arms | Fully In (score=1.0): At least one educational outreach visit component differs between study arms Fully Out (score=0.0): No educational outreach components differ between arms | Fully In (score=1.0): At least one patient-mediated intervention component differs between study arms Fully Out (score=0.0): No patient-mediated intervention components differ between arms | Fully In (score=1.0): At least one audit and feedback component differs between study arms Fully Out (score=0.0): No audit and feedback components differ between arms | Fully In (score=1.0): At least one reminders component differs between study arms Fully Out (score=0.0): No reminders components differ between arms | Fully In (score=1.0): At least one financial component differs between study arms Fully Out (score=0.0): No financial components differ between arms | Fully In (score= 1.0): At least one clinical multidisciplinary teams component differs between study arms Fully Out (score=0.0): No clinical multidisciplinary teams components differ between arms
Beidas et al., 2012 G1 vs. G3^4^ | 1 | 0 | 0 | 0 | 0 | 0 | 0
Beidas et al., 2012 G2 vs. G3^4^ | 1 | 0 | 0 | 0 | 0 | 0 | 0
Bickman et al., 2011^5^ | 0 | 0 | 0 | 1 | 0 | 0 | 0
Carroll et al., 2013^6^ | 1 | 0 | 1 | 0 | 1 | 0 | 0
Epstein et al., 2011^7^ | 1 | 0 | 1 | 1 | 1 | 0 | 1
Epstein et al., 2007^8^ | 0 | 0 | 0 | 1 | 1 | 1 | 0
Garner et al., 2012^9^ | 0 | 0 | 0 | 0 | 0 | 1 | 0
Glisson et al., 2012^10^ | 1 | 1 | 0 | 1 | 0 | 0 | 0
Glisson et al., 2010^11^ | 1 | 1 | 0 | 1 | 0 | 0 | 0
Gully et al., 2008 Study 1^12^ | 1 | 1 | 1 | 0 | 0 | 0 | 0
Gully et al., 2008 Study 2^12^ | 1 | 1 | 1 | 0 | 0 | 0 | 0
Henggeler et al., 2008^13^ | 0 | 0 | 0 | 0 | 0 | 0 | 0
Henggeler et al., 2013 G1 vs. G3^14^ | 1 | 1 | 0 | 0 | 0 | 0 | 0
Henggeler et al., 2013 G2 vs. G3^14^ | 1 | 0 | 0 | 0 | 0 | 0 | 0
Lester et al., 2009^15^ | 1 | 1 | 0 | 0 | 0 | 0 | 0
Lockman et al., 2009^16^ G1 vs. G3 | 1 | 0 | 0 | 1 | 0 | 0 | 0
Lockman et al., 2009^16^ G2 vs. G3 | 1 | 0 | 0 | 0 | 0 | 0 | 0
Ronsley et al., 2012^17^ | 1 | 1 | 0 | 0 | 1 | 0 | 0
Sterling et al., 2015^18^ | 0 | 0 | 1 | 0 | 0 | 0 | 1
Wildman et al., 2012^19^ | 0 | 0 | 1 | 0 | 0 | 0 | 0

G = group; QCA = Qualitative Comparative Analysis; vs = versus.

Table H-3 QCA inputs for each condition set and outcome examined for each included study (Part 2)

Study Authors | Fully In (score=1.0): At least one provider satisfaction with conditions of work component differs between study arms Fully Out (score=0.0): No provider satisfaction with conditions of work components differ between arms | Fully In (score=1.0): At least one quality monitoring component differs between arms Fully Out (score=0.0): No quality monitoring components differ between arms | Fully In (score=1.0): At least one changing the scope of patient benefits component differs between study arms Fully Out (score= 0.0): No changing the scope of patient benefits components differ between arms | [underlined: OUTCOME (Intermediate):] Fully In (score=1.0): A majority of practitioner-, system-, and patient-level intermediate outcomes showed statistically significant improvements across study arms Fully Out (score=0.0): A majority of intermediate outcomes tested did not show statistically significant improvements across study arms | [underlined: OUTCOME (Super [Intermediate or Patient Health/Service Utilization]):] Fully In (score=1.0): A majority of practitioner-, system-, and patient-level intermediate outcomes [underlined: or] at least one patient health or service utilization outcomes showed low strength of evidence for benefit across study arms Fully Out (score=0.0): A majority of intermediate outcomes did not show statistically significant improvements and at least one patient health or service utilization outcome tested did not show at least low strength of evidence for benefit across study arms
Beidas et al., 2012 G1 vs. G3^4^ | 0 | 0 | 0 | 0 | 0
Beidas et al., 2012 G2 vs. G3^4^ | 0 | 0 | 0 | 0 | 0
Bickman et al., 2011^5^ | 0 | 0 | 0 | 0 | 1
Carroll et al., 2013^6^ | 0 | 1 | 0 | 1 | 1
Epstein et al., 2011^7^ | 0 | 1 | 0 | 1 | 1
Epstein et al., 2007^8^ | 0 | 0 | 0 | 0 | 0
Garner et al., 2012^9^ | 0 | 0 | 0 | 1 | 1
Glisson et al., 2012^10^ | 1 | 0 | 0 | 1 | 1
Glisson et al., 2010^11^ | 1 | 0 | 0 | 0 | 0
Gully et al., 2008 Study 1^12^ | 0 | 0 | 0 | 1 | 1
Gully et al., 2008 Study 2^12^ | 0 | 0 | 0 | 1 | 1
Henggeler et al., 2008^13^ | 0 | 1 | 0 | 0 | 0
Henggeler et al., 2013 G1 vs. G3^14^ | 0 | 0 | 0 | 0 | 0
Henggeler et al., 2013 G2 vs. G3^14^ | 0 | 0 | 0 | 0 | 0
Lester et al., 2009^15^ | 0 | 0 | 0 | 0 | 1
Lockman et al., 2009^16^ G1 vs. G3 | 0 | 0 | 0 | N/A | 1
Lockman et al., 2009^16^ G2 vs. G3 | 0 | 0 | 0 | N/A | 0
Ronsley et al., 2012^17^ | 0 | 0 | 0 | 1 | 1
Sterling et al., 2015^18^ | 0 | 0 | 0 | 1 | 1
Wildman et al., 2012^19^ | 0 | 0 | 1 | 1 | 1

G = group; N/A = not applicable; QCA = Qualitative Comparative Analysis; vs = versus.

Table H-4 Truth table

Study Authors | Having an Educational Materials or Meetings Component | Having a Patient-Mediated Intervention Component | Having an Educational Outreach Component | Having an Audit and Feedback Component | Having a Financial Component | Having a Clinical Multidisciplinary Teams Component | Having a Changes in Scope of Patient Benefits Component | Having a Reminder Component | # of Studies in the Combination | Consistency
Beidas et al., 2012^4^ G1 vs. G3 and G2 vs. G3; Henggeler et al., 2013^14^ G1 vs G3; Lockman et al., 2009^16^ G2 vs. G3 | 1 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 4 | 1.000
Gully et al., 2008^12^ Study 1 and Study 2; | 1 | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 2 | 1.000
Henggeler et al., 2013^14^ G1 vs G3; Lester et al., 2009^15^ | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 0 | 2 | 0.500
Glisson et al., 2012^10^; Glisson et al., 2010^11^ | 1 | 0 | 1 | 1 | 0 | 0 | 0 | 0 | 2 | 0.500
Wildman et al., 2012^20^ | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 1 | 1.000
Sterling et al., 2015^18^ | 0 | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 1 | 1.000
Garner, 2012^9^ | 0 | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 1 | 1.000
Bickman et al., 2011^5^; | 0 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 1.000
Lockman et al., 2009^16^ G1 vs. G3 | 1 | 0 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 1.000
Ronsley et al., 2012^17^ | 1 | 0 | 1 | 0 | 0 | 0 | 0 | 1 | 1 | 1.000
Carroll et al., 2013^6^ | 1 | 1 | 0 | 0 | 0 | 0 | 0 | 1 | 1 | 1.000
Epstein et al., 2011^7^ | 1 | 1 | 0 | 1 | 0 | 0 | 0 | 1 | 1 | 1.000
Henggeler et al., 2008^13^ | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 0 | 1 | 1.000
Epstein et al., 2007^8^ | 0 | 0 | 0 | 1 | 0 | 1 | 0 | 0 | 1 | 1.000

NOTE: Combinations of condition sets not found in any included study are not shown (e.g., no study included professional and financial condition sets but not organizational provider and not organizational structural).

## References

1 Effective Practice and Organisation of Care (EPOC). (2002). EPOC Taxonomy.
2 Dusa A, Thiem A. (2014). Qualitative Comparative Analysis. R Package Version 1.1-4.
3 Ragin CC. (1999). Using qualitative comparative analysis to study causal complexity. Health Serv Res.
4 Beidas RS, Edmunds JM, Marcus SC, et al. (2012). Training and consultation to promote implementation of an empirically supported treatment: a randomized trial. Psychiatr Serv.
5 Bickman L, Kelley SD, Breda C, et al. (2011). Effects of routine feedback to clinicians on mental health outcomes of youths: results of a randomized trial. Psychiatr Serv.
6 Carroll AE, Bauer NS, Dugan TM, et al. (2013). Use of a computerized decision aid for ADHD diagnosis: a randomized controlled trial. Pediatrics.
7 Epstein JN, Langberg JM, Lichtenstein PK, et al. (2011). Use of an Internet portal to improve community-based pediatric ADHD care: a cluster randomized trial. Pediatrics.
8 Epstein JN, Rabiner D, Johnson DE, et al. (2007). Improving attention-deficit/hyperactivity disorder treatment outcomes through use of a collaborative consultation treatment service by community-based pediatricians: a cluster randomized trial. Arch Pediatr Adolesc Med.
9 Garner BR, Godley SH, Dennis ML, et al. (2012). Using pay for performance to improve treatment implementation for adolescent substance use disorders: results from a cluster randomized trial. Arch Pediatr Adolesc Med.
10 Glisson C, Hemmelgarn A, Green P, et al. (2012). Randomized trial of the Availability, Responsiveness, and Continuity (ARC) organizational intervention with community-based mental health programs and clinicians serving youth. J Am Acad Child Adolesc Psychiatry.
11 Glisson C, Schoenwald SK, Hemmelgarn A, et al. (2010). Randomized trial of MST and ARC in a two-level evidence-based treatment implementation strategy. J Consult Clin Psychol.
12 Gully KJ, Price BL, Johnson MK. (2008). Increasing abused children’s access to evidence-based treatment: diffusion via parents as consumers. Child Maltreat.
13 Henggeler SW, Sheidow AJ, Cunningham PB, et al. (2008). Promoting the implementation of an evidence-based intervention for adolescent marijuana abuse in community settings: testing the use of intensive quality assurance. J Clin Child Adolesc Psychol.
14 Henggeler SW, Chapman JE, Rowland MD, et al. (2013). Evaluating training methods for transporting contingency management to therapists. J Subst Abuse Treat.
15 Lester H, Birchwood M, Freemantle N, et al. (2009). REDIRECT: cluster randomised controlled trial of GP training in first-episode psychosis. Br J Gen Pract.
16 Lochman JE, Boxmeyer C, Powell N, et al. (2009). Dissemination of the Coping Power program: importance of intensity of counselor training. J Consult Clin Psychol.
17 Ronsley R, Rayter M, Smith D, et al. (2012). Metabolic monitoring training program implementation in the community setting was associated with improved monitoring in second-generation antipsychotic-treated children. Can J Psychiatry.
18 Sterling S, Kline-Simon AH, Satre DD, et al. (2015). Implementation of screening, brief intervention, and referral to treatment for adolescents in pediatric primary care a cluster randomized trial. JAMA Pediatrics.
19 Wildman BG, Langkamp DL. (2012). Impact of location and availability of behavioral health services for children. J Clin Psychol Med Settings.
20 Stice E, South K, Shaw H. (2012). Future directions in etiologic, prevention, and treatment research for eating disorders. J Clin Child Adolesc Psychol.