# Appendix F Strength of Evidence Tables

Table F-1 Augmented active learning versus computerized routine versus routine professional training workshop to implement an EBP: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Practitioner: Satisfaction with or acceptability of approach for augmented training | 1; 115 therapists | Low | Unknown (single study) | Direct | Imprecise^a^ | Undetected | Low for no benefit for practitioner satisfaction; calculated mean difference of G1–G3: 1.8, 95% CI, −0.423 to 4.023, p=0.11 CT group had lower satisfaction than usual care group
Intermediate outcome: Practitioner: Protocol adherence/program model fidelity | 1; 115 therapists | Low | Unknown (single study) | Direct | Imprecise^a^ | Undetected | Low for no benefit for various measures of protocol adherence/program model fidelity
Intermediate outcome: Practitioner: Competence/skills | 1; 115 therapists | Low | Unknown (single study) | Direct | Imprecise^a^ | Undetected | Low for no benefit for various measures of practitioner competence/skills

a Small sample size/number of events; CIs cross the line of no difference.

CI = confidence interval; EBP = evidence=based practice; p = p-value.

Table F-2 Protocol to train nurses to educate parents about EBPs versus typical services: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Patient: Access to care | 2; 172 parents/ caregivers in Study 1 (cohort study), 51 in Study 2 (RCT) | High | Consistent | Direct | Precise | Undetected | Low for benefit Strategy improved parent ratings of access to care (mean difference between groups ranged from 0.08 to 2.1 points in Study 1 and 0.6 to 1.9 in Study 2)
Intermediate outcome: Patient: satisfaction | 2; 172 parents/ caregivers in Study 1 (cohort study), 51 in Study 2 (RCT) | High | Consistent | Direct | Precise | Undetected | Low for benefit Strategy improved parent ratings of satisfaction of care by a mean of 0.4 in Study 1 and 0.9 in Study 2
Intermediate outcome: Patient: Treatment engagement | 2; 172 parents/ caregivers in Study 1 (cohort study), 51 in Study 2 (RCT) | High | Consistent | Direct | Precise | Undetected | Low for benefit Strategy improved parent ratings of treatment engagement by a mean of 0.9 in Study 1 and 2.5 in Study 2
Intermediate outcome: Patient: Therapeutic alliance with practitioner | 2; 172 parents/ caregivers in Study 1 (cohort study), 51 in Study 2 (RCT) | High | Consistent | Direct | Precise | Undetected | Low for benefit Strategy improved parent ratings of therapeutic alliance by a mean of 0.4 in Study 1 and 0.9 in Study 2

EBP = evidence-based practice; RCT = randomized controlled trial.

Table F-3 Professional training to identify and refer cases versus usual care: Strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Patient: Access to care | 1; 110 practices, 79 patients | High | Unknown (single study) | Direct | Imprecise^a^ | Undetected | Insufficient RR of referral to early intervention: 1.20 95% CI, 0.74 to 1.95 p=0.48
Final outcome: Change in mental health status | 1; 158 patients for detainment under Mental Health Act, 83 patients for recovery | High | Unknown (single study) | Direct | Imprecise^a^ | Undetected | Insufficient Patients in the professional training group did not have significant differences in change in mental health symptoms
Final outcome: Service utilization | 1: 68 patients for number of consultations in primary care following the strategy and duration of untreated psychosis and delay in reaching early-intervention services | High | Unknown (single study) | Direct | Precise | Undetected | Low for benefit Patients in the professional training group averaged 223.8 fewer days for time from the first decision to seek care to the point of referral to an early-intervention service than patients in the control group

a Small sample size/number of events; CIs cross the line of no difference.

CI = confidence interval; p = p-value; RR = relative risk.

Table F-4 Professional training plus feedback to implement an EBP intervention versus professional training only to implement an EBP intervention versus control: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Final outcome: Change in mental health status | 1; 511 patients | Medium | Unknown (single study) | Direct | Precise | Undetected | Low for no benefit for both comparisons (CP-TF vs control and CP-BT vs control) CP-TF and CP-BT groups had fewer behavioral problems as rated by teachers (beta=−0.41, SE=0.16, p=0.01). There were no significant differences in teacher ratings of behavioral problems for the CP-BT vs. comparison groups or for any comparisons of behavioral problems as rated by parents.
Final outcome: Change in socialization skills and behavior | 1; 511 patients | Medium | Unknown (single study) | Direct | Precise | Undetected | Low for benefit (CP-TF vs. control) CP-TF had fewer minor assaults as reported by the child (beta=−0.25, SE=0.12, p=0.03) and social/academic competence as reported by the teacher (beta=0.35, SE=0.13, p=0.01) as compared with comparison groups. Low for no benefit (CP-BT vs. control) Minor assaults and social/academic competence did not significantly differ for the CP-BT vs. comparison groups.

CP-BT = Coping Power-Basic Training; CP-TF = Coping Power-Training plus Feedback; EBP = evidence-based practice; p = p-value; SE = standard error.

Table F-5 Patient MMTP for practitioners versus usual care: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Practitioner adherence | 1; 2,376 patients | High | Unknown (single study) | Direct | Precise | Undetected | Low for benefit 38.3% of patients had MMT in the charts after program implementation; drop in the prevalence of SGA prescribing from 15.4% in the pre-MMTP period to 6.4% in the post-MMTP period (p<0.001)
Patient health and service utilization outcomes: Service utilization | 1; 253 patients (82 before, 171 after) | High | Unknown (single study) | Direct | Precise | Undetected | Low for benefit Increased metabolic monitoring over time (level of change varies by type of monitoring)

MMT = monitoring and documentation tool; MMTP = Metabolic Monitoring Training Program; p = p-value; SGA = second-generation antipsychotic.

Table F-6 Increasing intensity of a practitioner training strategy to improve implementation of an EBP intervention: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Practitioner adherence to CBT and monitoring techniques | 1; 161 practitioners from 10 agencies | Medium | Consistent | Direct | Imprecise | Undetected | Insufficient
Intermediate outcome: Practitioner CM knowledge competence/skills | 1; 161 practitioners from 10 agencies | Medium | Consistent | Direct | Imprecise | Undetected | Insufficient
Intermediate outcome: System uptake CM use by practitioner | 1; 161 practitioners from 10 agencies | Medium | Consistent | Direct | Precise | Undetected | Insufficient

CBT = cognitive behavioral therapy; CM = contingency management; EBP = evidence-based practice.

Table F-7 Internet portal providing practitioner access to practice guidelines versus wait-list control: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Practitioner—Protocol adherence/program model fidelity | 1; 746 patients | Medium | Unknown (single study) | Direct | Imprecise^a^ | Undetected | Low for benefit Strategy appeared to improve 4 of 5 examined outcomes that measured practitioner protocol adherence/program model fidelity outcomes (mean change in proportion of patients who received targeted, evidence-based ADHD care outcomes between groups ranged from 16.6 to −50), but estimates were very imprecise, with large CIs

a Wide CIs.

Table F-8 Weekly and cumulative 90-day feedback of patient symptoms and functioning to practitioners versus cumulative 90-day feedback of patient symptoms and functioning to practitioners only: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Practitioner adherence | 1; N of practitioners unclear | High | Unknown (single study) | Direct | Unknown^a^ | Undetected | Insufficient Two-thirds did not view web modules
Patient health and service utilization outcomes: Functional severity | 1; 340 youth,144 clinicians, 383 caregivers | High | Unknown (single study) | Direct | Precise | Undetected | Low for benefit Membership in the weekly feedback group increased the rate of decline in symptoms and functioning severity scale by 0.01

a Precision cannot be calculated without N of practitioners.

N = number.

Table F-9 Computer decision support plus EHR that included diagnosis and treatment guidelines versus computer decision support plus EHR only: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Practitioner adherence of completing a diagnostic assessment prior to making diagnosis | 1; 84 patients (4 practices) | Medium | Unknown (single study) | Direct | Imprecise^a^ | Undetected | Low for benefit^b^ Adjusted OR: OR, 8.0; 95% CI, 1.6 to 40.6
Intermediate outcome: Practitioner adherence through reassessment of symptoms at 3 months, adjustment of medications, mental health referral | 1; 84 patients (4 practices) | Medium | Unknown (single study) | Direct | Imprecise^b^ | Undetected | Insufficient No statistically significant improvement on any measure
Intermediate outcome: Practitioner adherence through measuring ADHD symptoms at diagnosis | 1; 84 patients (4 practices) | Medium | Unknown (single study) | Direct | Imprecise^c^ | Undetected | Low for benefit More reporting of 3 of 4 symptom domains p<0.05
Final health outcome: Service utilization (visit to mental health specialist) | 1; 84 patients (4 practices) | Medium | Unknown (single study) | Direct | Imprecise^d^ | Undetected | Insufficient Calculated OR: 2.195; 95% CI, 0.909 to 5.303; p=0.081, reported p-value in study=0.054

a Small sample size/number of events; wide CIs.

b Large magnitude of effect.

c Small sample size/number of events.

d Small sample size/number of events; CIs cross the line of no difference.

ADHD = attention deficit hyperactivity disorder; CI = confidence interval; EHR = electronic health record; OR = odds ratio p = p-value.

Table F-10 IQA system versus workshop only to implement an EBP intervention: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Practitioner adherence to CBT and monitoring techniques | 1; 30 practitioners, N of caregiver and patient reports and monthly data points NR | High | Unknown (single study) | Direct | Imprecise^a^ | Undetected | Insufficient Study does not provide sufficient detail to judge magnitude of effect

a Small sample size/number of events, CIs cannot be calculated.

CBT = cognitive behavioral therapy; EBP = evidence-based practice; IQA = intensive quality assurance; N = number; NR = not reported.

Table F-11 Collaborative consultation treatment service to promote the use of titration trials and periodic monitoring during medication management versus control: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Practitioner adherence | 1; 38 practitioners | High | Unknown (single study) | Indirect | Imprecise^a^ | Undetected | Insufficient Interaction for uptake of titration trials β=−0.283; SE, 0.09; p<0.01 Uptake of medication monitoring trials: p=NS, details NR
Intermediate outcome: Practitioner competency (cited obstacles to implementation of EBPs) | 1; 38 practitioners | High | Unknown (single study) | Indirect | Imprecise^a^ | Undetected | Insufficient Lower odds with overlapping confidence intervals of citing obstacles in 6 of 8 measures (2 reach statistical significance)
Patient health and service utilization outcomes: ADHD symptoms | 1; 144 patients | High | Unknown (single study) | Indirect | Imprecise^a^ | Undetected | Insufficient F score for decrease in combined parent and teacher ratings of ADHD symptoms for group × time interaction: F_2, 144_ = 0.44, p=0.65

a Small sample size/number of events.

ADHD = attention deficit hyperactivity disorder; EBP = evidence-based practice; NR = not reported; NS = not significant; p = p-value; SE = standard error.

Table F-12 Paying practitioners for performance in successful delivery of an EBP intervention versus IAU: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Practitioner: competence/skills | 1; 49 therapists and 936 patients | Medium | Unknown (single study) | Indirect | Precise | Undetected | Moderate for benefit Therapists in the P4P group were over twice as likely to demonstrate implementation competence than IAU therapists (event rate ratio=2.24; 95% CI, 1.12 to 4.48
Intermediate outcome: Practitioner: adherence/program fidelity | 1; 49 therapists and 936 patients | Medium | Unknown (single study) | Indirect | Imprecise | Undetected | Low for benefit Patients in the P4P condition were over 5 times as likely to meet target implementation standards (i.e., to receive specific numbers of treatment procedures and sessions) as IAU patients (OR, 5.19; 95% CI, 1.53 to 17.62) but confidence intervals were wide.
Final outcome: Change in mental health status | 1; 600 | Medium | Unknown (single study) | Direct | Precise | Undetected | Low for no benefit Patients in the P4P condition did not have significantly different rates of remission at end of treatment than patients in the IAU condition

CI = confidence interval; EBP = evidence-based practice; IAU = implementation-as-usual control condition; OR = odds ratio; P4P = pay for performance.

Table F-13 Program to improve organizational culture and climate versus usual care: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Practitioner adherence to MST (therapist and supervisor) | 1; 598 youth and 297 therapists | Medium | Unknown (single study) | Direct | NR | Undetected | Low for no benefit Does not demonstrate significant improvement in any measure of adherence by ARC group (any ARC vs. no ARC)
Intermediate outcome: Practitioner satisfaction/acceptability | 1; 197 practitioners in 26 programs | Medium | Unknown (single study) | Direct | Imprecise^a^ | Undetected | Low for benefit Trends toward improvement in all domains, but nonoverlapping CI for only some domains (ARC vs. usual care)
Patient mental health symptoms: Out-of-home placement and child behavior problem scores at 18 months | 1; 567 caregivers, 615 youth | Medium | Unknown (single study) | Direct | Precise | Undetected | Low for no benefit Difference in out of home placements between ARC only and usual care groups did not meet statistical significance (p=0.05) and no difference across arms (ARC only vs usual care) in behavior problem scores
Patient mental health symptoms: Child behavior problem scores each for 6 months (after organization completed 18 month implementation of program) | 1; 352 caregivers of youth ages 5–18 in 18 programs | Medium | Unknown (single study) | Direct | Imprecise^b^ | Undetected | Low for benefit. Lower problem behavior scores for youth in the ARC group vs. usual care

a Small sample size/number of events; CIs cross the line of no difference for some domains.

b Small sample size/number of events; CIs cross the line of no difference for some domains.

ARC = Availability, Responsiveness and Continuity; CI = confidence interval; MST = multisystemic therapy; NR = not reported.

Table F-14 Colocation of an EBP program in primary care versus enhanced referral to an EBP program: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Patient access to care (attending first Triple P visit) | 1; 4 pediatric practices, 20,917 children with primary care visits | High | Unknown (single study) | Direct | Precise | Unclear | Low for benefit OR, 3.10; 95% CI, 1.63 to 5.89
Patient health and service utilization outcomes: service utilization-mean number of session attended | 1; 4 pediatric practices, 20,917 children with primary care visits | High | Unknown (single study) | Direct | Imprecise | Unclear | Insufficient Mean difference=−1.01; 95% CI, −2.60 to 0.58

CI = confidence interval; EBP = evidence-based practice; OR = odds ratio; Triple P = Positive Parenting Program.

Table F-15 Implementation of an EBP by pediatricians versus by embedded BHCPs: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Practitioner adherence (assessment) to SBIRT | 1; 1,255 patients of 30 pediatricians | Medium | Unknown (single study) | Direct | NR | Undetected | Low for no benefit No significant differences in substance use assessment between study arms (aOR, 0.93; 95% CI, 0.72 to 1.21)
Intermediate outcome: Practitioner adherence (brief intervention) to SBIRT | 1; 1,255 patients of 30 pediatricians | Medium | Unknown (single study) | Direct | NR | Undetected | Low for benefit BHCP group patients more likely to receive brief intervention than pediatrician-only group (aOR, 1.74; 95% CI, 1.31 to 2.31)
Intermediate outcome: Practitioner adherence (referral to treatment) to SBIRT | 1; 1,255 patients of 30 pediatricians | Medium | Unknown (single study) | Direct | NR | Undetected | Low for benefit BHCP group patients less likely to receive brief intervention than pediatrician-only group (aOR, 0.58; 95% CI, 0.43 to 0.78)

aOR = adjusted odds ratio; BHCP: Behavioral Health Care Provider; CI = confidence interval; EBP = evidence-based practice NR = not reported; SBIRT = Screening, Brief Intervention, and Referral to Treatment.

Table F-16 Harms associated with professional training to identify and refer cases versus usual care: Detailed strength of evidence

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Intermediate outcome: Patient side effects | 1; 110 practices, 179 patients | High | Unknown (single study) | Direct | Unknown^a^ | Undetected | Insufficient No adverse events were reported, no significant between-group differences for false-positive referral rates from primary care

a Insufficient data to calculate precision.

Table F-17 Intensity of the strategy as a moderator of the effectiveness of the strategy: Detailed strength of evidence (intermediate outcomes)

Moderator and Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Training intensity: Patient access to care (G1: Professional training plus feedback to implement an EBP intervention, G2: Professional training only to implement an EBP intervention, G3: Control) | 1; 511 patients | High | Unknown (single study) | Direct | Precise | Undetected | Low for benefit More intensive training led to improved access-to-care ratings (sessions scheduled) for both children and for parents
Training intensity: Patient treatment engagement (G1: Professional training plus feedback to implement an EBP intervention, G2: Professional training only to implement an EBP intervention, G3: Control) | 1; 511 patients | High | Unknown (single study) | Direct | Precise | Undetected | Low for no benefit More intensive training associated with no differences in child or parent sessions attended or parent ratings of treatment engagement, although treatment engagement for child rated higher for more intensive training group
Training intensity practitioner protocol adherence and program fidelity (G1: Professional training plus feedback to implement an EBP intervention; G2: Professional training only to implement an EBP intervention; G3: Control) | 1; 511 patients | High | Unknown (single study) | Direct | Precise | Undetected | Low for no benefit More intensive training did not lead to significant differences in mean numbers of strategy objectives completed but did lead to increases in the numbers of contacts between practitioners and trainers in the CP-TF group

CP-TF = Coping Power-Training plus Feedback; EBP = evidence-based practice; G = group.

Table F-18 Intensity of the strategy as a moderator of the effectiveness of the strategy: Detailed strength of evidence (patient health and service utilization outcomes)

Moderator and Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Training intensity: Mental health symptoms (G1: Professional training plus feedback to implement an EBP intervention; G2: Professional training only to implement an EBP intervention; G3: Control) | 1; 511 patients | High | Unknown (single study) | Direct | Precise | Undetected | Low for benefit More intensive training associated with greater improvements in mental health symptoms
Training intensity: Mental health symptoms and functional status (G1: Weekly and cumulative 90-day feedback on patient symptoms and functioning to practitioners; G2: Cumulative 90-day feedback on patient symptoms and functioning to practitioners only) | 1; N of practitioners unclear | High | Unknown (single study) | Direct | Unknown | Undetected | Insufficient Effect sizes for child and parent ratings of symptoms and functional status improved significantly in the more intensive training group but precision is unknown and study limitations are high
Training intensity: Mental health symptoms (G1a: Patients whose physicians did conduct a titration trial as part of a collaborative consultative treatment service to promote the use of titration trials and periodic monitoring during medication management program G1b: Patients whose physicians did not conduct a titration trial as part of a collaborative consultative treatment service to promote the use of titration trials and periodic monitoring during medication management program G2: Control) | 1; 144 patients | High | Unknown (single study) | Indirect | Unknown | Undetected | Insufficient Unknown precision and high study limitations

EBP = evidence-based practice; G = group; N = number.

Table F-19 Detailed strength of evidence for moderating effect of fidelity to EBP in P4P

Outcome | Number of Studies; Subjects | Study Limitations | Consistency | Directness | Precision | Reporting Bias | Strength of Evidence Grade Magnitude of Effect
Final outcome: mental health symptoms (G1: Paying practitioners for performance (P4P) for successfully delivering an EBP intervention (A-CRA) G2: Implementation of an EBP intervention (A-CRA) as usual) | 1; 600 | Medium | Unknown (single study) | Direct | Precise | Undetected | Low for no benefit There was not a significant moderating effect of fidelity to EBP (meeting target A-CRA) on the association between treatment group and patient remission status (p=0.37)

A-CRA = Adolescent Community Reinforcement Approach; EBP = evidence-based practice; p = p-value; P4P = pay for performance.