# Appendix E Forest Plots

Figure E-1 Blood work measures (Ronsley et al., 2012)

ALT = Aspartate aminotransferase; AST = Alanine aminotransferase; CI = confidence interval; LDL-C = Low density lipoprotein – cholesterol; HDL-C = High density lipoprotein – cholesterol; MMTP = Metabolic Monitoring Training Program; TGs =Triglycerides

Appendix E, Figure E-1 is titled “Blood work measures (Ronsley et al., 2012).” The figure displays a forest plot reporting the odds ratio on various blood work measures including alanine aminotransferase (ALT) or aspartate aminotransferase (AST), fasting glucose, insulin, low-density lipoprotein cholesterol (LDL-C) or high-density lipoprotein cholesterol (HDL-C), Prolactin, triglycerides (TGs), and total cholesterol, metabolic monitoring training program (MMTP) versus usual care across several time periods. For the outcome of ALT or AST the odds ratio was 6.298 (95% CI 3.352 to 11.830, p =0.000) at baseline; 2.852 (95% CI 1.240 to 6.559, p =0.014) at 3 months; 2.918 (95% CI 1.337 to 6.369, p =0.007) at 6 months; 2.237 (95% CI 0.958 to 5.223, p =0.063) at 12 months. For the outcome of fasting glucose, the odds ratio was 6.255 (95% CI 3.374 to 11.596, p =0.000) at baseline; 2.713 (95% CI 1.247 to 5.905, p =0.012) at 3 months; 3.280 (95% CI 1.472 to 7.308, p =0.004) at 6 months; 3.634 (95% CI 1.577 to 8.374, p =0.002) at 12 months. For the outcome of insulin, the odds ratio was 9.057 (95% CI 4.134 to 19.842, p =0.00) at baseline; 4.537 (95% CI 1.724 to 11.947, p =0.002) at 3 months; 26.121(95% CI 4.435 to 153.845, p =0.000) at 6 months; 66.293 (95% CI 3.883 to 1131.886, p =0.004) at 12 months. For the outcome of LDL-C or HDL-C, the odds ratio was 6.922 (95% CI 3.556 to 13.474, p =0.00) at baseline; 3.043 (95% CI 1.235 to 7.499, p =0.016) at 3 months; 4.633(95% CI 1.882 to 11.408, p =0.001) at 6 months; 6.862 (95% CI 2.445 to 19.256, p =0.000) at 12 months. For the outcome of prolactin, the odds ratio was 7.513 (95% CI 3.308 to 17.059, p =0.00) at baseline; 5.049 (95% CI 2.262 to 11.272, p =0.000) at 12 months. For the outcome of TGs, the odds ratio was 6.027 (95% CI 3.181 to 11.418, p =0.00) at baseline; 3.209 (95% CI 1.364 to 7.550, p =0.008) at 3 months; 3.926(95% CI 1.658 to 9.296, p =0.002) at 6 months; 7.380 (95% CI 2.648 to 20.566, p =0.000) at 12 months. For the outcome of total cholesterol, the odds ratio was 7.368 (95% CI 3.896 to 13.933, p =0.000) at baseline; 3.209 (95% CI 1.364 to 7.550, p =0.008) at 3 months; 3.672(95% CI 1.613 to 8.360, p =0.002) at 6 months; 7.380 (95% CI 2.648 to 20.566, p =0.000) at 12 months.

Figure E-2 Anthropometric outcomes (Ronsley et al., 2012)

CI = confidence interval; MMTP = Metabolic Monitoring Training Program; WC = weight control.

Appendix E, Figure E-2 is titled “Anthropometric outcomes (Ronsley et al., 2012).” The figure displays a forest plot reporting the odds ratio on various anthropometric outcomes including blood pressure, height, waist circumference (WC), and weight, metabolic monitoring training program (MMTP) versus usual care across several time periods. For the outcome of blood pressure, the odds ratio was 4.812 (95% CI 2.414 to 9.591, p =0.000) at baseline; 4.849(95% CI 1.979 to 11.882, p =0.001) at 3 months; 7.717(95% CI 2.780 to 21.419, p =0.000) at 6 months; 7.380 (95% CI 2.648 to 20.566, p =0.000) at 12 months. For the outcome of height, the odds ratio was 4.873 (95% CI 2.621 to 9.060, p =0.000) at baseline; 5.222(95% CI 2.333 to 11.687, p =0.000) at 3 months; 5.418(95% CI 2.464 to 11.911, p =0.000) at 6 months; 9.126 (95% CI 2.648 to 31.030, p =0.000) at 12 months. For the outcome of WC, the odds ratio was 11.292 (95% CI 3.643 to 35.000, p =0.000) at baseline; 18.252(95% CI 2.679 to 124.377, p =0.003) at 3 months; 37.468(95% CI 2.125 to 660.641, p =0.013) at 6 months; 50.908 (95% CI 2.944 to 880.205, p =0.007) at 12 months. For the outcome of weight, the odds ratio was 4.882 (95% CI 2.724 to 8.752, p =0.000) at baseline; 3.355(95% CI 1.762 to 6.388, p =0.000) at 3 months; 3.204(95% CI 1.670 to 6.146, p =0.000) at 6 months; 3.466 (95% CI 1.401 to 8.570, p =0.007) at 12 months.

Figure E-3 Obstacles preventing implementation (Epstein et al., 2007)

CI = confidence interval

Appendix E, Figure E-3 is titled “Obstacles preventing implementation (Epstein et al., 2007).” The figure displays a forest plot reporting the odds ratio on several obstacles that prevent implementation, collaborative consultative service versus control. The odds ratio of concern about parental interest in medication monitoring was 0.542 (95% CI 0.105 to 2.798, p =0.465) comparing physicians who received the collaborative consultative service intervention to controls. The odds ratio of concern about parental interest in titration trials was 0.757 (95% CI 0.163 to 3.510, p =0.722) comparing physicians who received the collaborative consultative service intervention to controls. The odds ratio of lack of access to medications packaged for titration was 0.252 (95% CI 0.064 to 0.985, p =0.048) comparing physicians who received the collaborative consultative service intervention to controls. The odds ratio of lack of knowledge about how to conduct trials was 0.150 (95% CI 0.013 to 1.722, p =0.128) comparing physicians who received the collaborative consultative service intervention to controls. The odds ratio of lack of knowledge about interpretation was 0.827 (95% CI 0.112 to 6.106, p =0.852) comparing physicians who received the collaborative consultative service intervention to controls. The odds ratio of lack of knowledge about logistics was 0.942 (95% CI 0.196 to 4.530, p =0.941) comparing physicians who received the collaborative consultative service intervention to controls. The odds ratio of lack of time for medication monitoring was 0.352 (95% CI 0.056 to 2.200, p =0.264) comparing physicians who received the collaborative consultative service intervention to controls. The odds ratio of lack of time for titration trials was 0.164 (95% CI 0.028 to 0.971, p =0.046) comparing physicians who received the collaborative consultative service intervention to controls.