# Appendix D Risk of Bias Assessment of Included Studies

Table D-1 Risk of bias assessment for strategies to improve mental health care for children and adolescents

First Author, Year | Were eligibility criteria described clearly? | Are the inclusion/exclusion criteria measured using valid and reliable measures, implemented across all study participants? | Was symptom status of subjects determined using valid and reliable methods? | Was the intervention or exposure clearly defined, across all study participant | Was randomization adequate? | Was allocation concealment adequate? | Did strategy for recruiting participants into the study the same across study groups?
Beidas et al., 2012^1^ | Yes | Yes | NA | Yes | Yes (randomization by date) | Yes | NA
Bickman et al., 2011^2^ | Yes | Yes for sites; No for providers/patients | NA | Yes | Unclear | Unclear | NA
Carroll et al., 2013^3^ | No for clinics; Yes for patients | Yes for sites; No for clinicians or patients | NA | Yes | No for clinics; Yes for patient chart selection within clinics | Unclear | NA
Epstein et al., 2007^4^ | Yes | Yes | NA | Yes | Unclear | Unclear | NA
Epstein et al., 2011^5^ | Yes | Yes | NA | Yes | Yes | Yes | NA
Garner et al., 2012^6^ | Yes | Yes | NA | Yes | Yes | Yes | NA
Glisson et al., 2012^7^ Glisson et al., 2013 ^8^ | Yes | Yes | NA | Yes | Yes | Unclear | NA
Glisson et al., 2010^9^ | Yes | Yes for sites; no for clinicians or patients | NA | NA | Unclear for counties, yes for patients | Unclear for counties, yes for patients | NA
Gully et al., 2008^10^ (study 1) | Yes | Yes | NA | Yes | NA | NA | NA
Gully et al., 2008^10^ (study 2) | Yes | Yes | NA | Yes | Unclear | Unclear | NA
Henggeler et al., 2008^11^ | No | Unclear | NA | Yes | NA | NA | NA
Henggeler et al., 2013^12^ | No | NA | NA | Yes | Unclear | Unclear | NA
Lester et al., 2009^13^ | Yes | Yes | NA | Yes | Yes | Yes | NA
Lochman et al., 2009^14^ | Yes | Yes | NA | Yes | Unclear | Unclear | NA
Ronsley et al., 2012^15^ | Yes | Yes | NA | Yes | NA | NA | Yes
Wildman et al., 2012^16^ | No for the clinics, no patients | No for the clinics, no patients | NA | Yes | NA (unclear that all clinics were randomized) | NA | NA

NA = not applicable.

Table D--2 Risk of bias assessment for strategies to improve mental health care for children and adolescents

First Author, Year | Do start of follow-up and start of intervention coincide? | Are baseline characteristics similar between groups? | Did the study control for baseline differences between groups? | Were participants and the administrators of the intervention blinded to the intervention or exposure status of participants? | Were the outcome assessors blinded?
Beidas et al., 2012^1^ | NA | Unclear | NA | Not possible for participants | Yes
Bickman et al., 2011^2^ | NA | NR by site, similar for patients, caregivers and clinicians | No | Not possible for clinicians; unclear for patients | Unclear
Carroll et al., 2013^3^ | NA | Unclear for clinics, control arm has a higher proportion of black and Medicaid patients | No | Not possible for clinicians; unclear for patients | Unclear
Epstein et al., 2007^4^ | NA | Yes | NA | No | Yes
Epstein et al., 2011^5^ | NA | Unclear | No | Not possible for clinicians; unclear for patients | Unclear
Garner et al., 2012^6^ | NA | Yes | NA | Not possible for clinicians,; unclear for patients | Unclear
Glisson et al., 2012^7^ Glisson et al., 2013^8^ | NA | Unclear | Yes | Not possible for clinicians; unclear for patients | Yes
Glisson et al., 2010^9^ | NA | Yes for counties, unclear for patients | No | Not possible for clinicians, unclear for patients | Unclear
Gully et al., 2008^10^ (study 1) | Yes | Yes | NA | No | No
Gully et al., 2008^10^ (study 2) | NA | No | Yes | No | No
Henggeler et al., 2008^11^ | Yes | No, WSO therapists older than IQA | No | Not possible for clinicians, unclear for patients | Unclear
Henggeler et al., 2013^12^ | NA | No | No | Unclear | Unclear
Lester et al., 2009^13^ | NA | No | No | Yes for patients | Yes
Lochman et al., 2009^14^ | Yes | Unclear | No | Not possible for counselors, unclear for patients | Unclear
Ronsley et al., 2012^15^ | No | Yes | No | NA | Unclear
Wildman et al., 2012^16^ | Unclear | No, colocation parents likely to be older. Colocation parents less likely to be employed. | No | No | Unclear

NA = not applicable.

Table D--3 Risk of bias assessment for strategies to improve mental health care for children and adolescents

First author, Year | Were outcome assessors blinded to the exposure? | Was intervention fidelity adequate? | Was there a risk of recall bias? | Did the study focus on the time period that we are interested in? | Did researchers rule out any impact from a concurrent intervention or an unintended exposure that might bias results?
Beidas et al., 2012^1^ | NA | Yes | No | Yes | No
Bickman et al., 2011^2^ | NA | Unclear | No | Yes | Unclear
Carroll et al., 2013^3^ | NA | Unclear | No | Yes | Unclear
Epstein et al., 2007^4^ | NA | No | No | Yes | Unclear
Epstein et al., 2011^5^ | NA | NA (adherence varies, fidelity NA because intervention portal available) | No | Yes | Unclear
Garner et al., 2012^6^ | NA | Yes | No | Yes | Unclear
Glisson et al., 2012^7^ Glisson et al., 2013^8^ | NA | Yes | No | Yes | Unclear
Glisson et al., 2010^9^ | NA | Unclear, but similar across arms when measured (some tapes were missing) | No, except for out-of-home placement (based on caregiver recall) | Yes | Unclear
Gully et al., 2008^10^ (study 1) | NA | Unclear | No | Yes | No
Gully et al., 2008^10^ (study 2) | NA | Unclear | No | Yes | No
Henggeler et al., 2008^11^ | NA | Unclear | No | Yes | Unclear
Henggeler et al., 2013^12^ | No | Unclear | Yes | Yes | No
Lester et al., 2009^13^ | NA | Unclear | No | Yes | No (recruitment was in 3 waves as practices opened in the city)
Lochman et al., 2009^14^ | NA | Unclear | No | Yes | Unclear
Ronsley et al., 2012^15^ | NA | Unclear | No | Yes | Unclear
Wildman et al., 2012^16^ | NA | Unclear | No | Yes | Unclear

NA = not applicable.

Table D--4 Risk of bias assessment for strategies to improve mental health care for children and adolescents

First Author, Year | Did variation from the study protocol compromise the conclusions of the study? | What was the overall attrition?/What was the overall response rate? | What was the overall differential attrition? | Did the study have high attrition or low response rate raising concern for bias? | Is the analysis conducted on an intention-to-treat (ITT) basis?
Beidas et al., 2012^1^ | Unclear | 2% attrition at posttraining; 3% at follow-up assessment | Unclear but <5% | No | Yes (some outcomes)
Bickman et al., 2011^2^ | Unclear | 43% of sites | G1: (45.8%) 11/24 sites G2: (38.4%) 10/26 sites Differential attrition: 7.4% | Yes | No
Carroll et al., 2013^3^ | Unclear | 0 clinics dropped out, patient dropout rate NA because of retrospective selection of charts | NA | NA | NA
Epstein et al., 2007^4^ | Unclear | 100% had at least some missing data | Clinics: 0; Providers: G1: 64 % (16/25) G2: 81.5% (22/27); Differential attrition: 17.5; Patients differential attrition: 0 because of 100 partial or full attrition in both arms (Of 146 participants selected for follow-up, 45 had data from all 3 data points. The remaining 101 participants had at least 1 missing data point.) | Yes | Yes
Epstein et al., 2011^5^ | No | NA (retrospective electronic; chart review) | NA | NA | NA
Garner et al., 2012^6^ | No | organizations 0%, therapist competence ratings 19%, patient targets 20%, patient remission status 49% | 1.7% for therapists, 0.4% for patient targets, 7.5% for patient remission | Yes | Yes
Glisson et al., 2012^7^ Glisson et al., 2013 ^8^ | Unclear | 2 control sites found ineligible after randomization and replaced. All 26 programs retained, loss to followup in clinicians Unclear | Unclear | Unclear | No
Glisson et al., 2010^9^ | No | 23.3% at 6 month f/u; 38.1% for 12 month f/u | 4% at 6 month f/u; 6.7% at 12-month | Yes | No
Gully et al., 2008^10^ (study 1) | Unclear | 48% | 0% | Yes | NA
Gully et al., 2008^10^ (study 2) | Unclear | 41% attrition | 3% | Yes | No
Henggeler et al., 2008^11^ | Unclear | Unclear, 100% of therapists consented, but turnover (unspecified volume) of therapists occurred, and not all therapists referred patients to the study | Unclear | Unclear | No
Henggeler et al., 2013^12^ | Unclear | 100% completed baseline and postworkshop assessments. 96% of all CM use and implementation assessments were completed by telephone interview and 87% of CM knowledge assessments completed via paper/pencil forms returned via fax. Total of 22% attrition. | NR | No | Yes
Lester et al., 2009^13^ | Unclear | Appears to be 0 for primary outcome, secondary outcome: 111/179 | Unclear | Yes | No
Lochman et al., 2009^14^ | Unclear | 6% parents and 12% teacher ratings attrition | NR but not significant for some measures as reported in Methods | Some tests of differential attrition were significant | No
Ronsley et al., 2012^15^ | NA | NA (retrospective electronic and chart review) | NA | NA | NA
Wildman et al., 2012^16^ | Unclear | Unclear | Unclear | Unclear | NA

NA = not applicable.

Table D--5 Risk of bias assessment for strategies to improve mental health care for children and adolescents

First Author, Year | Did the analysis adjust for potential confounders? | Did the study have cross-overs or contamination raising concern for bias? | Were outcomes pre-specified/defined and adequately described? | Were outcome measures valid and reliable? | Were all important outcomes considered?
Beidas et al., 2012^1^ | NA | Unclear | Yes | Yes | Yes
Bickman et al., 2011^2^ | NA | Unclear | Yes | Yes | No
Carroll et al., 2013^3^ | NA | Unclear | Yes | Yes | Yes
Epstein et al., 2007^4^ | NA | Unclear | Yes | Yes | Yes
Epstein et al., 2011^5^ | NA | Unclear | Yes | Yes | Yes
Garner et al., 2012^6^ | NA | Unclear | Yes | Yes | Yes
Glisson et al., 2012^7^ Glisson et al., 2013^8^ | NA | NR | Yes | Yes | Yes
Glisson et al., 2010^9^ | NA | Unclear | Yes | Yes | Yes
Gully et al., 2008^10^ (study 1) | NA | Unclear | Yes | Unclear | Unclear
Gully et al., 2008^10^ (study 2) | NA | Unclear | Yes | Unclear | Unclear
Henggeler et al., 2008^11^ | NA | Unclear | Yes | Yes | Yes
Henggeler et al., 2013^12^ | NA | Unclear | Yes | Yes | Yes
Lester et al., 2009^13^ | NA | Unclear | Yes | Yes | Yes
Lochman et al., 2009^14^ | NA | Unclear | Yes | Yes | Yes
Ronsley et al., 2012^15^ | No | Unclear | Yes | Yes | Yes
Wildman et al., 2012^16^ | NA | Unclear | Yes | No | Yes

NA = not applicable.

Table D--6 Risk of bias assessment for strategies to improve mental health care for children and adolescents

First Author, Year | Was the duration of followup adequate to assess the outcome? | Was an appropriate method used to handle missing data? | Risk of Bias Rating | Comments
Beidas et al., 2012^1^ | Yes | NA | Low
Bickman et al., 2011^2^ | Unclear | NA | High | Initial design was a 2X2, but over 40% of the sites dropped out, leaving only a standard vs. control experiment. Access to data from missing sites was not available for an ITT analysis. Blinding of patients and outcome assessors unclear. Method of randomization, allocation concealment, fidelity to protocol, timing of outcome measurement also unclear
Carroll et al., 2013^3^ | Yes | NA | Unclear | Although study does not control for baseline differences in race and insurance status, these differences may not be relevant for main outcome
Epstein et al., 2007^4^ | Yes | NA | High | High attrition rate (although ITT was conducted) and low fidelity/adherence
Epstein et al., 2011^5^ | Yes | NA | Unclear | generally low of bias, but insufficient information on some criteria
Garner et al., 2012^6^ | Yes | NA | Medium | Study has high attrition rates (authors report no difference in baseline characteristics between intervention and control arms)
Glisson et al., 2012^7^ Glisson et al., 2013^8^ | Yes | NA | Unclear | Because 2 of 26 sites were found ineligible, they were replaced, but differences in baseline characteristics and controls for these potential differences were not described, so not possible to judge the effect of this alteration to the outcomes
Glisson et al., 2010^9^ | Yes | NA | Medium | Rate of attrition is over 20%; missing information on fidelity; recall bias for out-of-home placement; unclear outcome assessor blinding
Gully et al., 2008^10^ (study 1) | Yes | No | High | High attrition and no adjustment for missing data, potential for confounding through nonrandom assignment
Gully et al., 2008^10^ (study 2) | Yes | NA | High | High attrition and no adjustment for missing data
Henggeler et al., 2008^11^ | Yes | NA | Unclear | Insufficient information to judge risk of bias on most criteria. Potential for bias from unmeasured concurrent interventions and turnover in therapists
Henggeler et al., 2013^12^ | Yes | NA | Unclear | No information on randomization, allocation concealment, poor adherence in G3 arm
Lester et al., 2009^13^ | Yes | NA | High | High attrition rate for secondary outcomes
Lochman et al., 2009^14^ | Yes | NA | Unclear | Study has high attrition rates (authors report no difference in baseline characteristics between intervention and control arms)
Ronsley et al., 2012^15^ | Yes | Unclear | Unclear
Wildman et al., 2012^16^ | Yes | Unclear | High | Study results not adjusted for baseline differences and did not measure “differences in the cultures served by the practice, how the PCPs explained the program, and other patient, physician, and practice attributes.”

ITT = intent to treat; NA = not applicable.

## References for Appendix D

1 Beidas RS, Edmunds JM, Marcus SC, et al. (2012). Training and consultation to promote implementation of an empirically supported treatment: a randomized trial. Psychiatr Serv.
2 Bickman L, Kelley SD, Breda C, et al. (2011). Effects of routine feedback to clinicians on mental health outcomes of youths: results of a randomized trial. Psychiatr Serv.
3 Carroll AE, Bauer NS, Dugan TM, et al. (2013). Use of a computerized decision aid for ADHD diagnosis: a randomized controlled trial. Pediatrics.
4 Epstein JN, Rabiner D, Johnson DE, et al. (2007). Improving attention-deficit/hyperactivity disorder treatment outcomes through use of a collaborative consultation treatment service by community-based pediatricians: a cluster randomized trial. Arch Pediatr Adolesc Med.
5 Epstein JN, Langberg JM, Lichtenstein PK, et al. (2011). Use of an Internet portal to improve community-based pediatric ADHD care: a cluster randomized trial. Pediatrics.
6 Garner BR, Godley SH, Dennis ML, et al. (2012). Using pay for performance to improve treatment implementation for adolescent substance use disorders: results from a cluster randomized trial. Arch Pediatr Adolesc Med.
7 Glisson C, Hemmelgarn A, Green P, et al. (2012). Randomized trial of the Availability, Responsiveness, and Continuity (ARC) organizational intervention with community-based mental health programs and clinicians serving youth. J Am Acad Child Adolesc Psychiatry.
8 Glisson C, Hemmelgarn A, Green P, et al. (2013). Randomized trial of the Availability, Responsiveness and Continuity (ARC) organizational intervention for improving youth outcomes in community mental health programs. J Am Acad Child Adolesc Psychiatry.
9 Glisson C, Schoenwald SK, Hemmelgarn A, et al. (2010). Randomized trial of MST and ARC in a two-level evidence-based treatment implementation strategy. J Consult Clin Psychol.
10 Gully KJ, Price BL, Johnson MK. (2008). Increasing abused children’s access to evidence-based treatment: diffusion via parents as consumers. Child Maltreat.
11 Henggeler SW, Sheidow AJ, Cunningham PB, et al. (2008). Promoting the implementation of an evidence-based intervention for adolescent marijuana abuse in community settings: testing the use of intensive quality assurance. J Clin Child Adolesc Psychol.
12 Henggeler SW, Chapman JE, Rowland MD, et al. (2013). Evaluating training methods for transporting contingency management to therapists. J Subst Abuse Treat.
13 Lester H, Birchwood M, Freemantle N, et al. (2009). REDIRECT: cluster randomised controlled trial of GP training in first-episode psychosis. Br J Gen Pract.
14 Lochman JE, Boxmeyer C, Powell N, et al. (2009). Dissemination of the Coping Power program: importance of intensity of counselor training. J Consult Clin Psychol.
15 Ronsley R, Rayter M, Smith D, et al. (2012). Metabolic monitoring training program implementation in the community setting was associated with improved monitoring in second-generation antipsychotic-treated children. Can J Psychiatry.
16 Wildman BG, Langkamp DL. (2012). Impact of location and availability of behavioral health services for children. J Clin Psychol Med Settings.