# Appendix C Excluded Studies

X 1 | Wrong publication type (Editorials, Letters, Opinions, or Commentaries to the editor with no primary data, Nonsystematic Review articles)
X 2 | Wrong population (Population does not include health care systems, organizations, and providers; population does not provide care for children and adolescents with mental health problems and substance abuse disorders)
X 3 | Wrong or no comparator (Not usual care or other D/I/QI strategies)
X 4 | Wrong or no outcome (See Include/Exclude criteria for exceptions)
X 5 | Wrong setting (Settings not comparable with outpatient settings; In-patients or those in residential treatment or drug treatment program; incarcerated populations)
X 6 | Wrong geographical setting (Countries with human development index of low to high)
X 7 | Wrong Study Design (Case reports, case series)
X 8 | Wrong or no intervention (Non-D/I/QI strategies; interventions that do not target health care systems or providers to improve the quality of care for children and adolescents with mental health problems)
X 9 | Study size <50 subjects
X 10 | Wrong language

1 (1999). Moderators and mediators of treatment response for children with attention-deficit/hyperactivity disorder: the Multimodal Treatment Study of children with Attention-deficit/hyperactivity disorder. Arch Gen Psychiatry.
2 (1999). A 14-month randomized clinical trial of treatment strategies for attention-deficit/hyperactivity disorder. The MTA Cooperative Group. Multimodal Treatment Study of Children with ADHD. Arch Gen Psychiatry.
3 Conduct Problems Prevention Research Group. (1999). Initial impact of the Fast Track prevention trial for conduct problems: II. Classroom effects. J Consult Clin Psychol.
4 (1999). Therapeutic community effectiveness: a systematic international review of therapeutic community treatment for people with personality disorders and mentally disordered offenders (Structured abstract). Database of Abstracts of Reviews of Effects.
5 The Research Unit on Pediatric Psychopharmacology Anxiety Study Group. (2001). Fluvoxamine for the treatment of anxiety disorders in children and adolescents. N Engl J Med.
6 (2006). Parent-training/education programmes in the management of children with conduct disorders (Structured abstract). Health Technology Assessment Database.
7 (2007). Implementing CBT for traumatized children and adolescents after september 11: lessons learned from the Child and Adolescent Trauma Treatments and Services (CATS) Project. J Clin Child Adolesc Psychol.
8 (2010). Implementation of CBT for youth affected by the World Trade Center disaster: matching need to treatment intensity and reducing trauma symptoms. J Trauma Stress.
9 (2011). MMW Fortschr Med.
10 (2013). Singapore Health and Biomedical Congress, SHBC 2013. Annals of the Academy of Medicine Singapore.
11 Aalsma MC, Tong Y, Lane K, et al. (2012). Use of outpatient care by juvenile detainees upon community reentry: effects of mental health screening and referral. Psychiatr Serv.
12 Aarons GA, Sommerfeld DH. (2012). Leadership, innovation climate, and attitudes toward evidence-based practice during a statewide implementation. J Am Acad Child Adolesc Psychiatry.
13 Abrahamse ME, Junger M, Chavannes EL, et al. (2012). Parent–child interaction therapy for preschool children with disruptive behaviour problems in the Netherlands. Child and Adolescent Psychiatry and Mental Health.
14 Addis ME, Hatgis C, Cardemil E, et al. (2006). Effectiveness of cognitive-behavioral treatment for panic disorder versus treatment as usual in a managed care setting: 2-year follow-up. J Consult Clin Psychol.
15 Adi Y, Killoran A, Janmohamed K, et al. (2007). Systematic review of the effectiveness of interventions to promote mental wellbeing in children in primary education. Report 1: Universal approaches: non-violence related outcomes (Structured abstract). Database of Abstracts of Reviews of Effects: Title to be Checked.
16 Agius M, Shah S, Ramkisson R, et al. (2007). Three year outcomes of an early intervention for psychosis service as compared with treatment as usual for first psychotic episodes in a standard community mental health team. Preliminary results. Psychiatr Danub.
17 Ahuja AS, Crome I, Williams R. (2013). Engaging young people who misuse substances in treatment. Curr Opin Psychiatry.
18 Akinbami LJ, Cheng TL, Kornfeld D. (2001). A review of teen-tot programs: Comprehensive clinical care for young parents and their children. Adolescence.
19 Allison DB, Faith MS, Franklin RD. (1995). Antecedent exercise in the treatment of disruptive behavior: a meta-analytic review (Structured abstract). Clinical Psychology: Science and Practice.
20 Anderson Laurie M, Adeney Kathryn L, Shinn C, et al. (2012). Community coalition-driven interventions to reduce health disparities among racial and ethnic minority populations. Cochrane Database of Systematic Reviews.
21 Angelo C, Vittorio M, Anna M, et al. (2011). Cost-effectiveness of treating first-episode psychosis: five-year follow-up results from an Italian early intervention programme (Provisional abstract). Early Intervention in Psychiatry.
22 Araya R, Fritsch R, Spears M, et al. (2013). School intervention to improve mental health of students in Santiago, Chile: a randomized clinical trial. JAMA Pediatr.
23 Arnarson EO, Craighead WE. (2009). Prevention of depression among Icelandic adolescents. Behav Res Ther.
24 Arnarson EO, Craighead WE. (2011). Prevention of depression among Icelandic adolescents: a 12-month follow-up. Behav Res Ther.
25 Arnold LE, Chuang S, Davies M, et al. (2004). Nine months of multicomponent behavioral treatment for ADHD and effectiveness of MTA fading procedures. J Abnorm Child Psychol.
26 Arnold LE, Elliot M, Sachs L, et al. (2003). Effects of ethnicity on treatment attendance, stimulant response/dose, and 14-month outcome in ADHD. J Consult Clin Psychol.
27 Asarnow JR, Jaycox LH, Duan N, et al. (2005). Effectiveness of a quality improvement intervention for adolescent depression in primary care clinics: a randomized controlled trial. JAMA.
28 Asarnow JR, Jaycox LH, Tang L, et al. (2009). Long-term benefits of short-term quality improvement interventions for depressed youths in primary care. Am J Psychiatry.
29 Aseltine RH, DeMartino R. (2004). An outcome evaluation of the SOS Suicide Prevention Program. Am J Public Health.
30 Aseltine RH, James A, Schilling EA, et al. (2007). Evaluating the SOS suicide prevention program: a replication and extension. BMC Public Health.
31 Ashare RL, Hawk LW, Shiels K, et al. (2010). Methylphenidate enhances prepulse inhibition during processing of task-relevant stimuli in attention-deficit/hyperactivity disorder. Psychophysiology.
32 Asscher JJ, Dijkstra S, Stams GJJ, et al. (2014). Family group conferencing in youth care: characteristics of the decision making model, implementation and effectiveness of the Family Group (FG) plans. BMC Public Health.
33 Audrey S, Cordall K, Moore L, et al. (2004). The development and implementation of a peer-led intervention to prevent smoking among secondary school students using their established social networks. Health Educ J.
34 Audrey S, Holliday J, Campbell R. (2008). Commitment and compatibility: teachers’ perspectives on the implementation of an effective school-based, peer-led smoking intervention. Health Educ J.
35 August GJ, Lee SS, Bloomquist ML, et al. (2003). Dissemination of an evidence-based prevention innovation for aggressive children living in culturally diverse, urban neighborhoods: the Early Risers effectiveness study. Prev Sci.
36 Axberg U, Broberg AG. (2012). Evaluation of “the incredible years” in Sweden: the transferability of an American parent-training program to Sweden. Scand J Psychol.
37 Axelrad ME, Pendley JS, Miller DL, et al. (2008). Implementation of effective treatments of preschool behavior problems in a clinic setting. J Clin Psychol Med Settings.
38 Baandrup L, Allerup P, Lublin H, et al. (2010). Evaluation of a multifaceted intervention to limit excessive antipsychotic co-prescribing in schizophrenia out-patients. Acta Psychiatr Scand.
39 Baas KD, Wittkampf KA, van Weert HC, et al. (2009). Screening for depression in high-risk groups: prospective cohort study in general practice. Br J Psychiatry.
40 Bakken S, Haomiao J, Chen ES, et al. (2014). The Effect of a Mobile Health Decision Support System on Diagnosis and Management of Obesity, Tobacco Use, and Depression in Adults and Children. J Nurse Pract.
41 Barlow A, Mullany B, Neault N, et al. (2015). Paraprofessional-delivered home-visiting intervention for American Indian teen mothers and children: 3-year outcomes from a randomized controlled trial. Am J Psychiatry.
42 Barlow J. (1997). Systematic review of the effectiveness of parent-training programmes in improving behaviour problems in children aged 3–10 years: a review of the literature on parent-training programmes and child behaviour outcome measures (Structured abstract). Database of Abstracts of Reviews of Effects.
43 Barlow J, Davis H, McIntosh E, et al. (2007). Role of home visiting in improving parenting and health in families at risk of abuse and neglect: results of a multicentre randomised controlled trial and economic evaluation (Structured abstract). Arch Dis Child.
44 Barlow J, Johnston I, Kendrick D, et al. (2006). Individual and group-based parenting programmes for the treatment of physical child abuse and neglect. Cochrane Database Syst Rev.
45 Barnes TR, Paton C, Hancock E, et al. (2008). Screening for the metabolic syndrome in community psychiatric patients prescribed antipsychotics: a quality improvement programme. Acta Psychiatr Scand.
46 Barry CL, Busch SH. (2008). Caring for children with mental disorders: do state parity laws increase access to treatment?. J Ment Health Policy Econ.
47 Barwick MA, Schachter HM, Bennett LM, et al. (2012). Knowledge translation efforts in child and youth mental health: a systematic review. J Evid Based Soc Work.
48 Battjes RJ, Gordon MS, O’Grady KE, et al. (2004). Evaluation of a group-based substance abuse treatment program for adolescents. Journal of substance Abuse Treament.
49 Bayer J, Hiscock H, Scalzo K, et al. (2009). Systematic review of preventive interventions for children’s mental health: what would work in Australian contexts?. Aust N Z J Psychiatry.
50 Bayer JK, Rapee RM, Hiscock H, et al. (2011). Translational research to prevent internalizing problems early in childhood. Depress Anxiety.
51 Beach MC, Gary TL, Price EG, et al. (2006). Improving health care quality for racial/ethnic minorities: a systematic review of the best evidence regarding provider and organization interventions (Structured abstract). BMC Public Health.
52 Beardslee WR, Brent DA, Weersing VR, et al. (2013). Prevention of depression in at-risk adolescents: longer-term effects. JAMA Psychiatry.
53 Bearman SK, Ugueto A, Alleyne A, et al. (2010). Adapting cognitive-behavioral therapy for : Applying the deployment-focused model of treatment development and testing. Weisz JR, Kazdin AE, editors. Evidence-based psychotherapies for children and adolescents.
54 Bee P, Bower P, Byford S, et al. (2014). The clinical effectiveness, cost-effectiveness and acceptability of community-based interventions aimed at improving or maintaining quality of life in children of parents with serious mental illness: a systematic review (Provisional abstract). Health Technol Assess.
55 Bell RM, Ellickson PL, Harrison ER. (1993). Do drug prevention effects persist into high school? How project ALERT did with ninth graders. Prev Med.
56 Benbenishty R, Jedwab M, Chen W, et al. (2014). Predicting the decisions of hospital based child protection teams to report to child protective services, police and community welfare services. Child Abuse Negl.
57 Bender K, Tripodi SJ, Sarteschi C, et al. (2011). A meta-analysis of interventions to reduce adolescent cannabis use. Research on Social Work Practice.
58 Bensussen-Walls W, Saewyc EM. (2001). Teen-focused care versus adult-focused care for the high-risk pregnant adolescent: an outcomes evaluation (Structured abstract). Public Health Nurs.
59 Berger U, Wick K, Brix C, et al. (2011). Primary prevention of eating-related problems in the real world. Journal of public health.
60 Berger-Jenkins E, McCord M, Gallagher T, et al. (2012). Effect of routine mental health screening in a low-resource pediatric primary care population. Clin Pediatr (Phila).
61 Bickman L, Douglas SR, De Andrade AR, et al. (2015). Implementing a Measurement Feedback System: A Tale of Two Sites. Adm Policy Ment Health.
62 Bickman L, Kelley SD, Breda C, et al. (2011). Effects of routine feedback to clinicians on mental health outcomes of youths: results of a randomized trial. Psychiatric services (Washington, D.C.).
63 Bickman L, Summerfelt WT, Noser K. (1997). Comparative outcomes of emotionally disturbed children and adolescents in a system of services and usual care. Psychiatr Serv.
64 Birchwood M, Lester H, McCarthy L, et al. (2014). The UK national evaluation of the development and impact of Early Intervention Services (the National EDEN studies): study rationale, design and baseline characteristics. Early Interv Psychiatry.
65 Birdee GS, Yeh GY, Wayne PM, et al. (2009). Clinical applications of yoga for the pediatric population: a systematic review (Structured abstract). Acad Pediatr.
66 Bjorknes R, Manger T. (2013). Can parent training alter parent practice and reduce conduct problems in ethnic minority children? A randomized controlled trial. Prev Sci.
67 Blocher JB, Fujikawa M, Sung C, et al. (2013). Computer-assisted cognitive behavioral therapy for children with epilepsy and anxiety: a pilot study. Epilepsy Behav.
68 Boden R, Sundstrom J, Lindstrom E, et al. (2010). Five-year outcome of first-episode psychosis before and after the implementation of a modified assertive community treatment programme. Soc Psychiatry Psychiatr Epidemiol.
69 Bond GR, Witheridge TF, Dincin J, et al. (1990). Assertive community treatment for frequent users of psychiatric hospitals in a large city: a controlled study. Am J Community Psychol.
70 Bond L, Glover S, Godfrey C, et al. (2001). Building capacity for system-level change in schools: lessons from the Gatehouse Project. Health Educ Behav.
71 Bond L, Thomas L, Coffey C, et al. (2004). Long-term impact of the Gatehouse Project on cannabis use of 16-year-olds in Australia. J Sch Health.
72 Bonell CP, Sorhaindo AM, Allen EE, et al. (2010). Pilot multimethod trial of a school-ethos intervention to reduce substance use: building hypotheses about upstream pathways to prevention. The Journal of adolescent health : official publication of the Society for Adolescent Medicine.
73 Bonin EM, Stevens M, Beecham J, et al. (2011). Costs and longer-term savings of parenting programmes for the prevention of persistent conduct disorder: a modelling study (Structured abstract). BMC Public Health.
74 Bostic JQ, Rubin DH, Prince J, et al. (2005). Treatment of depression in children and adolescents. J Psychiatr Pract.
75 Botvin G, Baker E, Dusenbury L, et al. (1990). Preventing adolescent drug abuse through a multimodal cognitive behavioural approach: results of a 3 year study. J Consult Clin Psychol.
76 Botvin GJ, Baker E, Dusenbury L, et al. (1995). Long-term follow-up results of a randomized drug abuse prevention trial in a white middle-class population. JAMA.
77 Botvin GJ, Baker E, Dusenbury L, et al. (1990). Preventing adolescent drug abuse through a multimodal cognitive-behavioral approach: results of a 3-year study. J Consult Clin Psychol.
78 Botvin GJ, Baker E, Filazzola AD, et al. (1990). A cognitive-behavioral approach to substance abuse prevention: one-year follow-up. Addict Behav.
79 Botvin GJ, Baker E, Renick NL, et al. (1984). A cognitive-behavioral approach to substance abuse prevention. Addict Behav.
80 Botvin GJ, Griffin KW. (2001). Life Skills Training: Theory, methods, and effectiveness of a drug abuse prevention approach. Wagner EF, Waldron HB, editors. Innovations in adolescent substance abuse interventions.
81 Botvin GJ, Schinke SP, Epstein JA, et al. (1995). Effectiveness of culturally focused and generic skills training approaches to alcohol and drug abuse prevention among minority adolescents: Two-year follow-up results. Psychol Addict Behav.
82 Bourbonnais R, Brisson C, Vinet A, et al. (2006). Development and implementation of a participative intervention to improve the psychosocial work environment and mental health in an acute care hospital. Occup Environ Med.
83 Bower P, Garralda E, Kramer T, et al. (2001). The treatment of child and adolescent mental health problems in primary care: a systematic review (Structured abstract). Fam Pract.
84 Boyd RC, Gillham JE. (2009). Review of interventions for parental depression from toddlerhood to adolescence. Current Psychiatry Reviews.
85 Bradley MC, Mandell D. (2005). Oppositional defiant disorder: a systematic review of evidence of intervention effectiveness (Provisional abstract). Journal of Experimental Criminology.
86 Bradshaw CP, Mitchell MM, Leaf PJ. (2010). Examining the effects of schoolwide positive behavioral interventions and supports on student outcomes: Results from a randomized controlled effectiveness trial in elementary schools. J Posit Behav Interv.
87 Bradshaw CP, Pas ET, Goldweber A, et al. (2012). Integrating school-wide positive behavioral interventions and supports with tier 2 coaching to student support teams: The PBISplus model. Adv School Mental Health Promot.
88 Briesch AM, Sanetti LMH, Briesch JM. (2010). Reducing the prevalence of anxiety in children and adolescents: An evaluation of the evidence base for the FRIENDS for Life program. School Mental Health.
89 Brodey BB, Cuffel B, McCulloch J, et al. (2005). The acceptability and effectiveness of patient-reported assessments and feedback in a managed behavioral healthcare setting. Am J Manag Care.
90 Broning S, Kumpfer K, Kruse K, et al. (2012). Selective prevention programs for children from substance-affected families: a comprehensive systematic review (Provisional abstract). Substance Abuse Treatment, Prevention, and Policy.
91 Brown HE, Pearson N, Braithwaite RE, et al. (2013). Physical activity interventions and depression in children and adolescents : a systematic review and meta-analysis. Sports Med.
92 Brown JD, Wissow LS, Cook BL, et al. (2013). Mental health communications skills training for medical assistants in pediatric primary care. J Behav Health Serv Res.
93 Brown RT, Amler RW, Freeman WS, et al. (2005). Treatment of attention-deficit/hyperactivity disorder: overview of the evidence. Pediatrics.
94 Brown RT, Amler RW, Freeman WS, et al. (2005). Treatment of attention-deficit/hyperactivity disorder: overview of the evidence. Technical report. Pediatrics.
95 Bryant D, Vizzard LH, Willoughby M, et al. (1999). A review of interventions for preschoolers with aggressive and disruptive behavior (Structured abstract). Early Education and Development.
96 Buchmann AF, Kopf D, Westphal S, et al. (2010). Impact of early parental child-rearing behavior on young adults’ cardiometabolic risk profile: a prospective study. Psychosom Med.
97 Buka L, Birdthistle IJ. (1999). Long-term effects of a community-wide alcohol server training intervention. J Stud Alcohol.
98 Burns BJ, Friedman RM. (1990). Examining the research base for child mental health services and policy. J Ment Health Adm.
99 Burns T. (2000). Models of community treatments in schizophrenia: do they travel?. Acta Psychiatr Scand Suppl.
100 Burns T, Rugkasa J, Molodynski A, et al. (2013). Community treatment orders for patients with psychosis (OCTET): a randomised controlled trial. Lancet.
101 Buszewicz M, Griffin M, McMahon EM, et al. (2010). Evaluation of a system of structured, pro-active care for chronic depression in primary care: a randomised controlled trial. BMC Psychiatry.
102 Butler M, Kane RL, McAlpine D, et al. (2008). Integration of mental health/substance abuse and primary care (Structured abstract). Database of Abstracts of Reviews of Effects: AHRQ Research Activities.
103 Byrne MK, Willis A, Deane FP, et al. (2010). Training inpatient mental health staff how to enhance patient engagement with medications: Medication Alliance training and dissemination outcomes in a large US mental health hospital. J Eval Clin Pract.
104 Byrnes HF, Miller BA, Aalborg AE, et al. (2010). Implementation fidelity in adolescent family-based prevention programs: relationship to family engagement. Health Educ Res.
105 Calafat A, Amengual M, Guimerans C, et al. (1995). Adicciones.
106 Calear AL, Christensen H. (2009). Systematic review of school-based prevention and early intervention programs for depression (Structured abstract). J Adolesc.
107 Calear AL, Christensen H. (2010). Systematic review of school-based prevention and early intervention programs for depression. J Adolesc.
108 Calear AL, Christensen H, Griffiths KM, et al. (2013). The Y-Worri Project: study protocol for a randomised controlled trial. Trials.
109 Calear AL, Christensen H, Mackinnon A, et al. (2013). Adherence to the MoodGYM program: outcomes and predictors for an adolescent school-based population. J Affect Disord.
110 Cappella E, Hamre BK, Kim HY, et al. (2012). Teacher consultation and coaching within mental health practice: classroom and child effects in urban elementary schools. J Consult Clin Psychol.
111 Cardemil EV, Reivich KJ, Beevers CG, et al. (2007). The prevention of depressive symptoms in low-income, minority children: two-year follow-up. Behav Res Ther.
112 Carnevale TD. (2013). Universal adolescent depression prevention programs: a review. J Sch Nurs.
113 Cary CE, McMillen JC. (2012). The data behind the dissemination: a systematic review of trauma-focused cognitive behavioral therapy for use with children and youth (Structured abstract). Children and Youth Services Review.
114 Cauce AM, Morgan CJ, Wagner V, et al. (1994). Effectiveness of intensive case management for homeless adolescents: results of a 3-month follow-up. Journal of emotional and behavioral disorders.
115 Cavanagh K, Seccombe N, Lidbetter N. (2011). The implementation of computerized cognitive behavioural therapies in a service user-led, third sector self help clinic. Behav Cogn Psychother.
116 Challen AR, Machin SJ, Gillham JE. (2014). The UK Resilience Programme: A school-based universal nonrandomized pragmatic controlled trial. J Consult Clin Psychol.
117 Chally PS. (1998). An eating disorders prevention program. J Child Adolesc Psychiatr Nurs.
118 Chambers D, Grant R, Warren E, et al. (2010). Use of systematic review evidence to inform local decision-making in the National Health Service: a case study of eating disorders. Cochrane Database of Systematic Reviews, Supplement.
119 Champion KE, Newton NC, Barrett EL, et al. (2013). A systematic review of school-based alcohol and other drug prevention programs facilitated by computers or the Internet (Provisional abstract). Drug and Alcohol Review.
120 Charach A, Gajaria A. (2008). Improving psychostimulant adherence in children with ADHD. Expert Rev Neurother.
121 Charuvastra A, Goldfarb E, Petkova E, et al. (2010). Implementation of a screen and treat program for child posttraumatic stress disorder in a school setting after a school suicide. J Trauma Stress.
122 Chavira DA, Drahota A, Garland AF, et al. (2014). Feasibility of two modes of treatment delivery for child anxiety in primary care. Behav Res Ther.
123 Cheng TL, Haynie D, Brenner R, et al. (2008). Effectiveness of a mentor-implemented, violence prevention intervention for assault-injured youths presenting to the emergency department: Results of a randomized trial. Pediatrics.
124 Cheng TL, Wright JL, Markakis D, et al. (2008). Randomized trial of a case management program for assault-injured youth: impact on service utilization and risk for reinjury. Pediatr Emerg Care.
125 Cheung AH, Zuckerbrot RA, Jensen PS, et al. (2007). Guidelines for Adolescent Depression in Primary Care (GLAD-PC): II. Treatment and ongoing management. Pediatrics.
126 Choe CJ, Emslie GJ, Mayes TL. (2012). Depression. Child Adolesc Psychiatr Clin N Am.
127 Chorpita BF, Yim LM, Donkervoet JC, et al. (2002). Toward large-scale implementation of empirically supported treatments for children: A review and observations by the Hawaii Empirical Basis to Services Task Force. Clinical Psychology: Science and Practice.
128 Christensen H, Pallister E, Smale S, et al. (2010). Community-based prevention programs for anxiety and depression in youth: a systematic review (Structured abstract). J Prim Prev.
129 Chu S, Reynolds F. (2007). Occupational therapy for children with attention deficit hyperactivity disorder (ADHD), Part 2: A multicentre evaluation of an assessment and treatment package. The British Journal of Occupational Therapy.
130 Clarke AM, Kuosmanen T, Barry MM. (2015). A systematic review of online youth mental health promotion and prevention interventions. Journal of Youth and Adolescence.
131 Clever SL, Ford DE, Rubenstein LV, et al. (2006). Primary care patients’ involvement in decision-making is associated with improvement in depression. Med Care.
132 Co JP, Johnson SA, Poon EG, et al. (2010). Electronic health record decision support and quality of care for children with ADHD. Pediatrics.
133 Cohen J, Mannarino AP. (2008). Disseminating and implementing trauma-focused CBT in community settings. Trauma, Violence & Abuse.
134 Coleman JK. (2001). A controlled evaluation of the effects of classroom coping skills training on children’s aggressive and externalizing behaviors. US: ProQuest Information & Learning.
135 Compton SN, Walkup JT, Albano AM, et al. (2010). Child/Adolescent Anxiety Multimodal Study (CAMS): Rationale, design, and methods. Child and adolescent psychiatry and mental health.
136 Connell AM, Dishion TJ, Yasui M, et al. (2007). An adaptive approach to family intervention: linking engagement in family-centered intervention to reductions in adolescent problem behavior. J Consult Clin Psychol.
137 Copp HL, Bordnick PS, Traylor AC, et al. (2007). Evaluating wraparound services for seriously emotionally disturbed youth: pilot study outcomes in Georgia. Adolescence.
138 Corcoran J, Dattalo P. (2006). Parent involvement in treatment for ADHD: a meta-analysis of the published studies (Structured abstract). Research on Social Work Practice.
139 Corcoran J, Pillai V. (2008). A meta-analysis of parent-involved treatment for child sexual abuse (Structured abstract). Research on Social Work Practice.
140 Coupe N, Emma EA, Gask L, et al. (2014). Facilitating professional liaison in collaborative care for depression in UK primary care; a qualitative study utilising normalisation process theory. BMC Fam Pract.
141 Couturier J, Kimber M, Szatmari P. (2013). Efficacy of family-based treatment for adolescents with eating disorders: a systematic review and meta-analysis (Structured abstract). Int J Eat Disord.
142 Crow SJ, Mitchell JE, Crosby RD, et al. (2009). The cost effectiveness of cognitive behavioral therapy for bulimia nervosa delivered via telemedicine versus face-to-face. Behav Res Ther.
143 Cuijpers P. (2002). Peer-led and adult-led school drug prevention: a meta-analytic comparison (Structured abstract). J Drug Educ.
144 Cunningham CE, Bremner R, Boyle M. (1995). Large group community-based parenting programs for families of preschoolers at risk for disruptive behaviour disorders: utilization, cost effectiveness, and outcome (Structured abstract). J Child Psychol Psychiatry.
145 Curtis NM, Ronan KR, Heiblum N, et al. (2009). Dissemination and effectiveness of multisystemic treatment in New Zealand: a benchmarking study. J Fam Psychol.
146 Daley D, Jones K, Hutchings J, et al. (2009). Attention deficit hyperactivity disorder in pre-school children: current findings, recommended interventions and future directions. Child Care Health Dev.
147 Dalle Grave R. (2003). School-based prevention programs for eating disorders: achievements and opportunities (Structured abstract). Disease Management and Health Outcomes.
148 Danielson CK, McCart MR, Walsh K, et al. (2012). Reducing substance use risk and mental health problems among sexually assaulted adolescents: a pilot randomized controlled trial. J Fam Psychol.
149 Day C. (2008). Children’s and young people’s involvement and participation in mental health care. Child & Adolescent Mental Health.
150 Day C, Davis H. (2006). The effectiveness and quality of routine child and adolescent mental health care outreach clinics. Br J Clin Psychol.
151 DeBate RD, Severson HH, Cragun DL, et al. (2013). Evaluation of a theory-driven e-learning intervention for future oral healthcare providers on secondary prevention of disordered eating behaviors. Health Educ Res.
152 Deenadayalan Y, Perraton L, Machotka Z, et al. (2010). Day therapy programs for adolescents with mental health problems: a systematic review (Structured abstract). Internet Journal of Allied Health Sciences and Practice.
153 Delamater AM, Alvarez-Salvat R, McCullough J. (2003). Evidenced-based interventions for children and adolescents with type 1 diabetes. VandeCreek L, Jackson TL, editors. Innovations in clinical practice: Focus on children & adolescents.
154 Denise T. (2014). Cochrane Child Health Field. About The Cochrane Collaboration.
155 Dennehy EB, Suppes T, Rush AJ, et al. (2005). Does provider adherence to a treatment guideline change clinical outcomes for patients with bipolar disorder? Results from the Texas Medication Algorithm Project. Psychol Med.
156 Dennis M, Godley SH, Diamond G, et al. (2004). The Cannabis Youth Treatment (CYT) study: main findings from two randomized trials (Structured abstract). J Subst Abuse Treat.
157 Dennis M, Titus JC, Diamond G, et al. (2002). The Cannabis Youth Treatment (CYT) experiment: rationale, study design and analysis plans. Addiction (Abingdon, England).
158 DeRosa RR, Amaya-Jackson L, Layne CM. (2013). The translational evidence base. Ford JD, Courtois CA, editors. Treating complex traumatic stress disorders in children and adolescents: Scientific foundations and therapeutic models.
159 Dielman TE, Shope JT, Butchart AT, et al. (1986). Prevention of adolescent alcohol misuse: an elementary school program. J Pediatr Psychol.
160 Dielman TE, Shope JT, Leech SL, et al. (1989). Differential effectiveness of an elementary school-based alcohol misuse prevention program. J Sch Health.
161 Dishion TJ, Kavanagh K, Schneiger A, et al. (2002). Preventing early adolescent substance use: a family-centered strategy for the public middle school. Prevention science.
162 Domino ME, Foster EM, Vitiello B, et al. (2009). Relative cost-effectiveness of treatments for adolescent depression: 36-week results from the tads randomized trial (Provisional abstract). J Am Acad Child Adolesc Psychiatry.
163 D’Onise K, Lynch JW, Sawyer MG, et al. (2010). Can preschool improve child health outcomes? A systematic review (Structured abstract). Soc Sci Med.
164 Döpfner M, Breuer D, Schürmann S, et al. (2004). Effectiveness of an adaptive multimodal treatment in children with Attention-Deficit Hyperactivity Disorder -- global outcome. Eur Child Adolesc Psychiatry.
165 Doughty C. (2005). The effectiveness of mental health promotion, prevention and early intervention in children, adolescents and adults: a critical appraisal of the literature (Structured abstract). Health Technology Assessment Database: New Zealand Health Technology Assessment (NZHTA).
166 Dowell KA, Ogles BM. (2010). The effects of parent participation on child psychotherapy outcome: a meta-analytic review (Structured abstract). J Clin Child Adolesc Psychol.
167 Dowling M, Rickwood D. (2013). Online counseling and therapy for mental health problems: a systematic review of individual synchronous interventions using chat (Structured abstract). Journal of Technology in Human Services.
168 Drake RE, Frey W, Bond GR, et al. (2013). Assisting Social Security Disability Insurance beneficiaries with schizophrenia, bipolar disorder, or major depression in returning to work. Am J Psychiatry.
169 Dretzke J, Frew E, Davenport C, et al. (2005). The effectiveness and cost-effectiveness of parent training/education programmes for the treatment of conduct disorder, including oppositional defiant disorder, in children. Health Technol Assess.
170 Dretzke J, Frew E, Davenport C, et al. (2005). The effectiveness and cost-effectiveness of parent training/education programmes for the treatment of conduct disorder, including oppositional defiant disorder, in children (Provisional abstract). Health Technol Assess.
171 Druss BG, von Esenwein SA, Compton MT, et al. (2011). Budget impact and sustainability of medical care management for persons with serious mental illnesses. Am J Psychiatry.
172 Druss BG, Zhao L, von Esenwein SA, et al. (2010). The Health and Recovery Peer (HARP) Program: a peer-led intervention to improve medical self-management for persons with serious mental illness. Schizophr Res.
173 Dufour S, Denoncourt J, Mishara BL. (2011). Improving children’s adaptation: New evidence regarding the effectiveness of Zippy’s Friends, a school mental health promotion program. Advances in school mental health promotion.
174 Duggan AK, McFarlane, et al. (1999). Evaluation of Hawaii’s Healthy Start Program. Future Child.
175 Duncan AB, Velasquez SE, Nelson E-L. (2014). Using videoconferencing to provide psychological services to rural children and adolescents: A review and case example. J Clin Child Adolesc Psychol.
176 Duncan E, Best C, Hagen S. (2010). Shared decision making interventions for people with mental health conditions. Cochrane Database of Systematic Reviews.
177 Durlak JA, Wells AM. (1997). Primary prevention mental health programs for children and adolescents: a meta-analytic review (Structured abstract). Am J Community Psychol.
178 Dusenbury L, Brannigan R, Falco M, et al. (2003). A review of research on fidelity of implementation: implications for drug abuse prevention in school settings. Health Educ Res.
179 Eiraldi R, McCurdy B, Khanna M, et al. (2014). A cluster randomized trial to evaluate external support for the implementation of positive behavioral interventions and supports by school personnel. Implement Sci.
180 Eisen JC, Marko-Holguin M, Fogel J, et al. (2013). Pilot study of implementation of an internet-based depression prevention intervention (CATCH-IT) for adolescents in 12 US primary care practices: Clinical and management/organizational behavioral perspectives. Prim Care Companion J Clin Psychiatry.
181 Elek E, Wagstaff DA, Hecht ML. (2010). Effects of the 5th and 7th grade enhanced versions of the keepin’ it REAL substance use prevention curriculum. J Drug Educ.
182 Epstein JN, Langberg JM, Lichtenstein PK, et al. (2008). Community-wide intervention to improve the attention-deficit/hyperactivity disorder assessment and treatment practices of community physicians. Pediatrics.
183 Eyberg SM, Nelson MM, Boggs SR. (2008). Evidence-based psychosocial treatments for children and adolescents with disruptive behavior. J Clin Child Adolesc Psychol.
184 Fager JH, Melnyk BM. (2004). The effectiveness of intervention studies to decrease alcohol use in college undergraduate students: an integrative analysis (Structured abstract). Worldviews Evid Based Nurs.
185 Farmer EM, Burns BJ, Wagner HR, et al. (2010). Enhancing “usual practice” treatment foster care: findings from a randomized trial on improving youths’ outcomes. Psychiatr Serv.
186 Farrelly S, Brown Gill E, Flach C, et al. (2013). User-held personalised information for routine care of people with severe mental illness. Cochrane Database of Systematic Reviews.
187 Faurholt-Jepsen M, Vinberg M, Frost M, et al. (2014). Daily electronic monitoring of subjective and objective measures of illness activity in bipolar disorder using smartphones--the MONARCA II trial protocol: a randomized controlled single-blind parallel-group trial. BMC Psychiatry.
188 Feil EG, Bagget KM, Davis B, et al. (2008). Expanding the reach of preventive interventions: development of an Internet-based training for parents of infants. Child Maltreatment.
189 Feinberg E, Stein R, Diaz-Linhart Y, et al. (2012). Adaptation of problem-solving treatment for prevention of depression among low-income, culturally diverse mothers. Fam Community Health.
190 Fergusson D, Stanley L, Horwood LJ. (2009). Preliminary data on the efficacy of the Incredible Years Basic Parent Programme in New Zealand. Aust N Z J Psychiatry.
191 Fettig A, Barton EE. (2014). Parent implementation of function-based intervention to reduce children?s challenging behavior: a literature review (Provisional abstract). Database of Abstracts of Reviews of Effects.
192 Flodgren G, Eccles Martin P, Shepperd S, et al. (2011). An overview of reviews evaluating the effectiveness of financial incentives in changing healthcare professional behaviours and patient outcomes. Cochrane Database of Systematic Reviews.
193 Forman SF, Grodin LF, Graham DA, et al. (2011). An eleven site national quality improvement evaluation of adolescent medicine-based eating disorder programs: predictors of weight outcomes at one year and risk adjustment analyses. J Adolesc Health.
194 Forman SF, McKenzie N, Hehn R, et al. (2014). Predictors of outcome at 1 year in adolescents with DSM-5 restrictive eating disorders: report of the national eating disorders quality improvement collaborative. J Adolesc Health.
195 Forsetlund L, Bjørndal A, Rashidian A, et al. (2009). Continuing education meetings and workshops: effects on professional practice and health care outcomes. Cochrane Database of Systematic Reviews.
196 Foster EM, Jones D. (2006). Can a costly intervention be cost-effective?: An analysis of violence prevention. Arch Gen Psychiatry.
197 Fraguela J-G, Martin AL, Trinanes ER. (2002). Drug abuse prevention in the school: four years follow-up of a program. Psicothema.
198 Fraguela J-G, Martin AL, Trinanes ER. (2003). Drug abuse prevention in the school: four-year follow-up of a programme. Psychology in Spain.
199 Freeman JB, Choate-Summers ML, Garcia AM, et al. (2009). The Pediatric Obsessive-Compulsive Disorder Treatment Study II: Rationale, design and methods. Child and adolescent psychiatry and mental health.
200 Friedman RM. (2003). A conceptual framework for developing and implementing effective policy in children’s mental health. Journal of Emotional & Behavioral Disorders.
201 Furst DW, Boever W, Cohen J, et al. (1993). Implementation of the Boys Town psychoeducational treatment model in a children’s psychiatric hospital. Hosp Community Psychiatry.
202 Gardner F, Burton J, Klimes I. (2006). Randomised controlled trial of a parenting intervention in the voluntary sector for reducing child conduct problems: outcomes and mechanisms of change. J Child Psychol Psychiatry.
203 Garland AF, Haine-Schlagel R, Brookman-Frazee L, et al. (2013). Improving community-based mental health care for children: translating knowledge into action. Adm Policy Ment Health.
204 Gask L, Dowrick C, Dixon C, et al. (2004). A pragmatic cluster randomized controlled trial of an educational intervention for GPs in the assessment and management of depression (Structured abstract). Psychol Med.
205 Gearing RE, Schwalbe CS, MacKenzie MJ, et al. (2013). Adaptation and translation of mental health interventions in Middle Eastern Arab countries: a systematic review of barriers to and strategies for effective treatment implementation. Int J Soc Psychiatry.
206 Gensichen J, von Korff M, Peitz M, et al. (2009). Case management for depression by health care assistants in small primary care practices: a cluster randomized trial. Ann Intern Med.
207 Giesen F, Searle A, Sawyer M. (2007). Identifying and implementing prevention programmes for childhood mental health problems. J Paediatr Child Health.
208 Gillham JE, Hamilton J, Freres DR, et al. (2006). Preventing depression among early adolescents in the primary care setting: a randomized controlled study of the Penn Resiliency Program. J Abnorm Child Psychol.
209 Gillham JE, Reivich KJ, Freres DR, et al. (2007). School-based prevention of depressive symptoms: A randomized controlled study of the effectiveness and specificity of the Penn Resiliency Program. J Consult Clin Psychol.
210 Gladstone TRG, Beardslee WR. (2009). The prevention of depression in children and adolescents: A review. The Canadian Journal of Psychiatry.
211 Glisson C. (2002). The organizational context of children’s mental health services. Clin Child Fam Psychol Rev.
212 Godley SH, Smith JE, Passetti LL, et al. (2014). The Adolescent Community Reinforcement Approach (A-CRA) as a Model Paradigm for the Management of Adolescents With Substance Use Disorders and Co-Occurring Psychiatric Disorders. Subst Abus.
213 Goerke D, Kumra S. (2013). Substance abuse and psychosis. Child Adolesc Psychiatr Clin N Am.
214 Gowers SG, Clark A, Roberts C, et al. (2007). Clinical effectiveness of treatments for anorexia nervosa in adolescents: randomised controlled trial. Br J Psychiatry.
215 Graeff-Martins AS, Flament MF, Fayyad J, et al. (2008). Diffusion of efficacious interventions for children and adolescents with mental health problems. J Child Psychol Psychiatry.
216 Greenberg MT, Weissberg RP, O’Brien MU, et al. (2003). Enhancing school-based prevention and youth development through coordinated social, emotional, and academic learning. Am Psychol.
217 Griffin JP, Holliday RC, Frazier E, et al. (2009). The BRAVE (Building Resiliency and Vocational Excellence) Program: evaluation findings for a career-oriented substance abuse and violence preventive intervention. J Health Care Poor Underserved.
218 Grupp-Phelan J, McGuire L, Husky MM, et al. (2012). A randomized controlled trial to engage in care of adolescent emergency department patients with mental health problems that increase suicide risk. Pediatr Emerg Care.
219 Grych JH, Fincham FD. (1992). Interventions for children of divorce: toward greater integration of research and action. Psychol Bull.
220 Gully KJ, Price BL. (2008). Increasing abused children’s access to evidence-based treatment: diffusion via parents as consumers. Child Maltreatment.
221 Hahlweg K, Heinrichs N, Kuschel A, et al. (2008). Therapist-assisted, self-administered bibliotherapy to enhance parental competence: short- and long-term effects. Behav Modif.
222 Halgunseth LC, Carmack C, Childs SS, et al. (2012). Using the interactive systems framework in understanding the relation between general program capacity and implementation in afterschool settings. Am J Community Psychol.
223 Haller DM, Meynard A, Lefebvre D, et al. (2014). Effectiveness of training family physicians to deliver a brief intervention to address excessive substance use among young patients: a cluster randomized controlled trial. CMAJ.
224 Han SS, Weiss B. (2005). Sustainability of teacher implementation of school-based mental health programs. J Abnorm Child Psychol.
225 Hart LM, Cornell C, Damiano SR, et al. (2014). Parents and prevention: a systematic review of interventions involving parents that aim to prevent body dissatisfaction or eating disorders (Provisional abstract). Database of Abstracts of Reviews of Effects.
226 Hauser M, Galling B, Correll CU. (2013). Suicidal ideation and suicide attempts in children and adolescents with bipolar disorder: a systematic review of prevalence and incidence rates, correlates, and targeted interventions. Bipolar Disord.
227 Hawken LS, Bundock K, Kladis K, et al. (2014). Systematic review of the Check-in, Check-out intervention for students at risk for emotional and behavioral disorders. Education & Treatment of Children.
228 Hawkins JD, Brown EC, Oesterle S, et al. (2008). Early effects of Communities That Care on targeted risks and initiation of delinquent behavior and substance use. The Journal of adolescent health : official publication of the Society for Adolescent Medicine.
229 Hawkins JD, Catalano RF, Arthur MW, et al. (2008). Testing communities that care: The rationale, design and behavioral baseline equivalence of the community youth development study. Prevention Science.
230 Hawkins JD, Oesterle S, Brown EC, et al. (2014). Youth problem behaviors 8 years after implementing the communities that care prevention system: a community-randomized trial. JAMA pediatrics.
231 Hawkins JD, Oesterle S, Brown EC, et al. (2009). Results of a type 2 translational research trial to prevent adolescent drug use and delinquency: a test of Communities That Care. Arch Pediatr Adolesc Med.
232 Hawkins JD, Oesterle S, Brown EC, et al. (2012). Sustained decreases in risk exposure and youth problem behaviors after installation of the Communities That Care prevention system in a randomized trial. Arch Pediatr Adolesc Med.
233 Hecht ML, Elek E, Wagstaff DA, et al. (2008). Immediate and short-term effects of the 5th grade version of the keepin’ it REAL substance use prevention intervention. J Drug Educ.
234 Henderson C, Evans-Lacko S, Thornicroft G. (2013). Mental illness stigma, help seeking, and public health programs. Am J Public Health.
235 Henderson J, Milligan K, Niccols A, et al. (2012). Reporting of feasibility factors in publications on integrated treatment programs for women with substance abuse issues and their children: a systematic review and analysis. Health Res Policy Syst.
236 Henggeler SW, Chapman JE, Rowland MD, et al. (2008). Statewide adoption and initial implementation of contingency management for substance-abusing adolescents. J Consult Clin Psychol.
237 Henggeler SW, McCart MR, Cunningham PB, et al. (2012). Enhancing the effectiveness of juvenile drug courts by integrating evidence-based practices. J Consult Clin Psychol.
238 Henggeler SW, Melton GB, Brondino MJ, et al. (1997). Multisystemic therapy with violent and chronic juvenile offenders and their families: the role of treatment fidelity in successful dissemination. J Consult Clin Psychol.
239 Henggeler SW, Pickrel SG, Brondino MJ. (1999). Multisystemic treatment of substance-abusing and dependent delinquents: outcomes, treatment fidelity, and transportability. Mental health services research.
240 Henggeler SW, Pickrel SG, Brondino MJ, et al. (1996). Eliminating (almost) treatment dropout of substance abusing or dependent delinquents through home-based multisystemic therapy. Am J Psychiatry.
241 Henggeler SW, Sheidow AJ. (2012). Empirically supported family-based treatments for conduct disorder and delinquency in adolescents. J Marital Fam Ther.
242 Hetrick S, Alvarez-Jimenez M, Parker A, et al. (2010). Promoting physical health in youth mental health services: ensuring routine monitoring of weight and metabolic indices in a first episode psychosis clinic. Australas Psychiatry.
243 Hiscock H, Bayer JK, Lycett K, et al. (2012). Preventing mental health problems in children: the Families in Mind population-based cluster randomised controlled trial. BMC Public Health.
244 Hoagwood K, Burns BJ, Kiser L, et al. (2001). Evidence-based practice in child and adolescent mental health services. Psychiatr Serv.
245 Hoagwood KE, Jensen PS, Acri MC, et al. (2012). Outcome domains in child mental health research since 1996: have they changed and why does it matter?. J Am Acad Child Adolesc Psychiatry.
246 Hogue A, Dauber S. (2013). Assessing fidelity to evidence-based practices in usual care: the example of family therapy for adolescent behavior problems. Eval Program Plann.
247 Holliday J, Audrey S, Moore L, et al. (2009). High fidelity? How should we consider variations in the delivery of school-based health promotion interventions?. Health Educ J.
248 Horwitz SM, Chamberlain P, Landsverk J, et al. (2010). Improving the mental health of children in child welfare through the implementation of evidence-based parenting interventions. Adm Policy Ment Health.
249 Huey SJ, Polo AJ. (2008). Evidence-based psychosocial treatments for ethnic minority youth. J Clin Child Adolesc Psychol.
250 Hunter LR, Lynch BA. (2014). Impact of implementing mental health screening by mail with a primary care management model. J Prim Care Community Health.
251 Hutchings J, Gardner F, Bywater T, et al. (2007). Parenting intervention in Sure Start services for children at risk of developing conduct disorder: pragmatic randomised controlled trial. BMJ.
252 Ialongo NS, Werthamer L, Kellam SG, et al. (1999). Proximal impact of two first-grade preventive interventions on the early risk behaviors for later substance abuse, depression, and antisocial behavior. Am J Community Psychol.
253 Isaac M, Elias B, Katz LY, et al. (2009). Gatekeeper training as a preventative intervention for suicide: a systematic review (Structured abstract). Canadian Journal of Psychiatry.
254 Jackson C, Trower P, Reid I, et al. (2009). Improving psychological adjustment following a first episode of psychosis: a randomised controlled trial of cognitive therapy to reduce post psychotic trauma symptoms. Behav Res Ther.
255 Jane-Llopis E, Hosman C, Jenkins R, et al. (2003). Predictors of efficacy in depression prevention programmes: meta-analysis (Structured abstract). Br J Psychiatry.
256 Janssen B, Ludwig S, Eustermann H, et al. (2010). Improving outpatient treatment in schizophrenia: effects of computerized guideline implementation--results of a multicenter-study within the German research network on schizophrenia. Eur Arch Psychiatry Clin Neurosci.
257 Janssen M, Wensing M, van der Gaag RJ, et al. (2014). Improving patient care for attention deficit hyperactivity disorder in children by organizational redesign (Tornado program) and enhanced collaboration between psychiatry and general practice: a controlled before and after study. Implement Sci.
258 Jorm AF, Kitchener BA, Sawyer MG, et al. (2010). Mental health first aid training for high school teachers: a cluster randomized trial. BMC Psychiatry.
259 Kaslow NJ, McClure EB, Connell AM. (2002). Treatment of depression in children and adolescents. Gotlib IH, Hammen CL, editors. Handbook of depression.
260 Kates N. (2005). Improving quality of primary care reduces depression and improves quality of life in adolescents. Evidence Based Mental Health.
261 Kauer SD, Mangan C, Sanci L. (2014). Do online mental health services improve help-seeking for young people? A systematic review. J Med Internet Res.
262 Kelly SA, Oswalt K, Melnyk BM, et al. (2015). Comparison of intervention fidelity between COPE TEEN and an attention-control program in a randomized controlled trial. Health Educ Res.
263 Kendrick T, Simons L, Mynors-Wallis L, et al. (2006). Cost-effectiveness of referral for generic care or problem-solving treatment from community mental health nurses, compared with usual general practitioner care for common mental disorders (Structured abstract). Br J Psychiatry.
264 Kennard BD, Emslie GJ, Mayes TL, et al. (2008). Cognitive-behavioral therapy to prevent relapse in pediatric responders to pharmacotherapy for major depressive disorder. J Am Acad Child Adolesc Psychiatry.
265 Kent A, Fiander M, Burns T. (2003). Does extra staff change clinical practice? A prospective study of the impact of extra resources in mental health teams. Acta Psychiatr Scand.
266 Keurhorst MN, Anderson P, Spak F, et al. (2013). Implementing training and support, financial reimbursement, and referral to an internet-based brief advice program to improve the early identification of hazardous and harmful alcohol consumption in primary care (ODHIN): study protocol for a cluster randomized factorial trial. Implement Sci.
267 Kindt KCM, Kleinjan M, Janssens J, et al. (2014). Evaluation of a school-based depression prevention program among adolescents from low-income areas: A randomized controlled effectiveness trial. Int J Environ Res Public Health.
268 Kjobli J, Hukkelberg S, Ogden T. (2013). A randomized trial of group parent training: reducing child conduct problems in real-world settings. Behav Res Ther.
269 Klimes-Dougan B, Klingbeil DA, Meller SJ. (2013). The impact of universal suicide-prevention programs on the help-seeking attitudes and behaviors of youths. Crisis.
270 Kling Å, Forster M, Sundell K, et al. (2010). A randomized controlled effectiveness trial of parent management training with varying degrees of therapist support. Behav Ther.
271 Knapp M, Marks I, Wolstenholme J, et al. (1998). Home-based versus hospital-based care for serious mental illness: controlled cost-effectiveness study over four years (Structured abstract). Br J Psychiatry.
272 Knaup C, Koesters M, Schoefer D, et al. (2009). Effect of feedback of treatment outcome in specialist mental healthcare: meta-analysis (Structured abstract). Br J Psychiatry.
273 Kolko DJ, Baumann BL, Herschell AD, et al. (2012). Implementation of AF-CBT by community practitioners serving child welfare and mental health: a randomized trial. Child Maltreat.
274 Kolko DJ, Dorn LD, Bukstein OG, et al. (2009). Community vs. clinic-based modular treatment of children with early-onset ODD or CD: a clinical trial with 3-year follow-up. J Abnorm Child Psychol.
275 Kosters MP, Chinapaw MJ, Zwaanswijk M, et al. (2012). Study design of ‘FRIENDS for Life’: process and effect evaluation of an indicated school-based prevention programme for childhood anxiety and depression. BMC Public Health.
276 Kuklinski MR, Fagan AA, Hawkins JD, et al. (2015). Benefit–cost analysis of a randomized evaluation of Communities That Care: Monetizing intervention effects on the initiation of delinquency and substance use through grade 12. Journal of Experimental Criminology.
277 Kupfer DJ, Axelson DA, Birmaher B, et al. (2009). Bipolar disorder center for Pennsylvanians: implementing an effectiveness trial to improve treatment for at-risk patients. Psychiatr Serv.
278 Landsverk J, Brown CH, Reutz JR, et al. (2011). Design elements in implementation research: A structured review of child welfare and child mental health studies. Administration and Policy in Mental Health and Mental Health Services Research.
279 Lang JM, Ford JD, Fitzgerald MM. (2010). An algorithm for determining use of trauma-focused cognitive-behavioral therapy. Psychotherapy (Chic).
280 Larun L, Nordheim LV, Ekeland E, et al. (2006). Exercise in prevention and treatment of anxiety and depression among children and young people. Cochrane Database of Systematic Reviews.
281 Lau WY, Chan CK, Li JC, et al. (2010). Effectiveness of group cognitive-behavioral treatment for childhood anxiety in community clinics. Behav Res Ther.
282 Layne CM, Saltzman WR, Poppleton L, et al. (2008). Effectiveness of a school-based group psychotherapy program for war-exposed adolescents: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry.
283 Layne CM, Saltzman WR, Poppleton L, et al. (2008). Effectiveness of a school-based group psychotherapy program for war-exposed adolescents: a randomized controlled trial. J Am Acad Child Adolesc Psychiatry.
284 Leclerc A, Turrini T, Sherwood K, et al. (2013). Evaluation of a nutrition rehabilitation protocol in hospitalized adolescents with restrictive eating disorders. J Adolesc Health.
285 Lee J. (2007). Mindfulness-based cognitive therapy for children: Feasibility, acceptability, and effectiveness of a controlled clinical trial. US: ProQuest Information & Learning.
286 Lee PC, Niew WI, Yang HJ, et al. (2012). A meta-analysis of behavioral parent training for children with attention deficit hyperactivity disorder (Provisional abstract). Res Dev Disabil.
287 Leichsenring F, Rabung S. (2011). Long-term psychodynamic psychotherapy in complex mental disorders: update of a meta-analysis (Structured abstract). Br J Psychiatry.
288 Lester H, Birchwood M, Bryan S, et al. (2009). Development and implementation of early intervention services for young people with psychosis: case study. Br J Psychiatry.
289 Leve LD, Harold GT, Chamberlain P, et al. (2012). Practitioner review: Children in foster care--vulnerabilities and evidence-based interventions that promote resilience processes. J Child Psychol Psychiatry.
290 Levy S, Knight JR, Moore T, et al. (2011). Acceptability of drug testing in an outpatient substance abuse program for adolescents. The Journal of adolescent health : official publication of the Society for Adolescent Medicine.
291 Lewin AB, Park JM, Jones AM, et al. (2014). Family-based exposure and response prevention therapy for preschool-aged children with obsessive-compulsive disorder: A pilot randomized controlled trial. Behav Res Ther.
292 Liddle HA, Dakof GA, Henderson C, et al. (2011). Implementation outcomes of Multidimensional Family Therapy-Detention to Community: a reintegration program for drug-using juvenile detainees. Int J Offender Ther Comp Criminol.
293 Liddle HA, Dakof GA, Turner RM, et al. (2008). Treating adolescent drug abuse: a randomized trial comparing multidimensional family therapy and cognitive behavior therapy. Addiction (Abingdon, England).
294 Liddle HA, Rowe CL, Dakof GA, et al. (2004). Early intervention for adolescent substance abuse: pretreatment to posttreatment outcomes of a randomized clinical trial comparing multidimensional family therapy and peer group treatment. J Psychoactive Drugs.
295 Lindhiem O, Higa J, Trentacosta CJ, et al. (2014). Skill Acquisition and Utilization During Evidence-Based Psychosocial Treatments for Childhood Disruptive Behavior Problems: A Review and Meta-analysis. Clin Child Fam Psychol Rev.
296 Lindsay G, Strand S, Davis H. (2011). A comparison of the effectiveness of three parenting programmes in improving parenting skills, parent mental-well being and children’s behaviour when implemented on a large scale in community settings in 18 English local authorities: the parenting early intervention pathfinder (PEIP). BMC Public Health.
297 Lisha NE, Sun P, Rohrbach LA, et al. (2012). An evaluation of immediate outcomes and fidelity of a drug abuse prevention program in continuation high schools: project towards no drug abuse (TND). J Drug Educ.
298 Lloyd C, Joyce R, Hurry J, et al. (2000). The effectiveness of primary school drug education. Drugs: Education, Prevention & Policy.
299 Lochman JE, Powell N, Boxmeyer C, et al. (2012). Adaptations to the coping power program’s structure, delivery settings, and clinician training. Psychotherapy (Chic).
300 Lochman JE, Powell NP, Boxmeyer CL, et al. (2014). Counselor-Level Predictors of Sustained Use of an Indicated Preventive Intervention for Aggressive Children. Prev Sci.
301 Lochman JE, Wells KC. (2002). The Coping Power program at the middle-school transition: universal and indicated prevention effects. Psychol Addict Behav.
302 Lucksted A, McFarlane W, Downing D, et al. (2012). Recent developments in family psychoeducation as an evidence-based practice. J Marital Fam Ther.
303 Lundahl B, Risser HJ, Lovejoy MC. (2006). A meta-analysis of parent training: moderators and follow-up effects (Structured abstract). Clin Psychol Rev.
304 Lynch S, Wood J, Livingood W, et al. (2015). Feasibility of shelter-based mental health screening for homeless children. Public Health Rep.
305 Ma D, Zhang Z, Zhang X, et al. (2014). Comparative efficacy, acceptability, and safety of medicinal, cognitive-behavioral therapy, and placebo treatments for acute major depressive disorder in children and adolescents: a multiple-treatments meta-analysis (Provisional abstract). Curr Med Res Opin.
306 Maag JW, Swearer SM, Toland MD. (2009). Cognitive-behavioral interventions for depression in children and adolescents: meta-analysis, promising programs, and implications for school personnel (Structured abstract). Database of Abstracts of Reviews of Effects.
307 MacDonald J, Brown N, Ellis P. (2000). Using telephone prompts to improve initial attendance at a community mental health center. Psychiatr Serv.
308 Manos MJ, Tom-Revzon C, Bukstein OG, et al. (2007). Changes and challenges: managing ADHD in a fast-paced world. J Manag Care Pharm.
309 Marieke Schuppert H, Timmerman ME, Bloo J, et al. (2012). Emotion regulation training for adolescents with borderline personality disorder traits: A randomized controlled trial. J Am Acad Child Adolesc Psychiatry.
310 Marks K, Hix-Small H, Clark K, et al. (2009). Lowering developmental screening thresholds and raising quality improvement for preterm children. Pediatrics.
311 Martin G, Copeland J, Allsop S, et al. (2005). The Adolescent Cannabis Check-up.
312 Masia Warner C, Fisher PH, Shrout PE, et al. (2007). Treating adolescents with social anxiety disorder in school: an attention control trial. J Child Psychol Psychiatry.
313 Mason-Jones AJ, Crisp C, Momberg M, et al. (2012). A systematic review of the role of school-based healthcare in adolescent sexual, reproductive, and mental health. Syst Rev.
314 McCambridge J, Day M, Thomas BA, et al. (2011). Fidelity to Motivational Interviewing and subsequent cannabis cessation among adolescents. Addict Behav.
315 McCambridge J, Slym RL, Strang J. (2008). Randomized controlled trial of motivational interviewing compared with drug information and advice for early intervention among young cannabis users. Addiction.
316 McCart MR, Henggeler SW, Chapman JE, et al. (2012). System-level effects of integrating a promising treatment into juvenile drug courts. J Subst Abuse Treat.
317 McCarty CA, Violette HD, Duong MT, et al. (2013). A randomized trial of the Positive Thoughts and Action program for depression among early adolescents. Journal of clinical child and adolescent psychology : the official journal for the Society of Clinical Child and Adolescent Psychology, American Psychological Association, Division.
318 McConachie H, McLaughlin E. (2011). Pilot evaluation of adapted cognitive behaviour therapy for young people with autism spectrum disorder and high anxiety. Dev Med Child Neurol.
319 McDermut W, Miller IW, Brown RA. (2001). The efficacy of group psychotherapy for depression: a meta-analysis and review of the empirical research (Structured abstract). Clinical Psychology: Science and Practice.
320 McGarry D, Cashin A, Fowler C. (2011). “Coming ready or not” high fidelity human patient simulation in child and adolescent psychiatric nursing education: diffusion of Innovation. Nurse Educ Today.
321 McGarvey EL, Leon-Verdin M, Bloomfield K, et al. (2014). Effectiveness of A-CRA/ACC in treating adolescents with cannabis-use disorders. Community Ment Health J.
322 McGurk SR, Twamley EW, Sitzer DI, et al. (2007). A meta-analysis of cognitive remediation in schizophrenia (Structured abstract). Am J Psychiatry.
323 McKowen JW, Tompson MC, Brown TA, et al. (2013). Longitudinal associations between depression and problematic substance use in the Youth Partners in Care study. J Clin Child Adolesc Psychol.
324 McNally Keehn R. (2011). Effectiveness of cognitive-behavioral therapy for children with high-functioning autism and anxiety. US: ProQuest Information & Learning.
325 McVey G, Gusella J, Tweed S, et al. (2009). A controlled evaluation of web-based training for teachers and public health practitioners on the prevention of eating disorders. Eat Disord.
326 Melnyk BM, Brown HE, Jones DC, et al. (2003). Improving the mental/psychosocial health of US children and adolescents: outcomes and implementation strategies from the national KySS Summit. J Pediatr Health Care.
327 Mendlowitz SL, Manassis K, Bradley S, et al. (1999). Cognitive-behavioral group treatments in childhood anxiety disorders: the role of parental involvement. J Am Acad Child Adolesc Psychiatry.
328 Menrath I, Mueller-Godeffroy E, Pruessmann C, et al. (2012). Evaluation of school-based life skills programmes in a high-risk sample: A controlled longitudinal multi-centre study. Journal of Public Health (Germany).
329 Michelson D, Davenport C, Dretzke J, et al. (2013). Do evidence-based interventions work when tested in the “real world?” A systematic review and meta-analysis of parent management training for the treatment of child disruptive behavior (Structured abstract). Clin Child Fam Psychol Rev.
330 Miklowitz DJ, Axelson DA, Birmaher B, et al. (2008). Family-focused treatment for adolescents with bipolar disorder: results of a 2-year randomized trial. Arch Gen Psychiatry.
331 Miklowitz DJ, Schneck CD, Singh MK, et al. (2013). Early intervention for symptomatic youth at risk for bipolar disorder: a randomized trial of family-focused therapy. J Am Acad Child Adolesc Psychiatry.
332 Miranda J, Ong MK, Jones L, et al. (2013). Community-partnered evaluation of depression services for clients of community-based agencies in under-resourced communities in Los Angeles. J Gen Intern Med.
333 Mitcheson L, Bhavsar K, McCambridge J. (2009). Randomized trial of training and supervision in motivational interviewing with adolescent drug treatment practitioners. J Subst Abuse Treat.
334 Molina BS, Flory K, Bukstein OG, et al. (2008). Feasibility and preliminary efficacy of an after-school program for middle schoolers with ADHD: a randomized trial in a large public middle school. J Atten Disord.
335 Moore SK, Marsch LA, Badger GJ, et al. (2011). Improvement in psychopathology among opioid-dependent adolescents during behavioral-pharmacological treatment. J Addict Med.
336 Morgenstern J, Kuerbis A, Amrhein P, et al. (2012). Motivational interviewing: a pilot test of active ingredients and mechanisms of change. Psychol Addict Behav.
337 Morgenstern M, Wiborg G, Isensee B, et al. (2009). School-based alcohol education: results of a cluster-randomized controlled trial. Addiction (Abingdon, England).
338 Morral AR, McCaffrey DF, Ridgeway G. (2004). Effectiveness of community-based treatment for substance-abusing adolescents: 12-month outcomes of youths entering phoenix academy or alternative probation dispositions. Psychol Addict Behav.
339 Morriss R. (2008). Implementing clinical guidelines for bipolar disorder. Psychol Psychother.
340 Muntz R, Hutchings J, Edwards RT, et al. (2004). Economic evaluation of treatments for children with severe behavioural problems. Journal of mental health policy and economics.
341 Myers K, Vander Stoep A, Lobdell C. (2013). Feasibility of conducting a randomized controlled trial of telemental health with children diagnosed with attention-deficit/hyperactivity disorder in underserved communities. J Child Adolesc Psychopharmacol.
342 Nadeem E, Gleacher A, Beidas RS. (2013). Consultation as an implementation strategy for evidence-based practices across multiple contexts: unpacking the black box. Adm Policy Ment Health.
343 Najavits LM, Gallop RJ, Weiss RD. (2006). Seeking safety therapy for adolescent girls with PTSD and substance use disorder: a randomized controlled trial. J Behav Health Serv Res.
344 Nauta MH, Festen H, Reichart CG, et al. (2012). Preventing mood and anxiety disorders in youth: a multi-centre RCT in the high risk offspring of depressed and anxious patients. BMC Psychiatry.
345 Neighbors CJ, Barnett NP, Rohsenow DJ, et al. (2010). Cost-effectiveness of a motivational intervention for alcohol-involved youth in a hospital emergency department (Provisional abstract). Journal of Studies on Alcohol and Drugs.
346 Neil AL, Batterham P, Christensen H, et al. (2009). Predictors of adherence by adolescents to a cognitive behavior therapy website in school and community-based settings. J Med Internet Res.
347 Neil AL, Christensen H. (2009). Efficacy and effectiveness of school-based prevention and early intervention programs for anxiety (Structured abstract). Clin Psychol Rev.
348 Nelson E, Barnard M, Cain S. (2006). Feasibility of telemedicine intervention for childhood depression. Cpr.
349 Nelson E-L, Barnard M, Cain S. (2003). Treating Childhood Depression over Videoconferencing. Telemed J E Health.
350 Newton AS, Hamm MP, Bethell J, et al. (2010). Pediatric suicide-related presentations: a systematic review of mental health care in the emergency department (Structured abstract). Ann Emerg Med.
351 Ngo VK, Asarnow JR, Lange J, et al. (2009). Outcomes for youths from racial-ethnic minority groups in a quality improvement intervention for depression treatment. Psychiatr Serv.
352 Niccols A. (2009). Immediate and short-term outcomes of the ‘COPEing with Toddler Behaviour’ parent group. Journal of child psychology and psychiatry, and allied disciplines.
353 Niccols A, Sword W. (2005). “New Choices” for substance-using mothers and their children: preliminary evaluation. Journal of Substance Use.
354 Nitsch E, Hannon G, Rickard E, et al. (2015). Positive parenting: A randomised controlled trial evaluation of the Parents Plus Adolescent Programme in schools. Child and adolescent psychiatry and mental health.
355 Novins DK, Green AE, Legha RK, et al. (2013). Dissemination and implementation of evidence-based practices for child and adolescent mental health: a systematic review. J Am Acad Child Adolesc Psychiatry.
356 O’Brien MP, Zinberg JL, Bearden CE, et al. (2007). Psychoeducational multi-family group treatment with adolescents at high risk for developing psychosis. Early Interv Psychiatry.
357 O’Donnell M, Parker G, Proberts M, et al. (1999). A study of client-focused case management and consumer advocacy: the Community and Consumer Service Project. Aust N Z J Psychiatry.
358 Ogden Terje, Hagen, et al. (2006). Multisystemic Treatment of Serious Behaviour Problems in Youth: Sustainability of Effectiveness Two Years after Intake. Child-and-Adolescent-Mental-Health.
359 Ogden T, Christensen B, Sheidow AJ, et al. (2008). Bridging the gap between science and practice: the effective nationwide transport of MST programs in Norway. Journal of Child & Adolescent Substance Abuse.
360 O’Leary EMM, Barrett P, Fjermestad KW. (2009). Cognitive-behavioral family treatment for childhood obsessive-compulsive disorder: A 7-year follow-up study. J Anxiety Disord.
361 Olivares J, Garcia-Lopez LJ, Beidel DC, et al. (2002). Results at long-term among three psychological treatments for adolescents with generalized social phobia (I): Statistical significance. Psicologia conductual.
362 Olson BG, Rosenbaum PF, Dosa NP, et al. (2005). Improving guideline adherence for the diagnosis of ADHD in an ambulatory pediatric setting. Ambul Pediatr.
363 Overbeek MM, Schipper JC, Lamers-Winkelman F, et al. (2012). The effectiveness of a trauma-focused psycho-educational secondary prevention program for children exposed to interparental violence: study protocol for a randomized controlled trial. Trials.
364 Overbeek MM, Schipper JC, Lamers-Winkelman F, et al. (2013). Effectiveness of specific factors in community-based intervention for child-witnesses of interparental violence: A randomized trial. Child Abuse Negl.
365 Owens JS, Holdaway AS, Zoromski AK, et al. (2012). Incremental benefits of a daily report card intervention over time for youth with disruptive behavior. Behav Ther.
366 Owens JS, Murphy CE, Richerson L, et al. (2008). Science to practice in underserved communities: the effectiveness of school mental health programming. J Clin Child Adolesc Psychol.
367 Palinkas LA, Holloway IW, Rice E, et al. (2013). Influence network linkages across implementation strategy conditions in a randomized controlled trial of two strategies for scaling up evidence-based practices in public youth-serving systems. Implement Sci.
368 Palinkas LA, Holloway IW, Rice E, et al. (2011). Social networks and implementation of evidence-based practices in public youth-serving systems: a mixed-methods study. Implement Sci.
369 Pane HT, White RS, Nadorff MR, et al. (2013). Multisystemic therapy for child non-externalizing psychological and health problems: a preliminary review. Clin Child Fam Psychol Rev.
370 Španiel F, Hrdlička J, Novák T, et al. (2012). Effectiveness of the information technology-aided program of relapse prevention in schizophrenia (ITAREPS): a randomized, controlled, double-blind study. J Psychiatr Pract.
371 Parrish E, Peden A, Staten RT, et al. (2013). Advanced practice psychiatric nurses’ outcomes of care: a pilot study. Issues Ment Health Nurs.
372 Pas ET, Waasdorp TE, Bradshaw CP. (2015). Examining contextual influences on classroom-based implementation of positive behavior support strategies: Findings from a randomized controlled effectiveness trial. Prevention Science.
373 Paton C, Adroer R, Barnes TR. (2013). Monitoring lithium therapy: the impact of a quality improvement programme in the UK. Bipolar Disord.
374 Pattison C, Lynd-Stevenson RM. (2001). The prevention of depressive symptoms in children: The immediate and long-term outcomes of a school-based program. Behaviour change.
375 Pelham WE, Fabiano GA. (2008). Evidence-based psychosocial treatments for attention-deficit/hyperactivity disorder. J Clin Child Adolesc Psychol.
376 Pemberton JR, Kramer TL, Borrego J, et al. (2013). Kids at the VA? A call for evidence-based parenting interventions for returning veterans. Psychol Serv.
377 Pentz, Mary A, Trebow, et al. (1990). Effects of Program Implementation on Adolescent Drug Use Behavior: The Midwestern Prevention Project (MPP). Evaluation-Review.
378 Petrakis M, Hamilton B, Penno S, et al. (2011). Fidelity to clinical guidelines using a care pathway in the treatment of first episode psychosis. J Eval Clin Pract.
379 Pfeiffer PN, Heisler M, Piette JD, et al. (2011). Efficacy of peer support interventions for depression: a meta-analysis (Structured abstract). Gen Hosp Psychiatry.
380 Pierre TL, Osgood DW, Mincemoyer CC, et al. (2005). Results of an independent evaluation of Project ALERT delivered in schools by Cooperative Extension. Prevention science.
381 Pilling S, Bebbington P, Kuipers E, et al. (2002). Psychological treatments in schizophrenia - I: meta-analysis of family intervention and cognitive behaviour therapy (Structured abstract). Psychol Med.
382 Pitschel-Walz G, Leucht S, Bauml J, et al. (2001). The effect of family interventions on relapse and rehospitalization in schizophrenia: a meta-analysis (Provisional abstract). Schizophr Bull.
383 Ploeg J, Ciliska D, Brunton G, et al. (1999). The effectiveness of school-based curriculum suicide prevention programs for adolescents (Structured abstract). Database of Abstracts of Reviews of Effects.
384 Poikolainen K. (1999). Effectiveness of brief interventions to reduce alcohol intake in primary health care populations: a meta-analysis (Structured abstract). Prev Med.
385 Porath-Waller AJ, Beasley E, Beirness DJ. (2010). A meta-analytic review of school-based prevention for cannabis use (Structured abstract). Health Educ Behav.
386 Posthumus JA, Raaijmakers MA, Maassen GH, et al. (2012). Sustained effects of incredible years as a preventive intervention in preschool children with conduct problems. J Abnorm Child Psychol.
387 Powell BJ, Proctor EK, Glisson CA, et al. (2013). A mixed methods multiple case study of implementation as usual in children’s social service organizations: study protocol. Implement Sci.
388 Power P, Iacoponi E, Reynolds N, et al. (2007). The Lambeth Early Onset Crisis Assessment Team Study: general practitioner education and access to an early detection team in first-episode psychosis. Br J Psychiatry Suppl.
389 Powers MB, Halpern JM, Ferenschak MP, et al. (2010). A meta-analytic review of prolonged exposure for posttraumatic stress disorder (Structured abstract). Clin Psychol Rev.
390 Priebe S, Kelley L, Golden E, et al. (2013). Effectiveness of structured patient-clinician communication with a solution focused approach (DIALOG+) in community treatment of patients with psychosis--a cluster randomised controlled trial. BMC Psychiatry.
391 Prinz R. (2009). Dissemination of a multilevel evidence-based system of parenting interventions with broad application to child welfare populations. Child Welfare.
392 Puig O, Penades R, Baeza I, et al. (2013). Treatment of cognitive deficits in adolescents with early-onset schizophrenia: A randomised controlled trial of cognitive remediation. Eur Neuropsychopharmacol.
393 Pumariega AJ, Winters NC, Huffine C. (2003). The evolution of systems of care for children’s mental health: forty years of community child and adolescent psychiatry. Community Ment Health J.
394 Punja S, Zorzela L, Hartling L, et al. (2013). Long-acting versus short-acting methylphenidate for paediatric ADHD: a systematic review and meta-analysis of comparative efficacy (Structured abstract). BMJ Open.
395 Purcell DW, Garfein RS, Latka MH, et al. (2007). Development, description, and acceptability of a small-group, behavioral intervention to prevent HIV and hepatitis C virus infections among young adult injection drug users. Drug Alcohol Depend.
396 Puskar K, Sereika S, Tusaie-Mumford K. (2003). Effect of the Teaching Kids to Cope (TKC) program on outcomes of depression and coping among rural adolescents. J Child Adolesc Psychiatr Nurs.
397 Puskar KR, Lamb J, Tusaie-Mumford K. (1997). Teaching kids to cope: a preventive mental health nursing strategy for adolescents. J Child Adolesc Psychiatr Nurs.
398 Querido JG. (2004). Early intervention for child conduct problems in head start families. US: ProQuest Information & Learning.
399 Raghavan R, Newell R, Waseem F, et al. (2009). A randomized controlled trial of a specialist liaison worker model for young people with intellectual disabilities with challenging behaviour and mental health needs. Journal of Applied Research in Intellectual Disabilities.
400 Randell BP, Eggert LL, Pike KC. (2001). Immediate post intervention effects of two brief youth suicide prevention interventions. Suicide Life Threat Behav.
401 Ranney L, Melvin C, Lux L, et al. (2006). Tobacco use: prevention, cessation, and control. Evid Rep Technol Assess (Full Rep).
402 Raver CC, Jones SM, Li-Grining CP, et al. (2008). Improving preschool classroom processes: Preliminary findings from a randomized trial implemented in Head Start settings. Early Childhood Research Quarterly.
403 Redmond C, Spoth RL, Shin C, et al. (2009). Long-term protective factor outcomes of evidence-based interventions implemented by community teams through a community-university partnership. The journal of primary prevention.
404 Reilly-Harrington NA, Sylvia LG, Leon AC, et al. (2013). The Medication Recommendation Tracking Form: a novel tool for tracking changes in prescribed medication, clinical decision making, and use in comparative effectiveness research. J Psychiatr Res.
405 Reinecke MA, Ryan NE, DuBois DL. (1998). Cognitive-behavioral therapy of depression and depressive symptoms during adolescence: a review and meta-analysis (Structured abstract). J Am Acad Child Adolesc Psychiatry.
406 Reynolds S, Wilson C, Austin J, et al. (2012). Effects of psychotherapy for anxiety in children and adolescents: a meta-analytic review (Structured abstract). Clin Psychol Rev.
407 Rhew IC, Brown EC, Hawkins JD, et al. (2013). Sustained effects of the Communities That Care system on prevention service system transformation. Am J Public Health.
408 Rhoades KA, Chamberlain P, Roberts R, et al. (2013). MTFC for high-risk adolescent girls: A comparison of outcomes in England and the United States. Journal of Child & Adolescent Substance Abuse.
409 Richens Y, Burbeck R, Shackleton B, et al. (2007). Implementation: use of the guideline. RCM Midwives.
410 Rietdijk J, Dragt S, Klaassen R, et al. (2010). A single blind randomized controlled trial of cognitive behavioural therapy in a help-seeking population with an At Risk Mental State for psychosis: the Dutch Early Detection and Intervention Evaluation (EDIE-NL) trial. Trials.
411 Riggs PD, Mikulich-Gilbertson SK, Davies RD, et al. (2007). A randomized controlled trial of fluoxetine and cognitive behavioral therapy in adolescents with major depression, behavior problems, and substance use disorders. Arch Pediatr Adolesc Med.
412 Rigter H, Henderson CE, Pelc I, et al. (2013). Multidimensional family therapy lowers the rate of cannabis dependence in adolescents: A randomised controlled trial in Western European outpatient settings. Drug Alcohol Depend.
413 Rinaldi M, Perkins R, McNeil K, et al. (2010). The Individual Placement and Support approach to vocational rehabilitation for young people with first episode psychosis in the UK. J Ment Health.
414 Riper H, Straten A, Keuken M, et al. (2009). Curbing problem drinking with personalized-feedback interventions: a meta-analysis (Structured abstract). Am J Prev Med.
415 Rise MB, Eriksen L, Grimstad H, et al. (2012). The short-term effect on alliance and satisfaction of using patient feedback scales in mental health out-patient treatment. A randomised controlled trial. BMC Health Serv Res.
416 Robbins MS, Feaster DJ, Horigian VE, et al. (2011). Therapist adherence in brief strategic family therapy for adolescent drug abusers. J Consult Clin Psychol.
417 Robbins MS, Feaster DJ, Horigian VE, et al. (2011). Brief strategic family therapy versus treatment as usual: results of a multisite randomized trial for substance using adolescents. J Consult Clin Psychol.
418 Robinson TR, Smith SW, Miller MD, et al. (1999). Cognitive behavior modification of hyperactivity-impulsivity and aggression: a meta-analysis of school-based studies (Structured abstract). J Educ Psychol.
419 Rodenburg R, Benjamin A, Roos C, et al. (2009). Efficacy of EMDR in children: a meta-analysis (Structured abstract). Clin Psychol Rev.
420 Rohrbach LA, Graham JW, Hansen WB. (1993). Diffusion of a school-based substance abuse prevention program: predictors of program implementation. Prev Med.
421 Rohrbach LA, Gunning M, Sun P, et al. (2010). The Project Towards No Drug Abuse (TND) dissemination trial: implementation fidelity and immediate outcomes. Prevention science.
422 Rohrbach LA, Sun P, Sussman S. (2010). One-year follow-up evaluation of the Project Towards No Drug Abuse (TND) dissemination trial. Prev Med.
423 Rooney R, Hassan S, Kane R, et al. (2013). Reducing depression in 9–10 year old children in low SES schools: A longitudinal universal randomized controlled trial. Behav Res Ther.
424 Rossbach M, Probst P. (2005). Prax Kinderpsychol Kinderpsychiatr.
425 Rowe C, Rigter H, Henderson C, et al. (2013). Implementation fidelity of Multidimensional Family Therapy in an international trial. J Subst Abuse Treat.
426 Sachdeva S, Goldman G, Mustata G, et al. (2013). Naturalistic outcomes of evidence-based therapies for borderline personality disorder at a university clinic: a quasi-randomized trial. J Am Psychoanal Assoc.
427 Sanchez V, Steckler A, Nitirat P, et al. (2007). Fidelity of implementation in a treatment effectiveness trial of Reconnecting Youth. Health Educ Res.
428 Sanders MR, Bor W, Morawska A. (2007). Maintenance of treatment gains: a comparison of enhanced, standard, and self-directed Triple P-Positive Parenting Program. J Abnorm Child Psychol.
429 Sanders MR, Ralph A, Sofronoff K, et al. (2008). Every family: a population approach to reducing behavioral and emotional problems in children making the transition to school. J Prim Prev.
430 Sanford M, Boyle M, McCleary L, et al. (2006). A pilot study of adjunctive family psychoeducation in adolescent major depression: feasibility and treatment effect. J Am Acad Child Adolesc Psychiatry.
431 Santucci LC, Ehrenreich-May J. (2013). A randomized controlled trial of the child anxiety multi-day program (CAMP) for separation anxiety disorder. Child Psychiatry Hum Dev.
432 Sawyer MG, Harchak TF, Spence SH, et al. (2010). School-based prevention of depression: a 2-year follow-up of a randomized controlled trial of the beyondblue schools research initiative. J Adolesc Health.
433 Sawyer MG, Pfeiffer S, Spence SH, et al. (2010). School-based prevention of depression: a randomised controlled study of the beyondblue schools research initiative. J Child Psychol Psychiatry.
434 Schmidt MH, Lay B, Gopel C, et al. (2006). Home treatment for children and adolescents with psychiatric disorders. Eur Child Adolesc Psychiatry.
435 Schneider SJ, Grilli SF, Schneider JR. (2013). Evidence-based treatments for traumatized children and adolescents. Curr Psychiatry Rep.
436 Schoenwald SK, Chapman JE, Sheidow AJ, et al. (2009). Long-term youth criminal outcomes in MST transport: the impact of therapist adherence and organizational climate and structure. J Clin Child Adolesc Psychol.
437 Schoenwald SK, Garland AF. (2013). A review of treatment adherence measurement methods. Psychol Assess.
438 Schoenwald SK, Scherer DG, Brondino MJ. (1997). Effective community-based treatments for serious juvenile offenders. Henggeler SW, Santos AB, Henggeler SW, Santos AB, editors. Innovative approaches for difficult-to-treat populations.
439 Seekles W, van Straten A, Beekman A, et al. (2011). Stepped care treatment for depression and anxiety in primary care. a randomized controlled trial. Trials.
440 Sequist TD, Cullen T, Bernard K, et al. (2011). Trends in quality of care and barriers to improvement in the Indian Health Service. J Gen Intern Med.
441 Shakeshaft A, Doran C, Petrie D, et al. (2014). The Effectiveness of Community Action in Reducing Risky Alcohol Consumption and Harm: A Cluster Randomised Controlled Trial. PLoS Med.
442 Sharkey L, Mc Nicholas F, Barry E, et al. (2008). Group therapy for selective mutism - a parents’ and children’s treatment group. J Behav Ther Exp Psychiatry.
443 Sharry J, Nitsch E, Houghton S, et al. (2013). A randomized controlled trial evaluation of the parents plus adolescents programme in schools. Eur Child Adolesc Psychiatry.
444 Shaw DS, Dishion TJ, Supplee L, et al. (2006). Randomized trial of a family-centered approach to the prevention of early conduct problems: 2-year effects of the family check-up in early childhood. J Consult Clin Psychol.
445 Sheidow AJ, Henggeler SW. (2005). Community-Based Treatments. Heilbrun K, Goldstein NES, Redding RE, Heilbrun K, Goldstein NES, Redding RE, editors. Juvenile delinquency: Prevention, assessment, and intervention.
446 Shipman K, Taussig H. (2009). Mental health treatment of child abuse and neglect: the promise of evidence-based practice. Pediatr Clin North Am.
447 Shope Jean T, et al. (1986). Evaluation of an Elementary School-Based Alcohol Misuse Prevention Program.
448 Skara S, Rohrbach LA, Sun P, et al. (2005). An evaluation of the fidelity of implementation of a school-based drug abuse prevention program: project toward no drug abuse (TND). J Drug Educ.
449 Slee N, Garnefski N, van der Leeden R, et al. (2008). Cognitive-behavioural intervention for self-harm: randomised controlled trial. Br J Psychiatry.
450 Smith A, Cook-Cottone C. (2011). A review of family therapy as an effective intervention for anorexia nervosa in adolescents. J Clin Psychol Med Settings.
451 Smith P, Perrin S, Dalgleish T, et al. (2013). Treatment of posttraumatic stress disorder in children and adolescents. Curr Opin Psychiatry.
452 Smolders M, Laurant M, Roberge P, et al. (2008). Knowledge transfer and improvement of primary and ambulatory care for patients with anxiety (Structured abstract). Canadian Journal of Psychiatry.
453 Southam-Gerow MA, Rodríguez A, Chorpita BF, et al. (2012). Dissemination and implementation of evidence based treatments for youth: Challenges and recommendations. Professional Psychology: Research & Practice.
454 Spence SH, Sawyer MG, Sheffield J, et al. (2014). Does the absence of a supportive family environment influence the outcome of a universal intervention for the prevention of depression?. Int J Environ Res Public Health.
455 Spence SH, Shortt AL. (2007). Research review: can we justify the widespread dissemination of universal, school-based interventions for the prevention of depression among children and adolescents? (Structured abstract). Journal of Child Psychology and Psychiatry.
456 Spence SH, Shortt AL. (2007). Can we justify the widespread dissemination of universal, school-based interventions for the prevention of depression among children and adolescents?. Journal of Child Psychology and Psychiatry.
457 Spoth R, Clair S, Greenberg M, et al. (2007). Toward dissemination of evidence-based family interventions: maintenance of community-based partnership recruitment results and associated factors. J Fam Psychol.
458 Spoth R, Redmond C, Shin C, et al. (2007). Substance-use outcomes at 18 months past baseline: the PROSPER Community-University Partnership Trial. Am J Prev Med.
459 Spoth R, Redmond C, Shin C, et al. (2013). PROSPER community-university partnership delivery system effects on substance misuse through 6 1/2 years past baseline from a cluster randomized controlled intervention trial. Prev Med.
460 Spoth R, Shin C, Guyll M, et al. (2006). Universality of effects: an examination of the comparability of long-term family intervention effects on substance use across risk-related subgroups. Prevention science.
461 Sreeharan V, Madden H, Lee JT, et al. (2013). Improving Access to Psychological Therapies and antidepressant prescribing rates in England: a longitudinal time-series analysis. Br J Gen Pract.
462 Stallard P, Buck R. (2013). Preventing depression and promoting resilience: feasibility study of a school-based cognitive-behavioural intervention. Br J Psychiatry Suppl.
463 Starkey F, Audrey S, Holliday J, et al. (2009). Identifying influential young people to undertake effective peer-led health promotion: the example of A Stop Smoking In Schools Trial (ASSIST). Health Educ Res.
464 Stein RE, Zitner LE, Jensen PS. (2006). Interventions for adolescent depression in primary care. Pediatrics.
465 Stiles-Shields C, Hoste RR, Doyle PM, et al. (2012). A review of family-based treatment for adolescents with eating disorders. Rev Recent Clin Trials.
466 Sundell K, Hansson K, Lofholm CA, et al. (2008). The transportability of multisystemic therapy to Sweden: short-term results from a randomized trial of conduct-disordered youths. J Fam Psychol.
467 Sundell K, Hansson K, Löfholm CA, et al. (2008). The transportability of multisystemic therapy to Sweden: short-term results from a randomized trial of conduct-disordered youths. J Fam Psychol.
468 Sussman S, Sun P, McCuller WJ, et al. (2003). Project Towards No Drug Abuse: two-year outcomes of a trial that compares health educator delivery to self-instruction. Prev Med.
469 Sved Williams A, Dodding J, Wilson I, et al. (2006). Consultation-liaison to general practitioners coming of age: the South Australian psychiatrists’ experience. Australas Psychiatry.
470 Tait L, Lester H, Birchwood M, et al. (2005). Design of the BiRmingham Early Detection In untREated psyChosis Trial (REDIRECT): cluster randomised controlled trial of general practitioner education in detection of first episode psychosis. BMC Health Serv Res.
471 Tait RJ, Hulse GK, Robertson SI. (2004). Effectiveness of a brief-intervention and continuity of care in enhancing attendance for treatment by adolescent substance users. Drug Alcohol Depend.
472 Tak YR, Van Zundert RM, Kuijpers RC, et al. (2012). A randomized controlled trial testing the effectiveness of a universal school-based depression prevention program ‘Op Volle Kracht’ in the Netherlands. BMC Public Health.
473 Thaker S, Steckler A, Sánchez V, et al. (2008). Program characteristics and organizational factors affecting the implementation of a school-based indicated prevention program. Health Educ Res.
474 Thomas HV, Lewis G, Watson M, et al. (2004). Computerised patient-specific guidelines for management of common mental disorders in primary care: a randomised controlled trial. Br J Gen Pract.
475 Tolman RT, Mueller CW, Daleiden EL, et al. (2008). Outcomes from multisystemic therapy in a statewide system of care. Journal of Child and Family Studies.
476 Van Duin D, Franx G, Van Wijngaarden B, et al. (2013). Bridging the science-to-service gap in schizophrenia care in the Netherlands: the Schizophrenia Quality Improvement Collaborative. Int J Qual Health Care.
477 van Rosmalen-Nooijens KA, Prins JB, Vergeer M, et al. (2013). “Young people, adult worries”: RCT of an internet-based self-support method “Feel the ViBe” for children, adolescents and young adults exposed to family violence, a study protocol. BMC Public Health.
478 Wade SL, Carey J, Wolfe CR. (2006). An online family intervention to reduce parental distress following pediatric brain injury. J Consult Clin Psychol.
479 Wade SL, Walz NC, Carey JC, et al. (2008). Preliminary efficacy of a Web-based family problem-solving treatment program for adolescents with traumatic brain injury. J Head Trauma Rehabil.
480 Wagenaar AC, Murray DM, Toomey TL. (2000). Communities mobilizing for change on alcohol (CMCA): effects of a randomized trial on arrests and traffic crashes. Addiction (Abingdon, England).
481 Wand AP, Corr MJ, Eades SJ. (2009). Liaison psychiatry with Aboriginal and Torres Strait Islander peoples. Aust N Z J Psychiatry.
482 Weare K, Nind M. (2011). Mental health promotion and problem prevention in schools: what does the evidence say?. Health Promot Int.
483 Weersing VR, Rozenman M, Gonzalez A. (2009). Core components of therapy in youth: do we know what to disseminate?. Behav Modif.
484 Wei Y, Hayden JA, Kutcher S, et al. (2013). The effectiveness of school mental health literacy programs to address knowledge, attitudes and help seeking among youth. Early Interv Psychiatry.
485 Weiss B, Han S, Harris V, et al. (2013). An independent randomized clinical trial of multisystemic therapy with non-court-referred adolescents with serious conduct problems. J Consult Clin Psychol.
486 Weiss FL, Nicholson HJ. (1998). Friendly PEERsuasion(sm) against substance use: The Girls Incorporated(sm) model and evaluation. Drugs & society (New York, N.Y.).
487 Weist MD, Youngstrom EA, Stephan S, et al. (2014). Challenges and ideas from a research program on high-quality, evidence-based practice in school mental health. J Clin Child Adolesc Psychol.
488 Weisz JR, Southam-Gerow MA, Gordis EB, et al. (2009). Cognitive-behavioral therapy versus usual clinical care for youth depression: an initial test of transportability to community clinics and clinicians. J Consult Clin Psychol.
489 Wells KB, Sherbourne CD, Miranda J, et al. (2007). The cumulative effects of quality improvement for depression on outcome disparities over 9 years: Results from a randomized, controlled group-level trial. Med Care.
490 Wells KB, Tang L, Carlson GA, et al. (2012). Treatment of youth depression in primary care under usual practice conditions: observational findings from Youth Partners in Care. J Child Adolesc Psychopharmacol.
491 Werner EE. (2012). Children and war: risk, resilience, and recovery. Dev Psychopathol.
492 West AE, Henry DB, Pavuluri MN. (2007). Maintenance model of integrated psychosocial treatment in pediatric bipolar disorder: A pilot feasibility study. J Am Acad Child Adolesc Psychiatry.
493 Whiteford H, McKeon G, Harris M, et al. (2014). System-level intersectoral linkages between the mental health and non-clinical support sectors: a qualitative systematic review. Aust N Z J Psychiatry.
494 Wilhelm K, Finch A, Kotze B, et al. (2007). The Green Card Clinic: overview of a brief patient-centred intervention following deliberate self-harm. Australas Psychiatry.
495 Wilhelmsen BU, Laberg JC, Klepp KI. (1994). Evaluation of two student and teacher involved alcohol prevention programmes. Addiction (Abingdon, England).
496 Williams NJ, Green P. (2012). Reliability and validity of a treatment adherence measure for child psychiatric rehabilitation. Psychiatr Rehabil J.
497 Williford AP, Shelton TL. (2008). Using mental health consultation to decrease disruptive behaviors in preschoolers: adapting an empirically-supported intervention. J Child Psychol Psychiatry.
498 Winther J, Carlsson A, Vance A. (2014). A pilot study of a school-based prevention and early intervention program to reduce oppositional defiant disorder/conduct disorder. Early Intervention in Psychiatry.
499 Winther J, Carlsson A, Vance A. (2014). A pilot study of a school-based prevention and early intervention program to reduce oppositional defiant disorder/conduct disorder. Early Interv Psychiatry.
500 Wodarski JS. (2010). Prevention of adolescent reoccurring violence and alcohol abuse: a multiple site evaluation. Journal of Evidence-Based Social Work.
501 Wodarski JS, Feit MD. (2011). Adolescent preventive health and team-games-tournaments: five decades of evidence for an empirically based paradigm. Soc Work Public Health.
502 Wonderlich SA, Simonich HK, Myers TC, et al. (2011). Evidence-based mental health interventions for traumatized youth: a statewide dissemination project. Behav Res Ther.
503 Wong KK, Chan SK, Lam MM, et al. (2011). Cost-effectiveness of an early assessment service for young people with early psychosis in Hong Kong (Provisional abstract). Aust N Z J Psychiatry.
504 Wong PW, Fu KW, Chan KY, et al. (2012). Effectiveness of a universal school-based programme for preventing depression in Chinese adolescents: a quasi-experimental pilot study. J Affect Disord.
505 Wood D, Winterbauer N, Sloyer P, et al. (2009). A longitudinal study of a pediatric practice-based versus an agency-based model of care coordination for children and youth with special health care needs. Maternal and Child Health Journal.
506 Wood JJ, McLeod BD, Klebanoff S, et al. (2015). Toward the implementation of evidence-based interventions for youth with autism spectrum disorders in schools and community agencies. Behav Ther.
507 Woodside M, Bishop RM, Miller LT, et al. (1997). Experimental evaluation of “The Images Within”: an alcohol education and prevention program. J Drug Educ.
508 Wren FJ, Foy JM, Ibeziako PI. (2012). Primary care management of child & adolescent depressive disorders. Child Adolesc Psychiatr Clin N Am.
509 Wu Y, Stanton BF, Galbraith J, et al. (2003). Sustaining and broadening intervention impact: a longitudinal randomized trial of 3 adolescent risk reduction approaches. Pediatrics.
510 Wu YP, Pai AL. (2014). Health care provider-delivered adherence promotion interventions: a meta-analysis (Structured abstract). Pediatrics.
511 Yatham LN, Kauer-Sant’Anna M, Bond DJ, et al. (2009). Course and outcome after the first manic episode in patients with bipolar disorder: prospective 12-month data from the Systematic Treatment Optimization Program For Early Mania project. Can J Psychiatry.
512 Yokley JM, Coleman DJ, Yates BT. (1990). Cost effectiveness of three child mental health assessment methods: computer-assisted assessment is effective and inexpensive. J Ment Health Adm.
513 Yu L. (2000). Preventing depressive symptoms in Chinese children. Dissertation Abstracts International: Section B: the Sciences and Engineering.
514 Zatzick DF, Donovan DM, Dunn C, et al. (2013). Disseminating Organizational Screening and Brief Intervention Services (DO-SBIS) for alcohol at trauma centers study design. Gen Hosp Psychiatry.
515 Zhou Q, Sandler IN, Millsap RE, et al. (2008). Mother-child relationship quality and effective discipline as mediators of the 6-year effects of the New Beginnings Program for children from divorced families. J Consult Clin Psychol.
516 Zlotnick C, Tam T, Zerger S. (2012). Common needs but divergent interventions for U.S. homeless and foster care children: results from a systematic review. Health Soc Care Community.