# Appendix B Effective Practice and Organization of Care Taxonomy Tables

Table B-1 SIMHC intervention EPOC taxonomy table, professional components

Table B--2 SIMHC intervention EPOC taxonomy table, financial components (provider and patient)

Table B--3 SIMHC intervention EPOC taxonomy table, provider-oriented organizational components

Table B--4 SIMHC intervention EPOC taxonomy table, organizational components: structural interventions

## References

1 Beidas RS, Edmunds JM, Marcus SC, et al. (2012). Training and consultation to promote implementation of an empirically supported treatment: a randomized trial. Psychiatr Serv.
2 Bickman L, Kelley SD, Breda C, et al. (2011). Effects of routine feedback to clinicians on mental health outcomes of youths: results of a randomized trial. Psychiatr Serv.
3 Carroll AE, Bauer NS, Dugan TM, et al. (2013). Use of a computerized decision aid for ADHD diagnosis: a randomized controlled trial. Pediatrics.
4 Epstein JN, Langberg JM, Lichtenstein PK, et al. (2011). Use of an Internet portal to improve community-based pediatric ADHD care: a cluster randomized trial. Pediatrics.
5 Epstein JN, Rabiner D, Johnson DE, et al. (2007). Improving attention-deficit/hyperactivity disorder treatment outcomes through use of a collaborative consultation treatment service by community-based pediatricians: a cluster randomized trial. Arch Pediatr Adolesc Med.
6 Garner BR, Godley SH, Dennis ML, et al. (2012). Using pay for performance to improve treatment implementation for adolescent substance use disorders: results from a cluster randomized trial. Arch Pediatr Adolesc Med.
7 Glisson C, Hemmelgarn A, Green P, et al. (2012). Randomized trial of the Availability, Responsiveness, and Continuity (ARC) organizational intervention with community-based mental health programs and clinicians serving youth. J Am Acad Child Adolesc Psychiatry.
8 Glisson C, Schoenwald SK, Hemmelgarn A, et al. (2010). Randomized trial of MST and ARC in a two-level evidence-based treatment implementation strategy. J Consult Clin Psychol.
9 Gully KJ, Price BL, Johnson MK. (2008). Increasing abused children’s access to evidence-based treatment: diffusion via parents as consumers. Child Maltreat.
10 Henggeler SW, Chapman JE, Rowland MD, et al. (2013). Evaluating training methods for transporting contingency management to therapists. J Subst Abuse Treat.
11 Henggeler SW, Sheidow AJ, Cunningham PB, et al. (2008). Promoting the implementation of an evidence-based intervention for adolescent marijuana abuse in community settings: testing the use of intensive quality assurance. J Clin Child Adolesc Psychol.
12 Lester H, Birchwood M, Freemantle N, et al. (2009). REDIRECT: cluster randomised controlled trial of GP training in first-episode psychosis. Br J Gen Pract.
13 Lochman JE, Boxmeyer C, Powell N, et al. (2009). Dissemination of the Coping Power program: importance of intensity of counselor training. J Consult Clin Psychol.
14 Ronsley R, Rayter M, Smith D, et al. (2012). Metabolic monitoring training program implementation in the community setting was associated with improved monitoring in second-generation antipsychotic-treated children. Can J Psychiatry.
15 Sterling S, Kline-Simon AH, Satre DD, et al. (2015). Implementation of screening, brief intervention, and referral to treatment for adolescents in pediatric primary care a cluster randomized trial. JAMA Pediatrics.
16 Wildman BG, Langkamp DL. (2012). Impact of location and availability of behavioral health services for children. J Clin Psychol Med Settings.