# Appendix A Search Strategy and Detailed Methods

11/13/14 PubMed

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Health Plan Implementation”[Mesh] | 3925 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Quality Improvement”[Mesh] OR “quality improvement”[All Fields] OR “quality initiative”[All Fields]) | 23297 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Information Dissemination”[Mesh] OR “Diffusion of Innovation”[Mesh] OR “Health Information Management”[Mesh]))) | 25716 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 or #2 or #3) | 52013 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Patient Acceptance of Health Care”[Mesh] OR adaptation[tiab] OR disseminat*[tiab] OR “Feasibility Studies”[Mesh] OR feasibility[tiab] OR fidelity[tiab] OR implement*[tiab] OR penetration[tiab] OR supervision[tiab] OR sustain*[tiab] OR “Information Systems”[MeSH] OR uptake[tiab])) | 1390899 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Guideline Adherence”[Mesh] OR “Evidence-Based Practice”[Mesh] OR “evidence based practice”[All Fields] OR “evidence-based practice”[All Fields] OR effect* OR evidence)) | 7753831 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 and #6) | 608070 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4 or #7) | 651277 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“mental health”[All Fields] OR “mental illness”[All Fields] OR “mental disorders”[All Fields] OR “mental disorder”[All Fields] OR psychopathology OR “Adjustment Disorders”[Mesh] OR “adjustment disorder”[All Fields] OR “anxiety disorder”[All Fields] OR agoraphobia OR “panic disorder”[All Fields] OR “Phobic Disorders”[Mesh] OR phobia OR “Stress Disorders, Post-Traumatic”[Mesh] OR “posttraumatic stress disorder”[All Fields] OR “post-traumatic stress disorder”[All Fields] OR “generalized anxiety disorder”[All Fields] OR “Obsessive-Compulsive Disorder”[Mesh] OR “obsessive compulsive disorder”[All Fields] OR “reactive attachment disorder”[All Fields] OR “Anxiety, Separation”[Mesh] OR “separation anxiety disorder”[All Fields] OR “Eating Disorders”[Mesh] OR “eating disorder”[All Fields] OR “anorexia nervosa”[All Fields] OR “bulimia nervosa”[All Fields] OR “Attention Deficit Disorder with Hyperactivity”[Mesh] OR “attention deficit hyperactivity disorder”[All Fields] OR “Attention Deficit and Disruptive Behavior Disorders”[Mesh] OR “conduct disorder”[All Fields] OR “oppositional defiant disorder”[All Fields] OR depression OR “depressive disorder”[All Fields] OR “Bipolar Disorder”[Mesh] OR “bipolar disorder”[All Fields] OR mania OR “dysthymic disorder”[All Fields] OR “Schizophrenia”[Mesh] OR schizophrenia OR “Psychotic Disorders”[Mesh] OR “psychotic disorder”[All Fields] OR encopresis OR “Personality Disorders”[Mesh] OR “personality disorder”[All Fields] OR “behavioral disorder”[All Fields] OR “behavioral disturbance”[All Fields] OR “serious emotional distress”[All Fields] OR “emotional disorder”[All Fields] OR “Substance-Related Disorders”[All Fields] OR “substance use disorder”[All Fields] OR “drug use disorder”[All Fields] OR “Alcohol-Related Disorders”[Mesh] OR “alcohol use disorder”[All Fields] OR “alcohol dependence”[All Fields] OR alcoholism OR “drug dependence”[All Fields] OR “cannabis dependence”[All Fields] OR “marijuana dependence”[All Fields] OR “Tobacco Use Disorder”[Mesh] OR “nicotine dependence”[All Fields] OR “substance dependence”[All Fields] OR “substance abuse”[All Fields] OR “alcohol abuse”[All Fields] OR “drug abuse”[All Fields] OR “cannabis abuse”[All Fields] OR “marijuana abuse”[All Fields]) | 932701 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#8 and #9) | 39308 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“diffusion tensor” OR “diffusion tensors”)) | 9434 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 not #11) | 39276 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 not #11) Filters: Editorial | 200 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 not #11) Filters: Editorial; Letter | 376 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 NOT #14) | 38900 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH])) | 583142 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 and #16) | 6024 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Cohort Studies”[MeSH] OR (prospective AND cohort))) | 1380934 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#15 and #18) | 5327 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 NOT #14) Filters: Review | 6062 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#17 or #19 or #20) | 15664 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#17 or #19 or #20) Filters: Child: birth-18 years | 3605 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)

8/14/15 PubMed

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed) | Search “Health Plan Implementation”[Mesh] | 4144 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Quality Improvement”[Mesh] OR “quality improvement”[All Fields] OR “quality initiative”[All Fields]) | 26941 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Information Dissemination”[Mesh] OR “Diffusion of Innovation”[Mesh] OR “Health Information Management”[Mesh]) | 27242 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#1 or #2 or #3) | 57286 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Patient Acceptance of Health Care”[Mesh] OR adaptation[tiab] OR disseminat*[tiab] OR “Feasibility Studies”[Mesh] OR feasibility[tiab] OR fidelity[tiab] OR implement*[tiab] OR penetration[tiab] OR supervision[tiab] OR sustain*[tiab] OR “Information Systems”[MeSH] OR uptake[tiab]) | 1477711 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Guideline Adherence”[Mesh] OR “Evidence-Based Practice”[Mesh] OR “evidence based practice”[All Fields] OR “evidence-based practice”[All Fields] OR effect* OR evidence) | 8087430 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#5 and #6) | 647286 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#4 or #7) | 694719 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“mental health”[All Fields] OR “mental illness”[All Fields] OR “mental disorders”[All Fields] OR “mental disorder”[All Fields] OR psychopathology OR “Adjustment Disorders”[Mesh] OR “adjustment disorder”[All Fields] OR “anxiety disorder”[All Fields] OR agoraphobia OR “panic disorder”[All Fields] OR “Phobic Disorders”[Mesh] OR phobia OR “Stress Disorders, Post-Traumatic”[Mesh] OR “posttraumatic stress disorder”[All Fields] OR “post-traumatic stress disorder”[All Fields] OR “generalized anxiety disorder”[All Fields] OR “Obsessive-Compulsive Disorder”[Mesh] OR “obsessive compulsive disorder”[All Fields] OR “reactive attachment disorder”[All Fields] OR “Anxiety, Separation”[Mesh] OR “separation anxiety disorder”[All Fields] OR “Eating Disorders”[Mesh] OR “eating disorder”[All Fields] OR “anorexia nervosa”[All Fields] OR “bulimia nervosa”[All Fields] OR “Attention Deficit Disorder with Hyperactivity”[Mesh] OR “attention deficit hyperactivity disorder”[All Fields] OR “Attention Deficit and Disruptive Behavior Disorders”[Mesh] OR “conduct disorder”[All Fields] OR “oppositional defiant disorder”[All Fields] OR depression OR “depressive disorder”[All Fields] OR “Bipolar Disorder”[Mesh] OR “bipolar disorder”[All Fields] OR mania OR “dysthymic disorder”[All Fields] OR “Schizophrenia”[Mesh] OR schizophrenia OR “Psychotic Disorders”[Mesh] OR “psychotic disorder”[All Fields] OR encopresis OR “Personality Disorders”[Mesh] OR “personality disorder”[All Fields] OR “behavioral disorder”[All Fields] OR “behavioral disturbance”[All Fields] OR “serious emotional distress”[All Fields] OR “emotional disorder”[All Fields] OR “Substance-Related Disorders”[All Fields] OR “substance use disorder”[All Fields] OR “drug use disorder”[All Fields] OR “Alcohol-Related Disorders”[Mesh] OR “alcohol use disorder”[All Fields] OR “alcohol dependence”[All Fields] OR alcoholism OR “drug dependence”[All Fields] OR “cannabis dependence”[All Fields] OR “marijuana dependence”[All Fields] OR “Tobacco Use Disorder”[Mesh] OR “nicotine dependence”[All Fields] OR “substance dependence”[All Fields] OR “substance abuse”[All Fields] OR “alcohol abuse”[All Fields] OR “drug abuse”[All Fields] OR “cannabis abuse”[All Fields] OR “marijuana abuse”[All Fields]) | 973381 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#8 and #9) | 42184 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“diffusion tensor” OR “diffusion tensors”) | 10677 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 NOT #11) | 42149 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 NOT #11) Filters: Editorial | 215 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#10 NOT #11) Filters: Editorial; Letter | 406 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#12 NOT #14) | 41743 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH])) | 609530 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#15 and #16) | 6569 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (“Cohort Studies”[MeSH] OR (prospective AND cohort)) | 1455199 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#15 and #18) | 5702 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#12 NOT #14) Filters: Review | 6551 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#17 or #19 or #20) | 16936 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#17 or #19 or #20) Filters: Child: birth-18 years | 3858 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed) | Search (#17 or #19 or #20) Filters: Publication date from 2014/02/13; Child: birth-18 years | 262 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)

12/9/15 PubMed Add on Search

Search | Query | Items found
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (Community Mental Health Services/organization and administration [mesh]) OR Social Medicine/organization and administration [mesh])) | 9187 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((“mental health”[All Fields] OR “mental illness”[All Fields] OR “mental disorders”[All Fields] OR “mental disorder”[All Fields] OR psychopathology OR “Adjustment Disorders”[Mesh] OR “adjustment disorder”[All Fields] OR “anxiety disorder”[All Fields] OR agoraphobia OR “panic disorder”[All Fields] OR “Phobic Disorders”[Mesh] OR phobia OR “Stress Disorders, Post-Traumatic”[Mesh] OR “posttraumatic stress disorder”[All Fields] OR “post-traumatic stress disorder”[All Fields] OR “generalized anxiety disorder”[All Fields] OR “Obsessive-Compulsive Disorder”[Mesh] OR “obsessive compulsive disorder”[All Fields] OR “reactive attachment disorder”[All Fields] OR “Anxiety, Separation”[Mesh] OR “separation anxiety disorder”[All Fields] OR “Eating Disorders”[Mesh] OR “eating disorder”[All Fields] OR “anorexia nervosa”[All Fields] OR “bulimia nervosa”[All Fields] OR “Attention Deficit Disorder with Hyperactivity”[Mesh] OR “attention deficit hyperactivity disorder”[All Fields] OR “Attention Deficit and Disruptive Behavior Disorders”[Mesh] OR “conduct disorder”[All Fields] OR “oppositional defiant disorder”[All Fields] OR depression OR “depressive disorder”[All Fields] OR “Bipolar Disorder”[Mesh] OR “bipolar disorder”[All Fields] OR mania OR “dysthymic disorder”[All Fields] OR “Schizophrenia”[Mesh] OR schizophrenia OR “Psychotic Disorders”[Mesh] OR “psychotic disorder”[All Fields] OR encopresis OR “Personality Disorders”[Mesh] OR “personality disorder”[All Fields] OR “behavioral disorder”[All Fields] OR “behavioral disturbance”[All Fields] OR “serious emotional distress”[All Fields] OR “emotional disorder”[All Fields] OR “Substance-Related Disorders”[All Fields] OR “substance use disorder”[All Fields] OR “drug use disorder”[All Fields] OR “Alcohol-Related Disorders”[Mesh] OR “alcohol use disorder”[All Fields] OR “alcohol dependence”[All Fields] OR alcoholism OR “drug dependence”[All Fields] OR “cannabis dependence”[All Fields] OR “marijuana dependence”[All Fields] OR “Tobacco Use Disorder”[Mesh] OR “nicotine dependence”[All Fields] OR “substance dependence”[All Fields] OR “substance abuse”[All Fields] OR “alcohol abuse”[All Fields] OR “drug abuse”[All Fields] OR “cannabis abuse”[All Fields] OR “marijuana abuse”[All Fields])))) | 990413 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#2 AND #3)) | 8847 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((“diffusion tensor” OR “diffusion tensors”)))) | 11142 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((#4 NOT #5))) | 8847 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((#4 NOT #5))) Filters: Child: birth-18 years | 1792 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH])))) | 619652 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #8) | 101 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((“Cohort Studies”[MeSH] OR (prospective AND cohort)))) | 1482309 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 and #10) | 211 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((#4 NOT #5))) Filters: Review; Child: birth-18 years | 100 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)

1/14/16 PubMed

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Health Plan Implementation”[Mesh] | 4268 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Quality Improvement”[Mesh] OR “quality improvement”[All Fields] OR “quality initiative”[All Fields])) | 29143 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Information Dissemination”[Mesh] OR “Diffusion of Innovation”[Mesh] OR “Health Information Management”[Mesh] OR Community Mental Health Services/organization and administration [mesh] OR Social Medicine/organization and administration [mesh]) | 37223 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#1 or #2 or #3)) | 69380 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Patient Acceptance of Health Care”[Mesh] OR adaptation[tiab] OR disseminat*[tiab] OR “Feasibility Studies”[Mesh] OR feasibility[tiab] OR fidelity[tiab] OR implement*[tiab] OR penetration[tiab] OR supervision[tiab] OR sustain*[tiab] OR “Information Systems”[MeSH] OR uptake[tiab])) | 1530734 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Guideline Adherence”[Mesh] OR “Evidence-Based Practice”[Mesh] OR “evidence based practice”[All Fields] OR “evidence-based practice”[All Fields] OR effect* OR evidence)) | 8271369 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#5 and #6)) | 671035 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#4 or #7)) | 729296 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“mental health”[All Fields] OR “mental illness”[All Fields] OR “mental disorders”[All Fields] OR “mental disorder”[All Fields] OR psychopathology OR “Adjustment Disorders”[Mesh] OR “adjustment disorder”[All Fields] OR “anxiety disorder”[All Fields] OR agoraphobia OR “panic disorder”[All Fields] OR “Phobic Disorders”[Mesh] OR phobia OR “Stress Disorders, Post-Traumatic”[Mesh] OR “posttraumatic stress disorder”[All Fields] OR “post-traumatic stress disorder”[All Fields] OR “generalized anxiety disorder”[All Fields] OR “Obsessive-Compulsive Disorder”[Mesh] OR “obsessive compulsive disorder”[All Fields] OR “reactive attachment disorder”[All Fields] OR “Anxiety, Separation”[Mesh] OR “separation anxiety disorder”[All Fields] OR “Eating Disorders”[Mesh] OR “eating disorder”[All Fields] OR “anorexia nervosa”[All Fields] OR “bulimia nervosa”[All Fields] OR “Attention Deficit Disorder with Hyperactivity”[Mesh] OR “attention deficit hyperactivity disorder”[All Fields] OR “Attention Deficit and Disruptive Behavior Disorders”[Mesh] OR “conduct disorder”[All Fields] OR “oppositional defiant disorder”[All Fields] OR depression OR “depressive disorder”[All Fields] OR “Bipolar Disorder”[Mesh] OR “bipolar disorder”[All Fields] OR mania OR “dysthymic disorder”[All Fields] OR “Schizophrenia”[Mesh] OR schizophrenia OR “Psychotic Disorders”[Mesh] OR “psychotic disorder”[All Fields] OR encopresis OR “Personality Disorders”[Mesh] OR “personality disorder”[All Fields] OR “behavioral disorder”[All Fields] OR “behavioral disturbance”[All Fields] OR “serious emotional distress”[All Fields] OR “emotional disorder”[All Fields] OR “Substance-Related Disorders”[All Fields] OR “substance use disorder”[All Fields] OR “drug use disorder”[All Fields] OR “Alcohol-Related Disorders”[Mesh] OR “alcohol use disorder”[All Fields] OR “alcohol dependence”[All Fields] OR alcoholism OR “drug dependence”[All Fields] OR “cannabis dependence”[All Fields] OR “marijuana dependence”[All Fields] OR “Tobacco Use Disorder”[Mesh] OR “nicotine dependence”[All Fields] OR “substance dependence”[All Fields] OR “substance abuse”[All Fields] OR “alcohol abuse”[All Fields] OR “drug abuse”[All Fields] OR “cannabis abuse”[All Fields] OR “marijuana abuse”[All Fields])) | 1001782 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#8 and #9)) | 52648 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“diffusion tensor” OR “diffusion tensors”)) | 11297 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#10 NOT #11)) | 52609 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#10 NOT #11)) Filters: Editorial | 458 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#10 NOT #11)) Filters: Editorial; Letter | 961 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#12 NOT #14)) | 51648 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((randomized[title/abstract] AND controlled[title/abstract] AND trial[title/abstract]) OR (controlled[title/abstract] AND trial[title/abstract]) OR “controlled clinical trial”[publication type] OR “Randomized Controlled Trial”[Publication Type] OR “Single-Blind Method”[MeSH] OR “Double-Blind Method”[MeSH] OR “Random Allocation”[MeSH]))) | 624632 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#15 and #16)) | 7442 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Cohort Studies”[MeSH] OR (prospective AND cohort))) | 1499221 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#15 and #18)) | 6756 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#12 NOT #14)) Filters: Review | 7413 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#17 or #19 or #20)) | 19445 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#17 or #19 or #20)) Filters: Child: birth-18 years | 4504 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((#17 or #19 or #20)) Filters: Publication date from 2015/07/14; Child: birth-18 years | 15 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)

11/13/14 Cochrane Library

ID | Search | Hits
#1 | [mh “Health Plan Implementation”] | 87
#2 | [mh “Quality Improvement”] or [mh “quality improvement”] or “quality initiative” | 303
#3 | [mh “Information Dissemination”] or [mh “Diffusion of Innovation”] or [mh “Health Information Management”] | 324
#4 | #1 or #2 or #3 | 696
#5 | [mh “Patient Acceptance of Health Care”] or adaptation or disseminat* or [mh “Feasibility Studies”] or feasibility or fidelity or implement* or penetration or supervision or sustain* or [mh “Information Systems”] or uptake | 126782
#6 | [mh “Guideline Adherence”] or [mh “Evidence-Based Practice”] or “evidence based practice” or “evidence-based practice” or effect* or evidence | 534664
#7 | #5 and #6 | 102061
#8 | #4 or #7 | 102351
#9 | “mental health” or “mental illness” or “mental disorders” or “mental disorder” or psychopathology or [mh “Adjustment Disorders”] or “adjustment disorder” or “anxiety disorder” or agoraphobia or “panic disorder” or [mh “Phobic Disorders”] or phobia or [mh “Stress Disorders, Post-Traumatic”] or “posttraumatic stress disorder” or “post-traumatic stress disorder” or “generalized anxiety disorder” or [mh “Obsessive-Compulsive Disorder”] or “obsessive compulsive disorder” or “reactive attachment disorder” or [mh “Anxiety, Separation”] or “separation anxiety disorder” or [mh “Eating Disorders”] or “eating disorder” or “anorexia nervosa” or “bulimia nervosa” or [mh “Attention Deficit Disorder with Hyperactivity”] or “attention deficit hyperactivity disorder” or [mh “Attention Deficit and Disruptive Behavior Disorders”] or “conduct disorder” or “oppositional defiant disorder” or depression or “depressive disorder” or [mh “Bipolar Disorder”] or “bipolar disorder” or mania or “dysthymic disorder” or [mh Schizophrenia] or schizophrenia or [mh “Psychotic Disorders”] or “psychotic disorder” or encopresis or [mh “Personality Disorders”] or “personality disorder” or “behavioral disorder” or “behavioral disturbance” or “serious emotional distress” or “emotional disorder” or “Substance-Related Disorders” or “substance use disorder” or “drug use disorder” or [mh “Alcohol-Related Disorders”] or “alcohol use disorder” or “alcohol dependence” or alcoholism or “drug dependence” or “cannabis dependence” or “marijuana dependence” or [mh “Tobacco Use Disorder”] or “nicotine dependence” or “substance dependence” or “substance abuse” or “alcohol abuse” or “drug abuse” or “cannabis abuse” or “marijuana abuse” | 73438
#10 | #8 and #9 | 14782
#11 | “diffusion tensor” or “diffusion tensors” | 167
#12 | #10 not #11 | 14778
#13 | editorial* or letter* | 18489
#14 | #12 not #13 | 13249
#15 | child* or children or teen or teens or teenage or teenaged or adolescen* or pediatric or paediatric* or boys or girls or youth or youths | 162576
#16 | #14 and #15 | 3712
#17 | ((randomized and controlled) and trial) or (controlled and trial) or “controlled clinical trial”:pt or “Randomized Controlled Trial”:pt or [mh “Single-Blind Method”] or [mh “Double-Blind Method”] or [mh “Random Allocation”] | 853453
#18 | #16 and #17 | 3352
#19 | [mh “Cohort Studies”] or (prospective and cohort) | 118246
#20 | #16 and #19 | 737
#21 | #18 or #20 | 3616

9/2/15 Cochrane Library

ID | Search | Hits
#1 | [mh “Health Plan Implementation”] | 91
#2 | [mh “Quality Improvement”] or [mh “quality improvement”] or “quality initiative” | 354
#3 | [mh “Information Dissemination”] or [mh “Diffusion of Innovation”] or [mh “Health Information Management”] | 346
#4 | #1 or #2 or #3 | 772
#5 | [mh “Patient Acceptance of Health Care”] or adaptation or disseminat* or [mh “Feasibility Studies”] or feasibility or fidelity or implement* or penetration or supervision or sustain* or [mh “Information Systems”] or uptake | 139013
#6 | [mh “Guideline Adherence”] or [mh “Evidence-Based Practice”] or “evidence based practice” or “evidence-based practice” or effect* or evidence | 583827
#7 | #5 and #6 | 111763
#8 | #4 or #7 | 112083
#9 | “mental health” or “mental illness” or “mental disorders” or “mental disorder” or psychopathology or [mh “Adjustment Disorders”] or “adjustment disorder” or “anxiety disorder” or agoraphobia or “panic disorder” or [mh “Phobic Disorders”] or phobia or [mh “Stress Disorders, Post-Traumatic”] or “posttraumatic stress disorder” or “post-traumatic stress disorder” or “generalized anxiety disorder” or [mh “Obsessive-Compulsive Disorder”] or “obsessive compulsive disorder” or “reactive attachment disorder” or [mh “Anxiety, Separation”] or “separation anxiety disorder” or [mh “Eating Disorders”] or “eating disorder” or “anorexia nervosa” or “bulimia nervosa” or [mh “Attention Deficit Disorder with Hyperactivity”] or “attention deficit hyperactivity disorder” or [mh “Attention Deficit and Disruptive Behavior Disorders”] or “conduct disorder” or “oppositional defiant disorder” or depression or “depressive disorder” or [mh “Bipolar Disorder”] or “bipolar disorder” or mania or “dysthymic disorder” or [mh Schizophrenia] or schizophrenia or [mh “Psychotic Disorders”] or “psychotic disorder” or encopresis or [mh “Personality Disorders”] or “personality disorder” or “behavioral disorder” or “behavioral disturbance” or “serious emotional distress” or “emotional disorder” or “Substance-Related Disorders” or “substance use disorder” or “drug use disorder” or [mh “Alcohol-Related Disorders”] or “alcohol use disorder” or “alcohol dependence” or alcoholism or “drug dependence” or “cannabis dependence” or “marijuana dependence” or [mh “Tobacco Use Disorder”] or “nicotine dependence” or “substance dependence” or “substance abuse” or “alcohol abuse” or “drug abuse” or “cannabis abuse” or “marijuana abuse” | 81224
#10 | #8 and #9 | 16367
#11 | “diffusion tensor” or “diffusion tensors” | 224
#12 | #10 not #11 | 16362
#13 | editorial* or letter* | 19927
#14 | #12 not #13 | 14707
#15 | child* or children or teen or teens or teenage or teenaged or adolescen* or pediatric or paediatric* or boys or girls or youth or youths | 172821
#16 | #14 and #15 | 4038
#17 | ((randomized and controlled) and trial) or (controlled and trial) or “controlled clinical trial”:pt or “Randomized Controlled Trial”:pt or [mh “Single-Blind Method”] or [mh “Double-Blind Method”] or [mh “Random Allocation”] | 620555
#18 | #16 and #17 | 3160
#19 | [mh “Cohort Studies”] or (prospective and cohort) | 120469
#20 | #16 and #19 | 775
#21 | #18 or #20 | 3259
#22 | #21 Publication Year from 2014 to 2015 | 304

12/9/15 Cochrane Library Add on Search

ID | Search | Hits
#1 | MeSH descriptor: [Community Mental Health Services] explode all trees and with qualifier(s): [Organization & administration - OG] | 110
#2 | MeSH descriptor: [Social Medicine] explode all trees and with qualifier(s): [Organization & administration - OG] | 2
#3 | #1 or #2 | 112
#4 | “mental health” or “mental illness” or “mental disorders” or “mental disorder” or psychopathology or [mh “Adjustment Disorders”] or “adjustment disorder” or “anxiety disorder” or agoraphobia or “panic disorder” or [mh “Phobic Disorders”] or phobia or [mh “Stress Disorders, Post-Traumatic”] or “posttraumatic stress disorder” or “post-traumatic stress disorder” or “generalized anxiety disorder” or [mh “Obsessive-Compulsive Disorder”] or “obsessive compulsive disorder” or “reactive attachment disorder” or [mh “Anxiety, Separation”] or “separation anxiety disorder” or [mh “Eating Disorders”] or “eating disorder” or “anorexia nervosa” or “bulimia nervosa” or [mh “Attention Deficit Disorder with Hyperactivity”] or “attention deficit hyperactivity disorder” or [mh “Attention Deficit and Disruptive Behavior Disorders”] or “conduct disorder” or “oppositional defiant disorder” or depression or “depressive disorder” or [mh “Bipolar Disorder”] or “bipolar disorder” or mania or “dysthymic disorder” or [mh Schizophrenia] or schizophrenia or [mh “Psychotic Disorders”] or “psychotic disorder” or encopresis or [mh “Personality Disorders”] or “personality disorder” or “behavioral disorder” or “behavioral disturbance” or “serious emotional distress” or “emotional disorder” or “Substance-Related Disorders” or “substance use disorder” or “drug use disorder” or [mh “Alcohol-Related Disorders”] or “alcohol use disorder” or “alcohol dependence” or alcoholism or “drug dependence” or “cannabis dependence” or “marijuana dependence” or [mh “Tobacco Use Disorder”] or “nicotine dependence” or “substance dependence” or “substance abuse” or “alcohol abuse” or “drug abuse” or “cannabis abuse” or “marijuana abuse” | 83018
#5 | #4 and #3 | 110
#6 | “diffusion tensor” or “diffusion tensors” | 236
#7 | #5 not #6 | 110
#8 | child* or children or teen or teens or teenage or teenaged or adolescen* or pediatric or paediatric* or boys or girls or youth or youths | 175406
#9 | #7 and #8 | 42

1/14/16 Cochrane Library

ID | Search | Hits
#1 | [mh “Health Plan Implementation”] | 93
#2 | [mh “Quality Improvement”] or [mh “quality improvement”] or “quality initiative” | 371
#3 | [mh “Information Dissemination”] or [mh “Diffusion of Innovation”] or [mh “Health Information Management”] | 347
#4 | MeSH descriptor: [Community Mental Health Services] explode all trees and with qualifier(s): [Organization & administration - OG] | 110
#5 | MeSH descriptor: [Social Medicine] explode all trees and with qualifier(s): [Organization & administration - OG] | 2
#6 | #1 or #2 or #3 or #4 or #5 | 895
#7 | [mh “Patient Acceptance of Health Care”] or adaptation or disseminat* or [mh “Feasibility Studies”] or feasibility or fidelity or implement* or penetration or supervision or sustain* or [mh “Information Systems”] or uptake | 141594
#8 | [mh “Guideline Adherence”] or [mh “Evidence-Based Practice”] or “evidence based practice” or “evidence-based practice” or effect* or evidence | 597545
#9 | #7 and #8 | 113597
#10 | #6 or #9 | 113985
#11 | “mental health” or “mental illness” or “mental disorders” or “mental disorder” or psychopathology or [mh “Adjustment Disorders”] or “adjustment disorder” or “anxiety disorder” or agoraphobia or “panic disorder” or [mh “Phobic Disorders”] or phobia or [mh “Stress Disorders, Post-Traumatic”] or “posttraumatic stress disorder” or “post-traumatic stress disorder” or “generalized anxiety disorder” or [mh “Obsessive-Compulsive Disorder”] or “obsessive compulsive disorder” or “reactive attachment disorder” or [mh “Anxiety, Separation”] or “separation anxiety disorder” or [mh “Eating Disorders”] or “eating disorder” or “anorexia nervosa” or “bulimia nervosa” or [mh “Attention Deficit Disorder with Hyperactivity”] or “attention deficit hyperactivity disorder” or [mh “Attention Deficit and Disruptive Behavior Disorders”] or “conduct disorder” or “oppositional defiant disorder” or depression or “depressive disorder” or [mh “Bipolar Disorder”] or “bipolar disorder” or mania or “dysthymic disorder” or [mh Schizophrenia] or schizophrenia or [mh “Psychotic Disorders”] or “psychotic disorder” or encopresis or [mh “Personality Disorders”] or “personality disorder” or “behavioral disorder” or “behavioral disturbance” or “serious emotional distress” or “emotional disorder” or “Substance-Related Disorders” or “substance use disorder” or “drug use disorder” or [mh “Alcohol-Related Disorders”] or “alcohol use disorder” or “alcohol dependence” or alcoholism or “drug dependence” or “cannabis dependence” or “marijuana dependence” or [mh “Tobacco Use Disorder”] or “nicotine dependence” or “substance dependence” or “substance abuse” or “alcohol abuse” or “drug abuse” or “cannabis abuse” or “marijuana abuse” | 83516
#12 | #10 and #11 | 16857
#13 | “diffusion tensor” or “diffusion tensors” | 241
#14 | #12 not #13 | 16851
#15 | editorial* or letter* | 20444
#16 | #14 not #15 | 15119
#17 | child* or children or teen or teens or teenage or teenaged or adolescen* or pediatric or paediatric* or boys or girls or youth or youths | 176120
#18 | #16 and #17 | 4141
#19 | ((randomized and controlled) and trial) or (controlled and trial) or “controlled clinical trial”:pt or “Randomized Controlled Trial”:pt or [mh “Single-Blind Method”] or [mh “Double-Blind Method”] or [mh “Random Allocation”] | 636835
#20 | #18 and #19 | 3259
#21 | [mh “Cohort Studies”] or (prospective and cohort) | 121388
#22 | #18 and #21 | 783
#23 | #20 or #22 Publication Year from 2015 to 2016 | 186

12/2/14 CINAHL

# | Query | Limiters/Expanders | Last Run Via | Results
S23 | S22 | Limiters - English Language Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 504
S22 | S21 | Limiters - Age Groups: All Child Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 507
S21 | S17 OR S19 OR S20 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 2,272
S20 | S12 | Limiters - Publication Type: Review Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 838
S19 | S12 and S18 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 273
S18 | (MH “Prospective Studies+”) AND ( prospective AND cohort ) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 28,100
S17 | S14 OR S16 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 1,178
S16 | S12 AND S15 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 1,013
S15 | ( ((randomized AND controlled) AND trial) OR (controlled AND trial) ) OR ( “controlled clinical trial” OR “single-blind method” OR “double-blind method” OR “random allocation” ) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 33,779
S14 | S12 | Limiters - Randomized Controlled Trials Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 559
S13 | S10 not S11 | Limiters - Publication Type: Editorial, Letter Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 236
S12 | S10 not S11 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 15,636
S11 | “diffusion tensor” OR “diffusion tensors” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 702
S10 | S8 AND S9 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 15,641
S9 | “mental health” OR “mental illness” OR “mental disorders” OR “mental disorder” OR psychopathology OR “Adjustment Disorders” OR “adjustment disorder” OR “anxiety disorder” OR agoraphobia OR “panic disorder” OR (MH “Phobic Disorders+”) OR phobia OR (MH “Stress Disorders, Post-Traumatic+”) OR “posttraumatic stress disorder” OR “post-traumatic stress disorder” OR “generalized anxiety disorder” OR (MH “Obsessive-Compulsive Disorder+”) OR “obsessive compulsive disorder” OR “reactive attachment disorder” OR (MH “Separation Anxiety”) OR “separation anxiety disorder” OR (MH “Eating Disorders+”) OR “eating disorder” OR “anorexia nervosa” OR “bulimia nervosa” OR (MH “Attention Deficit Hyperactivity Disorder”) OR “attention deficit hyperactivity disorder” OR (MH “Attention Deficit Hyperactivity Disorder”) OR “conduct disorder” OR “oppositional defiant disorder” OR depression OR “depressive disorder” OR (MH “Bipolar Disorder+”) OR “bipolar disorder” OR mania OR “dysthymic disorder” OR schizophrenia OR (MH “Psychotic Disorders+”) OR “psychotic disorder” OR encopresis OR (MH “Personality Disorders+”) OR “personality disorder” OR “behavioral disorder” OR “behavioral disturbance” OR “serious emotional distress” OR “emotional disorder” OR (MH “Substance Use Disorders+”) OR “Substance-Related Disorders” OR “substance use disorder” OR “drug use disorder” OR (MH “Alcohol-Related Disorders+”) OR “alcohol use disorder” OR “alcohol dependence” OR alcoholism OR “drug dependence” OR “cannabis dependence” OR “marijuana dependence” OR “Tobacco Use Disorder” OR “nicotine dependence” OR “substance dependence” OR “substance abuse” OR “alcohol abuse” OR “drug abuse” OR “cannabis abuse” OR “marijuana abuse” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 273,908
S8 | S4 OR S7 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 125,198
S7 | S5 AND S6 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 94,374
S6 | (MH “Guideline Adherence”) OR (MH “Professional Practice, Evidence-Based+”) OR “evidence based practice” OR “evidence-based practice” OR effect* OR evidence | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 656,700
S5 | “Patient Acceptance of Health Care” OR (MH “Pilot Studies”) OR adaptation OR disseminat* OR (MH “Pilot Studies”) OR feasibility OR fidelity OR implement* OR penetration OR supervision OR sustain* OR (MH “Information Systems+”) OR uptake | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 254,437
S4 | S1 OR S2 OR S3 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 34,785
S3 | “Information Dissemination” OR (MH “Diffusion of Innovation”) OR (MH “Health Information Management”) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 7,840
S2 | “quality improvement” OR “quality initiative” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 27,386
S1 | “Health Plan Implementation” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL with Full Text | 1

8/14/15 CINAHL

# | Query | Limiters/Expanders | Results
S24 | S23 | Limiters - Published Date: 20131201- Search modes - Boolean/Phrase | 113
S23 | S22 | Limiters - English Language Search modes - Boolean/Phrase | 724
S22 | S21 | Limiters - Age Groups: All Child Search modes - Boolean/Phrase | 727
S21 | S17 OR S19 OR S20 | Search modes - Boolean/Phrase | 3,223
S20 | S12 | Limiters - Publication Type: Review Search modes - Boolean/Phrase | 1,148
S19 | S12 and S18 | Search modes - Boolean/Phrase | 342
S18 | (MH “Prospective Studies+”) AND ( prospective AND cohort ) | Search modes - Boolean/Phrase | 38,311
S17 | S14 OR S16 | Search modes - Boolean/Phrase | 1,757
S16 | S12 AND S15 | Search modes - Boolean/Phrase | 1,408
S15 | ( ((randomized AND controlled) AND trial) OR (controlled AND trial) ) OR ( “controlled clinical trial” OR “single-blind method” OR “double-blind method” OR “random allocation” ) | Search modes - Boolean/Phrase | 49,635
S14 | S12 | Limiters - Publication Type: Randomized Controlled Trial Search modes - Boolean/Phrase | 975
S13 | S12 | Limiters - Publication Type: Editorial, Letter Search modes - Boolean/Phrase | 347
S12 | S10 not S11 | Search modes - Boolean/Phrase | 20,801
S11 | “diffusion tensor” OR “diffusion tensors” | Search modes - Boolean/Phrase | 1,472
S10 | S8 AND S9 | Search modes - Boolean/Phrase | 20,809
S9 | “mental health” OR “mental illness” OR “mental disorders” OR “mental disorder” OR psychopathology OR “Adjustment Disorders” OR “adjustment disorder” OR “anxiety disorder” OR agoraphobia OR “panic disorder” OR (MH “Phobic Disorders+”) OR phobia OR (MH “Stress Disorders, Post-Traumatic+”) OR “posttraumatic stress disorder” OR “post-traumatic stress disorder” OR “generalized anxiety disorder” OR (MH “Obsessive-Compulsive Disorder+”) OR “obsessive compulsive disorder” OR “reactive attachment disorder” OR (MH “Separation Anxiety”) OR “separation anxiety disorder” OR (MH “Eating Disorders+”) OR “eating disorder” OR “anorexia nervosa” OR “bulimia nervosa” OR (MH “Attention Deficit Hyperactivity Disorder”) OR “attention deficit hyperactivity disorder” OR (MH “Attention Deficit Hyperactivity Disorder”) OR “conduct disorder” OR “oppositional defiant disorder” OR depression OR “depressive disorder” OR (MH “Bipolar Disorder+”) OR “bipolar disorder” OR mania OR “dysthymic disorder” OR schizophrenia OR (MH “Psychotic Disorders+”) OR “psychotic disorder” OR encopresis OR (MH “Personality Disorders+”) OR “personality disorder” OR “behavioral disorder” OR “behavioral disturbance” OR “serious emotional distress” OR “emotional disorder” OR (MH “Substance Use Disorders+”) OR “Substance-Related Disorders” OR “substance use disorder” OR “drug use disorder” OR (MH “Alcohol-Related Disorders+”) OR “alcohol use disorder” OR “alcohol dependence” OR alcoholism OR “drug dependence” OR “cannabis dependence” OR “marijuana dependence” OR “Tobacco Use Disorder” OR “nicotine dependence” OR “substance dependence” OR “substance abuse” OR “alcohol abuse” OR “drug abuse” OR “cannabis abuse” OR “marijuana abuse” | Search modes - Boolean/Phrase | 394,194
S8 | S4 OR S7 | Search modes - Boolean/Phrase | 163,503
S7 | S5 AND S6 | Search modes - Boolean/Phrase | 123,202
S6 | (MH “Guideline Adherence”) OR (MH “Professional Practice, Evidence-Based+”) OR “evidence based practice” OR “evidence-based practice” OR effect* OR evidence | Search modes - Boolean/Phrase | 939,942
S5 | “Patient Acceptance of Health Care” OR (MH “Pilot Studies”) OR adaptation OR disseminat* OR (MH “Pilot Studies”) OR feasibility OR fidelity OR implement* OR penetration OR supervision OR sustain* OR (MH “Information Systems+”) OR uptake | Search modes - Boolean/Phrase | 348,460
S4 | S1 OR S2 OR S3 | Search modes - Boolean/Phrase | 45,135
S3 | “Information Dissemination” OR (MH “Diffusion of Innovation”) OR (MH “Health Information Management”) | Search modes - Boolean/Phrase | 10,962
S2 | “quality improvement” OR “quality initiative” | Search modes - Boolean/Phrase | 34,728
S1 | “Health Plan Implementation” | Search modes - Boolean/Phrase | 2

12/10/15 CINAHL Add on Search

# | Query | Limiters/Expanders | Last Run Via | Results
S14 | S11 OR S13 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text | 13
S13 | S8 AND S12 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text | 9
S12 | S9 OR S10 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text | 30,049
S11 | S8 | Limiters - Publication Type: Review Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text | 4
S10 | (MH “Prospective Studies+”) AND ( prospective AND cohort ) | Limiters - Age Groups: Fetus, Conception to Birth, Infant, Newborn: birth-1 month, Infant: 1–23 months, Child, Preschool: 2–5 years, Child: 6–12 years, Adolescent: 13–18 years Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text | 12,422
S9 | ((randomized AND controlled) AND trial) OR (controlled AND trial) ) OR ( “controlled clinical trial” OR “single-blind method” OR “double-blind method” OR “random allocation” | Limiters - Age Groups: Fetus, Conception to Birth, Infant, Newborn: birth-1 month, Infant: 1–23 months, Child, Preschool: 2–5 years, Child: 6–12 years, Adolescent: 13–18 years Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text | 17,827
S8 | S5 NOT S6 | Limiters - Age Groups: Fetus, Conception to Birth, Infant, Newborn: birth-1 month, Infant: 1–23 months, Child, Preschool: 2–5 years, Child: 6–12 years, Adolescent: 13–18 years Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text | 160
S7 | S5 NOT S6 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text | 996
S6 | “diffusion tensor” OR “diffusion tensors” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text | 1,610
S5 | S3 AND S4 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text | 996
S4 | “mental health” OR “mental illness” OR “mental disorders” OR “mental disorder” OR psychopathology OR “Adjustment Disorders” OR “adjustment disorder” OR “anxiety disorder” OR agoraphobia OR “panic disorder” OR (MH “Phobic Disorders+”) OR phobia OR (MH “Stress Disorders, Post-Traumatic+”) OR “posttraumatic stress disorder” OR “post-traumatic stress disorder” OR “generalized anxiety disorder” OR (MH “Obsessive-Compulsive Disorder+”) OR “obsessive compulsive disorder” OR “reactive attachment disorder” OR (MH “Separation Anxiety”) OR “separation anxiety disorder” OR (MH “Eating Disorders+”) OR “eating disorder” OR “anorexia nervosa” OR “bulimia nervosa” OR (MH “Attention Deficit Hyperactivity Disorder”) OR “attention deficit hyperactivity disorder” OR (MH “Attention Deficit Hyperactivity Disorder”) OR “conduct disorder” OR “oppositional defiant disorder” OR depression OR “depressive disorder” OR (MH “Bipolar Disorder+”) OR “bipolar disorder” OR mania OR “dysthymic disorder” OR schizophrenia OR (MH “Psychotic Disorders+”) OR “psychotic disorder” OR encopresis OR (MH “Personality Disorders+”) OR “personality disorder” OR “behavioral disorder” OR “behavioral disturbance” OR “serious emotional distress” OR “emotional disorder” OR (MH “Substance Use Disorders+”) OR “Substance-Related Disorders” OR “substance use disorder” OR “drug use disorder” OR (MH “Alcohol-Related Disorders+”) OR “alcohol use disorder” OR “alcohol dependence” OR alcoholism OR “drug dependence” OR “cannabis dependence” OR “marijuana dependence” OR “Tobacco Use Disorder” OR “nicotine dependence” OR “substance dependence” OR “substance abuse” OR “alcohol abuse” OR “drug abuse” OR “cannabis abuse” OR “marijuana abuse” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text | 409,260
S3 | S1 OR S2 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text | 1,133
S2 | “social medicine” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text | 147
S1 | (MH “Community Mental Health Services/AM”) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - CINAHL Plus with Full Text | 986

1/14/16 CINAHL

# | Query | Limiters/Expanders | Results
S26 | S25 | Limiters - Published Date: 20150701- Search modes - Boolean/Phrase | 24
S25 | S19 OR S21 OR S22 | Narrow by Language: - english Narrow by SubjectAge: - all child Search modes - Boolean/Phrase | 917
S24 | S19 OR S21 OR S22 | Narrow by SubjectAge: - all child Search modes - Boolean/Phrase | 922
S23 | S19 OR S21 OR S22 | Search modes - Boolean/Phrase | 4,359
S22 | S12 not S13 | Limiters - Publication Type: Review Search modes - Boolean/Phrase | 1,206
S21 | S14 and S20 | Search modes - Boolean/Phrase | 383
S20 | (MH “Prospective Studies+”) AND ( prospective AND cohort ) | Search modes - Boolean/Phrase | 41,656
S19 | S16 OR S18 | Search modes - Boolean/Phrase | 2,879
S18 | S14 AND S17 | Search modes - Boolean/Phrase | 2,730
S17 | (((randomized AND controlled) AND trial) OR (controlled AND trial) ) OR ( “controlled clinical trial” OR “single-blind method” OR “double-blind method” OR “random allocation” ) | Search modes - Boolean/Phrase | 93,769
S16 | S12 not S13 | Limiters - Publication Type: Randomized Controlled Trial Search modes - Boolean/Phrase | 1,037
S15 | S12 not S13 | Limiters - Publication Type: Editorial, Letter Search modes - Boolean/Phrase | 430
S14 | S12 not S13 | Search modes - Boolean/Phrase | 22,727
S13 | “diffusion tensor” OR “diffusion tensors” | Search modes - Boolean/Phrase | 1,617
S12 | S10 AND S11 | Search modes - Boolean/Phrase | 22,736
S11 | “mental health” OR “mental illness” OR “mental disorders” OR “mental disorder” OR psychopathology OR “Adjustment Disorders” OR “adjustment disorder” OR “anxiety disorder” OR agoraphobia OR “panic disorder” OR (MH “Phobic Disorders+”) OR phobia OR (MH “Stress Disorders, Post-Traumatic+”) OR “posttraumatic stress disorder” OR “post-traumatic stress disorder” OR “generalized anxiety disorder” OR (MH “Obsessive-Compulsive Disorder+”) OR “obsessive compulsive disorder” OR “reactive attachment disorder” OR (MH “Separation Anxiety”) OR “separation anxiety disorder” OR (MH “Eating Disorders+”) OR “eating disorder” OR “anorexia nervosa” OR “bulimia nervosa” OR (MH “Attention Deficit Hyperactivity Disorder”) OR “attention deficit hyperactivity disorder” OR (MH “Attention Deficit Hyperactivity Disorder”) OR “conduct disorder” OR “oppositional defiant disorder” OR depression OR “depressive disorder” OR (MH “Bipolar Disorder+”) OR “bipolar disorder” OR mania OR “dysthymic disorder” OR schizophrenia OR (MH “Psychotic Disorders+”) OR “psychotic disorder” OR encopresis OR (MH “Personality Disorders+”) OR “personality disorder” OR “behavioral disorder” OR “behavioral disturbance” OR “serious emotional distress” OR “emotional disorder” OR (MH “Substance Use Disorders+”) OR “Substance-Related Disorders” OR “substance use disorder” OR “drug use disorder” OR (MH “Alcohol-Related Disorders+”) OR “alcohol use disorder” OR “alcohol dependence” OR alcoholism OR “drug dependence” OR “cannabis dependence” OR “marijuana dependence” OR “Tobacco Use Disorder” OR “nicotine dependence” OR “substance dependence” OR “substance abuse” OR “alcohol abuse” OR “drug abuse” OR “cannabis abuse” OR “marijuana abuse” | Search modes - Boolean/Phrase | 410,207
S10 | S6 or S9 | Search modes - Boolean/Phrase | 173,796
S9 | S7 and S8 | Search modes - Boolean/Phrase | 130,730
S8 | (MH “Guideline Adherence”) OR (MH “Professional Practice, Evidence-Based+”) OR “evidence based practice” OR “evidence-based practice” OR effect* OR evidence | Search modes - Boolean/Phrase | 989,251
S7 | “Patient Acceptance of Health Care” OR (MH “Pilot Studies”) OR adaptation OR disseminat* OR (MH “Pilot Studies”) OR feasibility OR fidelity OR implement* OR penetration OR supervision OR sustain* OR (MH “Information Systems+”) OR uptake | Search modes - Boolean/Phrase | 366,648
S6 | (S1 OR S2 OR S3 OR S4 OR S5) | Search modes - Boolean/Phrase | 48,221
S5 | “social medicine” | Search modes - Boolean/Phrase | 145
S4 | (MH “Community Mental Health Services/AM”) | Search modes - Boolean/Phrase | 986
S3 | “Information Dissemination” OR (MH “Diffusion of Innovation”) OR (MH “Health Information Management”) | Search modes - Boolean/Phrase | 11,338
S2 | “quality improvement” OR “quality initiative” | Search modes - Boolean/Phrase | 36,363
S1 | “Health Plan Implementation” | Search modes - Boolean/Phrase | 3

12/2/14 PSYCINFO

# | Query | Limiters/Expanders | Last Run Via | Results
S20 | S19 | Limiters - English Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 599
S19 | S18 | Limiters - Age Groups: Childhood (birth-12 yrs), Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs), School Age (6–12 yrs), Adolescence (13–17 yrs) Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 613
S18 | S13 OR S15 OR S17 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 4,382
S17 | S12 AND S16 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 235
S16 | (DE “Cohort Analysis”) OR “cohort study” OR “cohort studies” or (prospective AND cohort) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 14,911
S15 | S12 AND S14 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2,080
S14 | ((randomized AND controlled) AND trial) OR (controlled AND trial) OR “controlled clinical trial” OR “Single-Blind Method” OR “Single-Blind Method” OR “Random Allocation” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 30,733
S13 | S12 | Limiters - Methodology: LITERATURE REVIEW Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2,364
S12 | S10 not S11 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 33,717
S11 | “diffusion tensor” OR “diffusion tensors” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 3,284
S10 | S8 AND S9 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 33,730
S9 | (“mental health” OR “mental illness” OR “mental disorders” OR “mental disorder” OR psychopathology OR “Adjustment Disorders”[Mesh] OR “adjustment disorder” OR “anxiety disorder” OR agoraphobia OR “panic disorder” OR (DE “Phobias” OR DE “Acrophobia” OR DE “Agoraphobia” OR DE “Claustrophobia” OR DE “Ophidiophobia” OR DE “School Phobia” OR DE “Social Phobia”) OR phobia OR “posttraumatic stress disorder” OR “post-traumatic stress disorder” OR “generalized anxiety disorder” OR “Obsessive-Compulsive Disorder” OR “obsessive compulsive disorder” OR “reactive attachment disorder” OR “separation anxiety disorder” OR (DE “Eating Disorders” OR DE “Anorexia Nervosa” OR DE “Binge Eating Disorder” OR DE “Bulimia” OR DE “Hyperphagia” OR DE “Kleine Levin Syndrome” OR DE “Pica” OR DE “Purging (Eating Disorders)”) OR “eating disorder” OR “eating disorders” OR “anorexia nervosa” OR “bulimia nervosa” OR (DE “Attention Deficit Disorder with Hyperactivity”) OR “attention deficit hyperactivity disorder” OR “Attention Deficit and Disruptive Behavior Disorders” OR “conduct disorder” OR “oppositional defiant disorder” OR depression OR “depressive disorder” OR (DE “Bipolar Disorder” OR DE “Cyclothymic Personality”) OR “bipolar disorder” OR mania OR “dysthymic disorder” OR (DE “Schizophrenia” OR DE “Acute Schizophrenia” OR DE “Catatonic Schizophrenia” OR DE “Childhood Schizophrenia” OR DE “Paranoid Schizophrenia” OR DE “Process Schizophrenia” OR DE “Schizophrenia (Disorganized Type)” OR DE “Schizophreniform Disorder” OR DE “Undifferentiated Schizophrenia”) OR schizophrenia OR (DE “Psychoticism”) OR “Psychotic Disorders” OR “psychotic disorder” OR encopresis OR (DE “Personality Disorders” OR DE “Antisocial Personality Disorder” OR DE “Avoidant Personality Disorder” OR DE “Borderline Personality Disorder” OR DE “Dependent Personality Disorder” OR DE “Histrionic Personality Disorder” OR DE “Narcissistic Personality Disorder” OR DE “Obsessive Compulsive Personality Disorder” OR DE “Paranoid Personality Disorder” OR DE “Passive Aggressive Personality Disorder” OR DE “Sadomasochistic Personality” OR DE “Schizoid Personality Disorder” OR DE “Schizotypal Personality Disorder”) OR “personality disorder” OR “behavioral disorder” OR “behavioral disturbance” OR “serious emotional distress” OR “emotional disorder” OR “Substance-Related Disorders” OR “substance use disorder” OR “drug use disorder” OR (DE “Alcoholic Hallucinosis” OR DE “Delirium Tremens” OR DE “Korsakoffs Psychosis” OR DE “Wernicke’s Syndrome” OR DE “Alcoholic Psychosis” OR DE “Alcoholic Hallucinosis” OR DE “Alcoholism” OR DE “Alcoholic Psychosis”) OR “alcohol use disorder” OR “alcohol dependence” OR alcoholism OR “drug dependence” OR “cannabis dependence” OR “marijuana dependence” OR “Tobacco Use Disorder” OR “nicotine dependence” OR “substance dependence” OR “substance abuse” OR “alcohol abuse” OR “drug abuse” OR “cannabis abuse” OR “marijuana abuse” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 896,839
S8 | S4 OR S7 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 120,548
S7 | S5 AND S6 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 117,248
S6 | Guideline Adherence OR Evidence-Based Practice OR “evidence based practice” OR effect* OR evidence | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1,233,597
S5 | (Patient Acceptance of Health Care OR adaptation OR disseminat* OR Feasibility Studies OR feasibility OR fidelity OR implement* OR penetration OR supervision OR sustain* OR (DE “Information Systems” OR DE “Internet”) OR uptake | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 286,703
S4 | S1 OR S2 OR S3 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 4,536
S3 | DE “Information Dissemination” OR “diffusion of innovation” OR “Health Information Management” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1,581
S2 | “Quality Improvement” OR “Quality Initiative” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2,961
S1 | “Health Plan Implementation” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2

8/14/15 PSYCINFO

# | Query | Limiters/Expanders | Last Run Via | Results
S21 | S20 | Limiters - Published Date: 20140601- Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 98
S20 | S19 | Limiters - Language: English Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 691
S19 | S18 | Limiters - Age Groups: Childhood (birth-12 yrs), Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs), School Age (6–12 yrs), Adolescence (13–17 yrs) Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 705
S18 | S13 OR S15 OR S17 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 4,957
S17 | S12 AND S16 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 271
S16 | (DE “Cohort Analysis”) OR “cohort study” OR “cohort studies” or (prospective AND cohort) | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 16,658
S15 | S12 AND S14 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2,414
S14 | ((randomized AND controlled) AND trial) OR (controlled AND trial) OR “controlled clinical trial” OR “Single-Blind Method” OR “Single-Blind Method” OR “Random Allocation” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 33,684
S13 | S12 | Limiters - Methodology: LITERATURE REVIEW Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 2,617
S12 | S10 not S11 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 36,841
S11 | “diffusion tensor” OR “diffusion tensors” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 3,859
S10 | S8 AND S9 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 36,857
S9 | (“mental health” OR “mental illness” OR “mental disorders” OR “mental disorder” OR psychopathology OR “Adjustment Disorders”[Mesh] OR “adjustment disorder” OR “anxiety disorder” OR agoraphobia OR “panic disorder” OR (DE “Phobias” OR DE “Acrophobia” OR DE “Agoraphobia” OR DE “Claustrophobia” OR DE “Ophidiophobia” OR DE “School Phobia” OR DE “Social Phobia”) OR phobia OR “posttraumatic stress disorder” OR “post-traumatic stress disorder” OR “generalized anxiety disorder” OR “Obsessive-Compulsive Disorder” OR “obsessive compulsive disorder” OR “reactive attachment disorder” OR “separation anxiety disorder” OR (DE “Eating Disorders” OR DE “Anorexia Nervosa” OR DE “Binge Eating Disorder” OR DE “Bulimia” OR DE “Hyperphagia” OR DE “Kleine Levin Syndrome” OR DE “Pica” OR DE “Purging (Eating Disorders)”) OR “eating disorder” OR “eating disorders” OR “anorexia nervosa” OR “bulimia nervosa” OR (DE “Attention Deficit Disorder with Hyperactivity”) OR “attention deficit hyperactivity disorder” OR “Attention Deficit and Disruptive Behavior Disorders” OR “conduct disorder” OR “oppositional defiant disorder” OR depression OR “depressive disorder” OR (DE “Bipolar Disorder” OR DE “Cyclothymic Personality”) OR “bipolar disorder” OR mania OR “dysthymic disorder” OR (DE “Schizophrenia” OR DE “Acute Schizophrenia” OR DE “Catatonic Schizophrenia” OR DE “Childhood Schizophrenia” OR DE “Paranoid Schizophrenia” OR DE “Process Schizophrenia” OR DE “Schizophrenia (Disorganized Type)” OR DE “Schizophreniform Disorder” OR DE “Undifferentiated Schizophrenia”) OR schizophrenia OR (DE “Psychoticism”) OR “Psychotic Disorders” OR “psychotic disorder” OR encopresis OR (DE “Personality Disorders” OR DE “Antisocial Personality Disorder” OR DE “Avoidant Personality Disorder” OR DE “Borderline Personality Disorder” OR DE “Dependent Personality Disorder” OR DE “Histrionic Personality Disorder” OR DE “Narcissistic Personality Disorder” OR DE “Obsessive Compulsive Personality Disorder” OR DE “Paranoid Personality Disorder” OR DE “Passive Aggressive Personality Disorder” OR DE “Sadomasochistic Personality” OR DE “Schizoid Personality Disorder” OR DE “Schizotypal Personality Disorder”) OR “personality disorder” OR “behavioral disorder” OR “behavioral disturbance” OR “serious emotional distress” OR “emotional disorder” OR “Substance-Related Disorders” OR “substance use disorder” OR “drug use disorder” OR (DE “Alcoholic Hallucinosis” OR DE “Delirium Tremens” OR DE “Korsakoffs Psychosis” OR DE “Wernicke’s Syndrome” OR DE “Alcoholic Psychosis” OR DE “Alcoholic Hallucinosis” OR DE “Alcoholism” OR DE “Alcoholic Psychosis”) OR “alcohol use disorder” OR “alcohol dependence” OR alcoholism OR “drug dependence” OR “cannabis dependence” OR “marijuana dependence” OR “Tobacco Use Disorder” OR “nicotine dependence” OR “substance dependence” OR “substance abuse” OR “alcohol abuse” OR “drug abuse” OR “cannabis abuse” OR “marijuana abuse” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 946,411
S8 | S4 OR S7 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 130,347
S7 | S5 AND S6 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 126,757
S6 | Guideline Adherence OR Evidence-Based Practice OR “evidence based practice” OR effect* OR evidence | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1,301,208
S5 | (Patient Acceptance of Health Care OR adaptation OR disseminat* OR Feasibility Studies OR feasibility OR fidelity OR implement* OR penetration OR supervision OR sustain* OR (DE “Information Systems” OR DE “Internet”) OR uptake | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 306,677
S4 | S1 OR S2 OR S3 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 4,927
S3 | DE “Information Dissemination” OR “diffusion of innovation” OR “Health Information Management” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1,707
S2 | “Quality Improvement” OR “Quality Initiative” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 3,226
S1 | “Health Plan Implementation” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 3

12/10/15 PsycInfo Add on Search

# | Query | Limiters/Expanders | Last Run Via | Results
S14 | S12 OR S13 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 110
S13 | S8 | Limiters - Document Type: Review-Any Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 10
S12 | S8 AND S11 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 90
S11 | S9 OR S10 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 9,679
S10 | (DE “Cohort Analysis”) OR “cohort study” OR “cohort studies” or (prospective AND cohort) | Limiters - Age Groups: Childhood (birth-12 yrs), Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs), School Age (6–12 yrs), Adolescence (13–17 yrs) Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 4,546
S9 | (randomized AND controlled) AND trial) OR (controlled AND trial) OR “controlled clinical trial” OR “Single-Blind Method” OR “Single-Blind Method” OR “Random Allocation” | Limiters - Age Groups: Childhood (birth-12 yrs), Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs), School Age (6–12 yrs), Adolescence (13–17 yrs) Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 5,172
S8 | S5 NOT S6 | Limiters - Age Groups: Childhood (birth-12 yrs), Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs), School Age (6–12 yrs), Adolescence (13–17 yrs) Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 1,520
S7 | S5 NOT S6 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 9,553
S6 | “diffusion tensor” OR “diffusion tensors | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 4,077
S5 | S3 AND S4 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 9,555
S4 | (“mental health” OR “mental illness” OR “mental disorders” OR “mental disorder” OR psychopathology OR “Adjustment Disorders”[Mesh] OR “adjustment disorder” OR “anxiety disorder” OR agoraphobia OR “panic disorder” OR (DE “Phobias” OR DE “Acrophobia” OR DE “Agoraphobia” OR DE “Claustrophobia” OR DE “Ophidiophobia” OR DE “School Phobia” OR DE “Social Phobia”) OR phobia OR “posttraumatic stress disorder” OR “post-traumatic stress disorder” OR “generalized anxiety disorder” OR “Obsessive-Compulsive Disorder” OR “obsessive compulsive disorder” OR “reactive attachment disorder” OR “separation anxiety disorder” OR (DE “Eating Disorders” OR DE “Anorexia Nervosa” OR DE “Binge Eating Disorder” OR DE “Bulimia” OR DE “Hyperphagia” OR DE “Kleine Levin Syndrome” OR DE “Pica” OR DE “Purging (Eating Disorders)”) OR “eating disorder” OR “eating disorders” OR “anorexia nervosa” OR “bulimia nervosa” OR (DE “Attention Deficit Disorder with Hyperactivity”) OR “attention deficit hyperactivity disorder” OR “Attention Deficit and Disruptive Behavior Disorders” OR “conduct disorder” OR “oppositional defiant disorder” OR depression OR “depressive disorder” OR (DE “Bipolar Disorder” OR DE “Cyclothymic Personality”) OR “bipolar disorder” OR mania OR “dysthymic disorder” OR (DE “Schizophrenia” OR DE “Acute Schizophrenia” OR DE “Catatonic Schizophrenia” OR DE “Childhood Schizophrenia” OR DE “Paranoid Schizophrenia” OR DE “Process Schizophrenia” OR DE “Schizophrenia (Disorganized Type)” OR DE “Schizophreniform Disorder” OR DE “Undifferentiated Schizophrenia”) OR schizophrenia OR (DE “Psychoticism”) OR “Psychotic Disorders” OR “psychotic disorder” OR encopresis OR (DE “Personality Disorders” OR DE “Antisocial Personality Disorder” OR DE “Avoidant Personality Disorder” OR DE “Borderline Personality Disorder” OR DE “Dependent Personality Disorder” OR DE “Histrionic Personality Disorder” OR DE “Narcissistic Personality Disorder” OR DE “Obsessive Compulsive Personality Disorder” OR DE “Paranoid Personality Disorder” OR DE “Passive Aggressive Personality Disorder” OR DE “Sadomasochistic Personality” OR DE “Schizoid Personality Disorder” OR DE “Schizotypal Personality Disorder”) OR “personality disorder” OR “behavioral disorder” OR “behavioral disturbance” OR “serious emotional distress” OR “emotional disorder” OR “Substance-Related Disorders” OR “substance use disorder” OR “drug use disorder” OR (DE “Alcoholic Hallucinosis” OR DE “Delirium Tremens” OR DE “Korsakoffs Psychosis” OR DE “Wernicke’s Syndrome” OR DE “Alcoholic Psychosis” OR DE “Alcoholic Hallucinosis” OR DE “Alcoholism” OR DE “Alcoholic Psychosis”) OR “alcohol use disorder” OR “alcohol dependence” OR alcoholism OR “drug dependence” OR “cannabis dependence” OR “marijuana dependence” OR “Tobacco Use Disorder” OR “nicotine dependence” OR “substance dependence” OR “substance abuse” OR “alcohol abuse” OR “drug abuse” OR “cannabis abuse” OR “marijuana abuse” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 957,493
S3 | S1 OR S2 | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 13,312
S2 | “social medicine” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 6,485
S1 | DE “Community Mental Health Services” | Search modes - Boolean/Phrase | Interface - EBSCOhost Research Databases Search Screen - Advanced Search Database - PsycINFO | 6,834

1/14/16 PSYCINFO

# | Query | Limiters/Expanders | Results
S23 | S22 | Limiters - Published Date: 20150701- Search modes - Boolean/Phrase | 33
S22 | S21 | Limiters - English Search modes - Boolean/Phrase | 794
S21 | S20 | Limiters - Age Groups: Childhood (birth-12 yrs), Neonatal (birth-1 mo), Infancy (2–23 mo), Preschool Age (2–5 yrs), School Age (6–12 yrs), Adolescence (13–17 yrs) Search modes - Boolean/Phrase | 811
S20 | S15 OR S17 OR S19 | Search modes - Boolean/Phrase | 5,765
S19 | S14 AND S18 | Search modes - Boolean/Phrase | 435
S18 | (DE “Cohort Analysis”) OR “cohort study” OR “cohort studies” or (prospective AND cohort) S16 | Search modes - Boolean/Phrase | 14,371
S17 | S14 AND S16 | Search modes - Boolean/Phrase | 2,702
S16 | ((randomized AND controlled) AND trial) OR (controlled AND trial) OR “controlled clinical trial” OR “Single-Blind Method” OR “Single-Blind Method” OR “Random Allocation” | Search modes - Boolean/Phrase | 35,396
S15 | S12 not S13 | Limiters - Methodology: LITERATURE REVIEW Search modes - Boolean/Phrase | 3,025
S14 | S12 not S13 | Search modes - Boolean/Phrase | 47,185
S13 | “diffusion tensor” OR “diffusion tensors” | Search modes - Boolean/Phrase | 4,126
S12 | S10 AND S11 | Search modes - Boolean/Phrase | 47,203
S11 | (“mental health” OR “mental illness” OR “mental disorders” OR “mental disorder” OR psychopathology OR “Adjustment Disorders”[Mesh] OR “adjustment disorder” OR “anxiety disorder” OR agoraphobia OR “panic disorder” OR (DE “Phobias” OR DE “Acrophobia” OR DE “Agoraphobia” OR DE “Claustrophobia” OR DE “Ophidiophobia” OR DE “School Phobia” OR DE “Social Phobia”) OR phobia OR “posttraumatic stress disorder” OR “post-traumatic stress disorder” OR “generalized anxiety disorder” OR “Obsessive-Compulsive Disorder” OR “obsessive compulsive disorder” OR “reactive attachment disorder” OR “separation anxiety disorder” OR (DE “Eating Disorders” OR DE “Anorexia Nervosa” OR DE “Binge Eating Disorder” OR DE “Bulimia” OR DE “Hyperphagia” OR DE “Kleine Levin Syndrome” OR DE “Pica” OR DE “Purging (Eating Disorders)”) OR “eating disorder” OR “eating disorders” OR “anorexia nervosa” OR “bulimia nervosa” OR (DE “Attention Deficit Disorder with Hyperactivity”) OR “attention deficit hyperactivity disorder” OR “Attention Deficit and Disruptive Behavior Disorders” OR “conduct disorder” OR “oppositional defiant disorder” OR depression OR “depressive disorder” OR (DE “Bipolar Disorder” OR DE “Cyclothymic Personality”) OR “bipolar disorder” OR mania OR “dysthymic disorder” OR (DE “Schizophrenia” OR DE “Acute Schizophrenia” OR DE “Catatonic Schizophrenia” OR DE “Childhood Schizophrenia” OR DE “Paranoid Schizophrenia” OR DE “Process Schizophrenia” OR DE “Schizophrenia (Disorganized Type)” OR DE “Schizophreniform Disorder” OR DE “Undifferentiated Schizophrenia”) OR schizophrenia OR (DE “Psychoticism”) OR “Psychotic Disorders” OR “psychotic disorder” OR encopresis OR (DE “Personality Disorders” OR DE “Antisocial Personality Disorder” OR DE “Avoidant Personality Disorder” OR DE “Borderline Personality Disorder” OR DE “Dependent Personality Disorder” OR DE “Histrionic Personality Disorder” OR DE “Narcissistic Personality Disorder” OR DE “Obsessive Compulsive Personality Disorder” OR DE “Paranoid Personality Disorder” OR DE “Passive Aggressive Personality Disorder” OR DE “Sadomasochistic Personality” OR DE “Schizoid Personality Disorder” OR DE “Schizotypal Personality Disorder”) OR “personality disorder” OR “behavioral disorder” OR “behavioral disturbance” OR “serious emotional distress” OR “emotional disorder” OR “Substance-Related Disorders” OR “substance use disorder” OR “drug use disorder” OR (DE “Alcoholic Hallucinosis” OR DE “Delirium Tremens” OR DE “Korsakoffs Psychosis” OR DE “Wernicke’s Syndrome” OR DE “Alcoholic Psychosis” OR DE “Alcoholic Hallucinosis” OR DE “Alcoholism” OR DE “Alcoholic Psychosis”) OR “alcohol use disorder” OR “alcohol dependence” OR alcoholism OR “drug dependence” OR “cannabis dependence” OR “marijuana dependence” OR “Tobacco Use Disorder” OR “nicotine dependence” OR “substance dependence” OR “substance abuse” OR “alcohol abuse” OR “drug abuse” OR “cannabis abuse” OR “marijuana abuse” | Search modes - Boolean/Phrase | 961,296
S10 | S6 OR S9 | Search modes - Boolean/Phrase | 148,469
S9 | S7 AND S8 | Search modes - Boolean/Phrase | 132,235
S8 | Guideline Adherence OR Evidence-Based Practice OR “evidence based practice” OR effect* OR evidence | Search modes - Boolean/Phrase | 1,337,708
S7 | (Patient Acceptance of Health Care OR adaptation OR disseminat* OR Feasibility Studies OR feasibility OR fidelity OR implement* OR penetration OR supervision OR sustain* OR (DE “Information Systems” OR DE “Internet”) OR uptake | Search modes - Boolean/Phrase | 318,270
S6 | S1 or S2 or S3 or S4 or S5 | Search modes - Boolean/Phrase | 18,565
S5 | “social medicine” | Search modes - Boolean/Phrase | 6,518
S4 | DE “Community Mental Health Services” | Search modes - Boolean/Phrase | 6,846
S3 | DE “Information Dissemination” OR “diffusion of innovation” OR “Health Information Management” | Search modes - Boolean/Phrase | 1,796
S2 | “Quality Improvement” OR “Quality Initiative” | Search modes - Boolean/Phrase | 3,477
S1 | “Health Plan Implementation” | Search modes - Boolean/Phrase | 4

## Grey Literature searches

### 5/7/15 ClinicalTrials.gov

174 studies found for:

“Health Plan Implementation” OR “Quality Improvement” OR “quality initiative” OR “Information Dissemination” OR “Diffusion of Innovation” OR “Health Information Management” | mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis OR Attention Deficit OR ADHD OR conduct disorder | Child

131 studies found for:

(“Patient Acceptance of Health Care” OR adaptation OR disseminat*OR “Feasibility Studies” OR feasibility OR fidelity OR implement* OR penetration OR supervision OR sustain* OR “Information Systems” OR uptake) AND (guideline* OR evidence OR effect*) | mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis OR Attention Deficit OR ADHD OR conduct disorder | Child

### 8/17/15 ClinicalTrials.gov

5 studies found for:

“Health Plan Implementation” OR “Quality Improvement” OR “quality initiative” OR “Information Dissemination” OR “Diffusion of Innovation” OR “Health Information Management” | mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis OR Attention Deficit OR ADHD OR conduct disorder | Child | received from 05/07/2015 to 08/17/2015

6 studies found for:

(“Patient Acceptance of Health Care” OR adaptation OR disseminat*OR “Feasibility Studies” OR feasibility OR fidelity OR implement* OR penetration OR supervision OR sustain* OR “Information Systems” OR uptake) AND (guideline* OR evidence OR effect*) | mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis OR Attention Deficit OR ADHD OR conduct disorder | Child | received from 05/07/2015 to 08/17/2015

### 12/16/15 ClinicalTrials.gov Add on Search

20 studies found for:

In main search terms box: “Community Mental Health” OR “social medicine”

MH Terms in Condition box: mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis OR Attention Deficit OR ADHD OR conduct disorder

Limit to Child

### 1/19/2016 and 1/21/2016 ClinicalTrials.gov

64 results found:

“Health Plan Implementation” OR “Quality Improvement” OR “quality initiative” OR “Information Dissemination” OR “Diffusion of Innovation” OR “Health Information Management” OR “Community Mental Health” OR “social medicine” | mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis OR Attention Deficit OR ADHD OR conduct disorder | Child | updated on or after 07/15/2015

39 results found:

(“Patient Acceptance of Health Care” OR adaptation OR disseminat*OR “Feasibility Studies” OR feasibility OR fidelity OR implement* OR penetration OR supervision OR sustain* OR “Information Systems” OR uptake ) AND (guideline* OR evidence OR effect*) | mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis OR Attention Deficit OR ADHD OR conduct disorder | Child | updated on or after 07/15/2015

### 5/8/15 WHO ICTRP

Character limits present and unable to use parentheses or quotes, or mix AND and OR in the same search box.

Modified searches:

QI search

In Title:

Health Plan Implementation OR Quality Improvement OR quality OR Diffusion

In Condition:

mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis

Limited to trials in children

1 results for 30 trials

“EBM search” (could not include the AND for EMB terms so the results will have to be reviewed to see if any qualify

In Title:

Patient Acceptance OR adaptation OR disseminat* OR feasibility OR fidelity OR implement* OR Information OR uptake

In Condition:

mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis

Limited to search for clinical trials in children.

69 records for 66 trials

### 8/17/15 WHO ICTRP

Character limits present and unable to use parentheses or quotes, or mix AND and OR in the same search box.Modified searches:

QI search

In Title:

Health Plan Implementation OR Quality Improvement OR quality OR Diffusion

In Condition:

mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis

Limited to trials in children

Dates: May 8, 2015 – Aug 17, 2015

results for 8 trials

“EBM search” (could not include the AND for EMB terms so the results will have to be reviewed to see if any qualify

In Title:

Patient Acceptance OR adaptation OR disseminat* OR feasibility OR fidelity OR implement* OR Information OR uptake

In Condition:

mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis

Limited to search for clinical trials in children.

Dates: May 8, 2015 – Aug 17, 2015

8 records for 8 trials

### 12/15/15 WHO ICTRP Add on Search

In title box: Community Mental Health OR social medicine

In condition box: mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis

Limited to search for clinical trials in children.

Recruitment status ALL.

1 Result

### 1/19/2016 and 1/21/2016 WHO ICTRP

#### QI Search

2 results found:

(In title): Health Plan Implementation OR Quality Improvement OR quality OR Diffusion OR Community Mental Health OR social medicine

(In condition): mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis

Limited to trials in children

Recruitment is ALL

Date of registration is 07/15/2015 -

#### EBM Search

1 result found:

(In title): Patient Acceptance OR adaptation OR disseminat* OR feasibility OR fidelity OR implement* OR Information OR uptake

(In condition): mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis

Limited to trials in children

Recruitment is ALL

Date of registration is 07/15/2015 –

### 5/13/15 NIH RePORTER

((“Health Plan Implementation” OR “Quality Improvement” OR “quality initiative” OR “Information Dissemination” OR “Diffusion of Innovation” OR “Health Information Management”) OR ((“Patient Acceptance of Health Care” OR adaptation OR disseminat OR “Feasibility Studies” OR feasibility OR fidelity OR implement OR penetration OR supervision OR sustain OR “Information Systems” OR uptake) AND (“Guideline Adherence” OR evidence OR effect))) AND (mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis) AND (child or children or teen or teens or teenage or teenaged or adolescen or pediatric or paediatric or boys or girls or youth or youths) AND (randomized AND controlled AND trial) OR (controlled AND trial) OR (“controlled clinical trial” OR “single-blind method” OR “double-blind method” OR “random allocation”)

### 8/18/15 NIH RePORTER

((“Health Plan Implementation” OR “Quality Improvement” OR “quality initiative” OR “Information Dissemination” OR “Diffusion of Innovation” OR “Health Information Management”) OR (“Patient Acceptance of Health Care” OR adaptation OR disseminat* OR “Feasibility Studies” OR feasibility OR fidelity OR implement OR penetration OR supervision OR sustain OR “Information Systems” OR uptake) AND (“Guideline Adherence” OR evidence OR effect)) AND (mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR “eating disorder” OR “eating disorders” OR anorexia OR bulimia OR psychotic OR psychosis) AND (child or children or teen or teens or teenage or teenaged or adolescen* or pediatric or paediatric or boys or girls or youth or youths) AND ((randomized AND controlled AND trial) OR (controlled AND trial) OR (“controlled clinical trial” OR “single-blind method” OR “double-blind method” OR “random allocation”))Limited to 5-1-15 to 8-17-15

### 12/15/15 NIH RePorter Add on Search

(“Community Mental Health” OR “social medicine”) AND (mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR “eating disorder” OR “eating disorders” OR anorexia OR bulimia OR psychotic OR psychosis) AND (child or children or teen or teens or teenage or teenaged or adolescen* or pediatric or paediatric or boys or girls or youth or youths) AND ((randomized AND controlled AND trial) OR (controlled AND trial) OR (“controlled clinical trial” OR “single-blind method” OR “double-blind method” OR “random allocation”))

### 1/21/2016 NIH Reporter

Limited to Award Notice Date > 7/15/2015

((“Health Plan Implementation” OR “Quality Improvement” OR “quality initiative” OR “Information Dissemination” OR “Diffusion of Innovation” OR “Health Information Management” OR “Community Mental Health” OR “social medicine”) OR ((“Patient Acceptance of Health Care” OR adaptation OR disseminat OR “Feasibility Studies” OR feasibility OR fidelity OR implement OR penetration OR supervision OR sustain OR “Information Systems” OR uptake) AND (“Guideline Adherence” OR evidence OR effect))) AND (mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis) AND (child or children or teen or teens or teenage or teenaged or adolescen or pediatric or paediatric or boys or girls or youth or youths) AND ((randomized AND controlled AND trial) OR (controlled AND trial) OR (“controlled clinical trial” OR “single-blind method” OR “double-blind method” OR “random allocation”))

### 5/8/15 DoPHER

((“Health Plan Implementation” OR “Quality Improvement” OR “quality initiative” OR “Information Dissemination” OR “Diffusion of Innovation” OR “Health Information Management”) OR ((“Patient Acceptance of Health Care” OR adaptation OR disseminat* OR “Feasibility Studies” OR feasibility OR fidelity OR implement* OR penetration OR supervision OR sustain* OR “Information Systems” OR uptake) AND (“Guideline Adherence” OR evidence OR effect*))) AND (mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis OR Attention Deficit OR ADHD OR conduct disorder OR schizophrenia OR panic OR phobic OR phobia OR obsessive compulsive OR reactive attachment OR oppositional defiant disorder OR mania OR dysthymic OR psychotic OR encopresis OR personality OR behavioral OR emotional OR Substance-Related OR substance use OR drug use OR alcoholism OR drug dependence OR cannabis OR marijuana OR Tobacco OR nicotine OR alcohol OR Adjustment OR agoraphobia)

### 8/17/15 DoPHER

((“Health Plan Implementation” OR “Quality Improvement” OR “quality initiative” OR “Information Dissemination” OR “Diffusion of Innovation” OR “Health Information Management”) OR ((“Patient Acceptance of Health Care” OR adaptation OR disseminat* OR “Feasibility Studies” OR feasibility OR fidelity OR implement* OR penetration OR supervision OR sustain* OR “Information Systems” OR uptake) AND (“Guideline Adherence” OR evidence OR effect*))) AND (mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis OR Attention Deficit OR ADHD OR conduct disorder OR schizophrenia OR panic OR phobic OR phobia OR obsessive compulsive OR reactive attachment OR oppositional defiant disorder OR mania OR dysthymic OR psychotic OR encopresis OR personality OR behavioral OR emotional OR Substance-Related OR substance use OR drug use OR alcoholism OR drug dependence OR cannabis OR marijuana OR Tobacco OR nicotine OR alcohol OR Adjustment OR agoraphobia)

### 12/16/15 DoPHER Add on Search

(Community Mental Health OR social medicine) AND (mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR eating disorder OR eating disorders OR anorexia OR bulimia OR psychotic OR psychosis OR Attention Deficit OR ADHD OR conduct disorder OR schizophrenia OR panic OR phobic OR phobia OR obsessive compulsive OR reactive attachment OR oppositional defiant disorder OR mania OR dysthymic OR psychotic OR encopresis OR personality OR behavioral OR emotional OR Substance-Related OR substance use OR drug use OR alcoholism OR drug dependence OR cannabis OR marijuana OR Tobacco OR nicotine OR alcohol OR Adjustment OR agoraphobia) – Search did not produce results in Free-text or Title search

Tried:

“Community Mental Health” OR “social medicine” in Title gave 1 result and it was about adults.

### 1/21/2016 and 1/22/2016 DoPHER

Longer search (same as for RePORTER) – 0 results

Database would not return results unless the search was one word.

### 5/8/15 CMS.gov

“Health Plan Implementation” “Quality Improvement” “quality initiative” “Information Dissemination” “Diffusion of Innovation” “Health Information Management” site:cms.gov

Results were too numerous (5000+) so I searched visually for publications on the CMS website and identified 14 publications.

Search in Innovation Center for “child” (9), “mental”(3)

Browsed Innovation Center Data and reports since they were not that numerous and found 2 reports about mental health.

### 8/18/15 CMS.gov

Search on CMS.gov doesn’t yield results, and Google search with CMS.gov as domain is also large.

Results were too numerous (5000+) so I searched visually for publications on the CMS website and identified 0 new publications.

Search in Innovation Center for “child” (9), “mental”(3); same results as last time; did not save.

### 12/15/15/ CMS.gov Add on Search

Search on CMS.gov doesn’t yield results, and Google search with CMS.gov as domain is also large.

Results were too numerous (1900+) so I searched visually for publications on the CMS website and identified 0 publications about children.

Searched in Innovation Center and there were no results.

### 1/21/16 CMS.gov

CMS.gov main site:

((“Health Plan Implementation” OR “Quality Improvement” OR “quality initiative” OR “Information Dissemination” OR “Diffusion of Innovation” OR “Health Information Management” OR “community mental health services” OR “social medicine”) OR (“Patient Acceptance of Health Care” OR adaptation OR disseminat* OR “Feasibility Studies” OR feasibility OR fidelity OR implement OR penetration OR supervision OR sustain OR “Information Systems” OR uptake) AND (“Guideline Adherence” OR evidence OR effect)) AND (mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR “eating disorder” OR “eating disorders” OR anorexia OR bulimia OR psychotic OR psychosis) AND (child or children or teen or teens or teenage or teenaged or adolescen* or pediatric or paediatric or boys or girls or youth or youths) AND ((randomized AND controlled AND trial) OR (controlled AND trial) OR (“controlled clinical trial” OR “single-blind method” OR “double-blind method” OR “random allocation”))

~2350 results, not saved

Google Advanced Search for domain CMS.gov

Using just condition terms in the “any of these words” search box and updated in the past year:

mental OR anxiety OR posttraumatic OR post-traumatic OR substance OR depression OR depressive OR bipolar OR “eating disorder” OR “eating disorders” OR anorexia OR bulimia OR psychotic OR psychosis

Changed to remove ORs since Google puts them in

mental anxiety posttraumatic post-traumatic substance depression depressive bipolar “eating disorder” “eating disorders” anorexia OR bulimia psychotic psychosis

0 results

Visually reviewing relevant tabs on CMS.gov

Searched the [underlined: Research, Statistics, Data & Systems] tab of the CMS website looking for publications in Research Reports - searched the 293 publications listed again for the condition terms (individually, the OR statement did not return results) and did not find anything.

Searched [underlined: Innovation Center] tab (Data and Reports section) for “child” (9), “mental”(3); same results as last time; did not save.

## Searches Conducted to Obtain Additional Information on Included Interventions

### 10/14/15 SIMHC extra searches for intervention names in PubMed

“availability, responsiveness, and continuity” - 12, all imported

“chica system” - 8, all imported

“Contextualized Feedback Systems” - 7, all imported

“Coping Power–training plus feedback”[all fields] OR “cp-tf”[all fields] OR “Coping Power–basic training”[all fields] OR “cp-bt” [all fields] - 12, all imported

“Intensive Quality Assurance” – 7, all imported

“metabolic monitoring training program”[all fields] - 1

P4P - 354 - 353 imported, 1 duplicate discarded.

### 10/14/15 SIMHC extra searches for author names in PubMed

Searched Last Name, First and Middle Initials (if known) OR Last Name, First Name. (Except for H Lester, which produced 520 results. “Helen Lester” produced 99 results.)

Bauer NS

Beidas RS

Bickman L

Birchwood M

Boxmeyer C

Carroll AE

Edmunds JM

Epstein JN

Garner BR

Glisson C

Godley SH

Gully KJ

Hemmelgarn A

Henggeler SW

Kelley SD

Langberg JM

Langkamp DL

Lester Helen

Lochman JE

Price BL

Rabiner D

Rayter M

Ronsley R

Schoenwald SK

Sheidow AJ

Sterling S

Wildman BG