# Results

## Introduction

This chapter presents the results of our systematic review. We first present the results of our literature searches and identify studies that met our inclusion criteria (referred to as “included studies”). We then discuss the findings from our analyses for each Key Question (KQ), providing an overview of key points and summarizing the supporting judgment for our strength of evidence (SOE) grades74 (Tables 5, 6, and 7).

Table 5 Summary of findings with strength of evidence grades: Comparative benefits of two strategies for preventing aggressive behavior^a^ (Key Question 1a)

Intervention and Comparison | Primary Outcome of Interest | Outcome N of Patients Analyzed | Strength of Evidence | Supporting Judgment | Findings and Direction of Effect
Staff training vs. usual care | Change in aggressive behavior | Aggressive behavior resulting in staff injury NR | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | Fewer assaults on staff occurred in unit that received the staff training vs. the control unit (4 vs. 5); no statistical testing reported.103
Staff training vs. usual care | Change in seclusion or restraint | Incidents of seclusion or restraint NR | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | Fewer incidents of seclusion or restraint on the unit that received the training vs. the control unit (84 vs. 228); no statistical testing reported.103
Risk assessment vs. usual care | Change in aggressive behavior | Number of aggressive patients 170 during baseline period, 458 during intervention period | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Nonsignificant 50% RR reduction with risk assessment87
Risk assessment vs. usual care | Change in aggressive behavior | Aggressive incidents 170 during baseline period, 458 during intervention period | Low | Medium risk of bias, consistency unknown—single study, direct, precise | Significant 68% RR reduction with risk assessment, p<0.0001 reported; failure to control for intraclass correlations weakens the finding.87
Risk assessment vs. usual care | Change in aggressive behavior | Rate of severe aggressive incidents 973 post-intervention | Low | Medium risk of bias, consistency unknown—single study, direct, precise | Significantly lower risk with structured risk assessment: (RR, 0.59; 95% CI, 0.41 to 0.83) p<0.001 reported; failure to control for intraclass correlations weakens the finding. Decrease achieved since baseline with risk assessment (-41%) vs. usual care (-15%), no statistical testing reported.78
Risk assessment vs. usual care | Change in aggressive behavior | Change in physical attacks 973 post-intervention | Low | Medium risk of bias, consistency unknown—single study, direct, precise | Significantly greater decrease with risk assessment (-41%) vs. usual care (-7%), p<0.001 reported; failure to control for intraclass correlations weakens the finding.78
Risk assessment vs. usual care | Change in seclusion or restraint | Secluded patients 170 during baseline period, 458 during intervention period | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Nonsignificant 8% RR increase with risk assessment.87
Risk assessment vs. usual care | Change in seclusion or restraint | Seclusion incidents 170 during baseline period, 458 during intervention period | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Nonsignificant 15% RR reduction with risk assessment.87
Risk assessment vs. usual care | Change in seclusion or restraint | Hours in seclusion 170 during baseline period, 458 during intervention period | Low | Medium risk of bias, consistency unknown—single study, direct, precise | Significant 45% RR reduction with risk assessment, p<0.0001 reported; failure to control for intraclass correlations weakens the finding.87
Risk assessment vs. usual care | Change in seclusion or restraint | Change in coercive^b^ incidents 973 post-intervention | Low | Medium risk of bias, consistency unknown—single study, indirect, precise | Significant decrease from baseline with risk assessment (-27%) vs. usual care (+10%), p<0.001 reported; failure to control for intraclass correlations weakens the finding.78

a For KQ 1a, we had no studies of eligible study design for environmental or group psychotherapeutic interventions or multimodal interventions; thus, we could not rate risk of bias.

b Coercive measures covered a wide range of measures, from forced injection of psychotropic medication to seclusion and mechanical restraint.78

CI = confidence interval; CRT = cluster randomized trial; KQ = Key Question; N = number; NR = not reported; RR = relative risk; vs. = versus.

Table 6 Summary of findings with strength of evidence grades: Comparative benefits of medication-based strategies for de-escalating aggressive behavior (Key Question 1b)

Intervention and Comparison | Primary Outcome of Interest | Outcome N of Patients Analyzed | Strength of Evidence | Supporting Judgment | Findings and Direction of Effect
Medication protocols vs. other medication protocols | Change in aggressive behavior | Aggression response rate 28 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Nonsignificant difference in rates of OAS score reduction at 90 minutes in haloperidol vs. flunitrazepam (92% vs. 80%).82
Medication protocols vs. other medication protocols | Change in aggressive behavior | Duration of aggression 91 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Nonsignificant difference in the median duration of violent and acute behavioral disturbances with droperidol vs. midazolam vs. a combination of droperidol plus midazolam (20 vs. 24 vs. 25 minutes).77
Medication protocols vs. other medication protocols | Change in aggressive behavior | Clinically significant change in OAS scores 20 | Insufficient | Low risk of bias, consistency unknown—single study, direct, imprecise | Significantly greater likelihood of improvement (decrease of four or more points) in OAS scores of aggressive or agitated behavior at 60 minutes with the combination of haloperidol plus lorazepam (100%) vs. lorazepam alone (55%), p=0.03 (note small sample size).98
Medication protocols vs. other medication protocols | Change in aggressive behavior | Time to OAS improvement 20 | Insufficient | Low risk of bias, consistency unknown—single study, direct, imprecise | Significantly improvement in shorter time to OAS improvement with the combination of haloperidol plus lorazepam vs. lorazepam alone, data NR, p=0.028 (note small sample size).98
Medication protocols vs. other medication protocols | Change in aggressive behavior | Sedation score at 5, 10, 15, 30, and 60 minutes 202 | Insufficient | High risk of bias, consistency unknown—single study, direct, precise | Significantly lower mean sedation scores (i.e., less combative, violent, or out of control behavior) at 10, 15, 30 and 60 minutes with droperidol vs. lorazepam, each p <0.001^102^
Medication protocols vs. other medication protocols | Change in aggressive behavior | Change in CGI-A scores 558 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | No differences found in changes in percentages of patients with CGI-A score ≥3 from baseline to day 6 or to last day of observation with olanzapine vs. risperidone vs. haloperidol, p=NR.106
Medication protocols vs. other medication protocols | Change in aggressive behavior | Change in MOAS total aggression scores 101 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Nonsignificant differences between risperidone vs. olanzapine vs. quetiapine vs. haloperidol in changes in mean total MOAS scores from baseline to 72 hours.99

CGI-A = Clinical Global Impression Severity of Illness – Aggression; MOAS = Modified Overt Aggression Scale; n = number of patients; NR = not reported; OAS = Overt Aggression Scale; vs. = versus.

Table 7 Summary of findings with strength of evidence grades: Comparative benefits of medication-based strategies for reducing seclusion and restraint use in aggressive patients (Key Question 1c)

Intervention and Comparison | Primary Outcome of Interest | Outcome N of Patients Analyzed | Strength of Evidence | Supporting Judgment | Findings and Direction of Effect
Medication protocols vs. other medication protocols or usual care | Change in seclusion or restraint | Seclusion incident rate 659 | Insufficient | High risk of bias, consistency unknown—single study, direct, precise | Significant lower risk with involuntary medication^a^ as first choice vs. seclusion as first choice (RR, 0.51; 95% CI, 0.34 to 0.79), p<0.001^86^
Medication protocols vs. other medication protocols or usual care | Change in seclusion or restraint | Seclusion hours 659 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | Lower number of overall hours with involuntary medication^a^ as first choice vs. seclusion as first choice (998 vs. 2,098), no statistical testing reported86
Medication protocols vs. other medication protocols or usual care | Change in seclusion or restraint | Seclusion duration 659 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | Longer mean duration with involuntary medication^a^ as first choice vs. seclusion as first choice (32 vs. 30 hours), no statistical testing reported86
Medication protocols vs. other medication protocols or usual care | Change in seclusion or restraint | Seclusion duration rate 659 | Insufficient | High risk of bias, consistency unknown—single study, direct, precise | Significant lower risk with involuntary medication^a^ as first choice vs. seclusion as first choice (RR, 0.54; 95% CI, 0.5 to 0.58) p<0.001^86^
Medication protocols vs. other medication protocols or usual care | Change in seclusion or restraint | Mechanical restraint incident rate 659 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | No significant difference in involuntary medication^a^ as first choice vs. seclusion as first choice (RR, 1.44; 95% CI, 0.38 to 5.36).86
Medication protocols vs. other medication protocols or usual care | Change in seclusion or restraint | Duration in restraints 200 | Insufficient | High risk of bias, consistency unknown—single study, direct, precise | Significant decrease with single-dose delirium treatment vs. no delirium treatment, both in the first 24 hours, 3 vs. 6 days, p<0.001^85^
Medication protocols vs. other medication protocols or usual care | Change in seclusion or restraint | Coercive incident rate^b^ 659 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | No significant difference in coercive incident rate in involuntary medication^a^ vs. seclusion as first choice options (RR, 0.95; 95% CI, 0.67 to 1.35)86

a “Involuntary medication” refers to singled dose haloperidol plus promethazine or lorazepam.

b “Coercion” refers to a sequence of coercive episodes (seclusion, mechanical restraint, or involuntary medication) for less than 24 hours.

CI = confidence interval; N = number; RR = relative risk; vs. = versus.

Next, we present the detailed synthesis organized first by subquestion (e.g., 1a, 1b, 1c), second by intervention type, and third by the study design. The last factor involves two main classifications: (a) randomized controlled trials (RCTs), nonrandomized controlled trials (NRCTs), and cohort studies and (b) pre/post studies without an independent control group (referred to as “pre/post studies”). The former group represents all studies with at least one independent control group; we included them in SOE grades. The second pre/post group refers to studies that we did not use for SOE grading. As described in Methods, we did not assign risk of bias ratings to pre/post studies or grade the SOE for those studies because they are very limited in their ability to support causal inferences, largely as a result of potential confounding from multiple sources that generally do not affect controlled studies as much.

KQ 1 focuses on the effectiveness of strategies to prevent aggressive behavior in persons without active aggression (KQ 1a) and, in those exhibiting active aggression, to de-escalate aggressive behavior (KQ 1b) or reduce the use of seclusion and/or restraints (KQ 1c). A study could have data relevant to one or more subquestions. Some studies were challenging to classify into these subquestions. For example, some outcome measures combined prevention of aggression (1a) with response to aggressive behavior (relevant to 1b or 1c). Multimodal interventions were usually policies and considered preventive (1a), but sometimes they included components that were specifically in response to aggressive behavior (1b or 1c). Our decisions about classification were guided by the populations involved in the reported analyses. For example, if the denominator included all patients on a unit (which could involve both those actively aggressive and those not), we considered the data to be relevant to subquestion (a). If the denominator included only those patients who were actively aggressive, we regarded those data as relevant to subquestion (b) or (c). If the study provided an analysis for the general population (a) but also provided a subanalysis for the aggressive group (b or c), it could provide data relevant to multiple subquestions.

KQ 2 evaluates the harms resulting from the same strategies evaluated in KQ 1; its organization of findings and classification of studies mirrors that of KQ 1. KQ 3 evaluates potential moderators of the benefits or harms of strategies to prevent or de-escalate aggressive behavior or use of seclusion or restraints, and it also follows the same structure as KQs 1 and 2.

## Results of Literature Searches

Searches of all sources identified a total of 1,921 potentially relevant citations. In all, we included 29 primary studies (described in 31 articles) that compared interventions to de-escalate aggressive behavior or reduce the use of seclusion or restraints with an alternative strategy or usual care and provided data for our KQs.76-106 Figure 2 describes the flow of literature through the screening process according to PRISMA (Preferred Reporting Items for Systematic Reviews and Meta-Analyses) categories.62 Appendix A presents our search strategy, and Appendix B provides a complete list of articles excluded at the full-text screening stage with reasons for exclusion.

Figure 2 Disposition of articles for strategies to de-escalate aggressive behavior

^a^ This minimum sample size requirement only applies to nonrandomized studies.

KQ = Key Question; PICOTS = Populations-Interventions-Comparators-Outcomes-Time Frames-Settings.

The PRISMA flowchart presents the yield of our literature retrieval process and the results of each stage of literature review, including title and abstract review, and full-text article review. We retrieved a total of 1,983 records through electronic database searches and other sources, including MEDLINE, Embase, PsycINFO, the Cochrane Library, CINAHL, ClinicalTrials.gov, Academic Search Premier, NIH RePORTer, WHOLIS, the Substance Abuse and Mental Health Services Administration Website, hand searches of other publications' reference lists, and bibliographies of relevant reviews. After removal of 326 duplicate records, we screened 1,921 titles and abstracts, and excluded 1,624 of these. We then reviewed 297 full-text articles for eligibility. Of these, we excluded 266 articles because of ineligible publication type, ineligible study design, ineligible PICOTS, not addressing any of our KQs, an ineligible sample size for nonrandomized studies (i.e., fewer than 100 patients), or because articles were unretrievable. The final yield included in the systematic review was 29 studies with 31 articles.

## Description of Included Studies

The included studies focused predominantly on benefits, reporting on aggressive behavior and seclusion or restraint use (or both); 15 studies also reported harms, such as adverse effects of medications or suicide attempts76,77,80-82,88,90,91,94,98,99,101-103,106 (Table 3). Most interventions (n=19) took place in psychiatric hospitals or inpatient psychiatric treatment units or facilities;76,79-81,88,89,92 five were in emergency department settings.77,93,98,99,102 Half (n=15) took place in the United States.

Table 3 Characteristics of included studies

Study Characteristic | Number (%)
Country
United States | 15 (52)
Outside the United States | 14 (48)
Funding^a^
Government | 7 (24)
Foundations/nonprofit | 3 (10)
Academic (treating hospital) | 1 (3)
Pharmaceutical company | 1 (3)
Multiple (foundation and government) | 2 (7)
Internal funding | 1 (3)
No financial support | 1 (3)
Not reported | 13 (45)
Settings
Public psychiatric hospital | 5 (17)
Private or academic psychiatric hospital | 2 (7)
Inpatient psychiatric treatment units or facilities^b^ | 10 (35)
Multiple (inpatient psychiatric or forensic hospitals) | 1 (3)
Multiple (inpatient psychiatric wards and psychiatric emergency department) | 1 (3)
General medical hospital | 2 (7)
General emergency department | 2 (7)
Psychiatric emergency department | 3 (10)
Psychiatric intensive care unit | 3 (10)
Study design
Randomized controlled trial | 5 (17)
Cluster randomized trial | 3 (10)
Nonrandomized controlled trial | 2 (7)
Retrospective cohort study | 1 (3)
Pre/post study with no control group (not included in strength of evidence grading) | 18 (62)
Used an active treatment comparison arm | 6 (21)
Primary outcomes measured
Aggression | 21 (72)
Seclusion | 7 (24)
Restraints | 12 (41)
Seclusion and restraints | 10 (35)
Harms | 15 (52)
Risk of Bias
Low | 1 (9)
Medium | 5 (45.5)^c^
High | 5 (45.5)^c^

a Percentages of studies funded by different sources add up to a slightly smaller or greater value than 100%, but these numbers do reflect all included studies.

b No further information about their public, private, or academic status.

c Percentages based on a total of 11 studies that used controlled designs and therefore received risk of bias ratings.

Generally, for those studies reporting on demographics for their patient populations, the mean age ranged between 38 and 40 years, the distribution by males and females varied widely across studies, and race or ethnicity was sparsely reported. Of these 29 studies, 19 took place in acute inpatient psychiatric settings, and most involved serious mental illness diagnoses. The majority of articles did not, however, report the proportion of patients with agitated or aggressive behavior. Patient characteristics are further detailed in Appendix E.

Our interventions are presented in five broad categories of interventions: staff training, risk assessment, multimodal, environmental or group psychotherapeutic, or medication protocols. Staff training interventions aim to equip clinical staff providing acute care to patients with psychiatric symptomatology with new skills and/or promote staff attitudes that can help prevent or de-escalate aggression. Risk assessment interventions involve clinical staff's use of structured assessment of individual patients' risk of becoming actively aggressive. Multimodal interventions involve a combination of different intervention types (e.g., enhanced administrative review of patients with high restraint use, staff training in strategies to better manage patients' difficult behavior) with the purpose of decreasing the occurrence of active aggression or use of seclusion and/or restraint for managing active aggression. Environmental or group psychotherapeutic interventions involve changes to the physical environment of the acute care setting or the introduction of group psychotherapeutic interventions meant to diminish precursors to active aggression. Finally, medication protocols encompass any medication-focused intervention, ranging from hospital or unit-wide policies specifically affecting how or which medications can be used to manage active aggression to the use of emergency medication(s) to de-escalate active aggression.

Interventions could focus on preventing aggression (KQ 1a, KQ 2a), de-escalating aggression (KQ 1b, KQ 2b), and de-escalating aggression to reduce use of seclusion and restraints (KQ 1c, KQ 2c). Studies that did not differentiate their results between those patients with aggression and those who were not yet aggressive were included in the prevention of aggressive behavior results. Table 4 shows the assumed main focus of the studies, the two KQs (and subquestions) they address, and the nature of evidence report (benefits only or benefits and harms). The table has no information on KQ 3, because no studies reported on potential modifiers that would have been relevant to the other KQs.

Table 4 Five classes of interventions by focus and available evidence

Intervention Category | Prevention (KQ 1a, KQ 2a) | De-escalation (KQ 1b, KQ 2b) | De-escalation and Reduce Seclusion or Restraints (KQ 1c, KQ 2c)
Staff training | 1 NRCT reporting benefits and harms; 3 pre/post studies reporting only on benefits | Data not reported by those presenting with aggression | No studies
Risk assessment | 2 CRTs reporting on only benefits | Not applicable | Not applicable
Multimodal programs | 11 pre/post studies, 5 reporting benefits and harms, 6 reporting only on benefits | Data not reported by those presenting with aggression | No studies
Environmental or group psychotherapeutic interventions | 3 pre/post studies, 1 reporting both benefits and harms, 2 reporting only on benefits | No studies | No studies
Medication protocols | No studies | 4 RCTs reporting benefits and harms 2 NRCTs reporting benefits and harms | 1 RCT and 1 retrospective cohort reporting only on benefits 1 pre/post study reporting on benefits and harms

CRT = cluster randomized trial; KQ = Key Question; NRCT = nonrandomized controlled trial; RCT = randomized controlled trial.

Of the 29 primary studies, 11 were controlled trials that provided eligible data for SOE ratings; only 4 took place in the United States,85,98,102,103 1 in a psychiatric inpatient unit,103 2 in an emergency department,98,102 and 1 in an intensive care unit with intubated patients.85 All controlled trials occurred in inpatient psychiatric settings except for those involving medication protocols, which also involved emergency department73,77,98,99,102 or intensive care unit (ICU) settings.85 The remaining 18 studies were pre/post studies, for which we did not grade SOE; we identified no interrupted time-series studies. We report below in Key Points only on findings from trials or studies for which we could grade SOE.

We had data for KQs 1 (benefits) and 2 (harms) from the following types of trials or studies: KQ 1a (benefits of prevention), three CRTs; KQ 1b (benefits of de-escalating aggression), four RCTs and two NRCTs; KQ 1c (benefits of reducing seclusion/restraint use), one RCT and one retrospective cohort study; KQ 2a (harms of prevention), one CRT; and KQ 2b (harms of de-escalating aggression), four RCTs and two NRCTs. No eligible studies pertained to KQ 2c. We identified no eligible studies for KQ 3.

We found the SOE for most of the findings to be insufficient, with the justification for these assessments provided in the tables below (see Appendix D of the main report for detail about scores for each SOE domain). To help clarify this literature's range of different types of studies, and the heterogeneity of approaches, populations, settings, and outcomes, we report below the findings for all 11 eligible studies, whether the SOE was insufficient or low. We report the findings as the authors reported them; we then indicate the SOE for the finding.

## Comparative Benefits of Strategies (Key Question 1)

### Key Points

#### Key Question 1a Benefits of Strategies To Prevent Aggressive Behavior

##### Staff Training Interventions Versus Usual Care

- One CRT reported staff training in interpersonal communication led to fewer incidents of seclusion and restraint, and a larger decrease in incidents of seclusion and restraint compared to usual care on a control unit103 (one CRT, insufficient SOE).

##### Risk Assessment Interventions Versus Usual Care

- Units employing structured risk assessment protocols reported fewer aggressive incidents when compared with usual-care units. One CRT78 focused on lowering severe aggressive incidents; the other87 focused on any aggressive incidents (one CRT for each outcome, low SOE).
- Cluster trials in which units employed structured risk assessment protocols reported fewer hours spent in seclusion87 (one CRT, low SOE) and fewer coercive measures than usual-care units78 (one CRT, low SOE).

##### Multimodal Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Environmental or Group Psychotherapeutic Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Medication Protocols Versus Other Medication Protocols or Alternative Strategies

- We identified no eligible studies (insufficient SOE).

In Table 5 for KQ 1a, we present our supporting judgment for our SOE grades for evidence from studies with eligible study designs (i.e., any study that we could rate for risk of bias). Supporting judgment is essentially the ratings on the main domains for grading SOE (study limitations [i.e., risk of bias], consistency, directness, and precision). The CRTs in this report did not control for clustering in their statistical analyses, which weakened the SOE grade. Table 5 has entries only for staff training (one CRT) and for risk assessment strategies (two studies); we had no relevant studies for the other three types of interventions.

#### Key Question 1b Benefits of Strategies To De-escalate Aggressive Behavior

##### Staff Training Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Risk Assessment Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Multimodal Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Environmental or Group Psychotherapeutic Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Medication Protocols Versus Other Medication Protocols or Alternative Strategies

- In an inpatient psychiatric unit, effects of intramuscular haloperidol did not differ from effects of intramuscular flunitrazepam for treating patients displaying aggressive psychotic behavior82 (one RCT, insufficient SOE).
- In a public psychiatric hospital emergency department, intramuscular droperidol for treating patients exhibiting violent and acute behavioral disturbance did not reduce the duration of aggressive behavior any more than intramuscular midazolam, but droperidol treatment did result in fewer patients requiring additional sedative medication over the ensuing 6 hours than intramuscular midazolam77 (one RCT, insufficient SOE).
- In a hospital psychiatric emergency service, compared with intramuscular lorazepam, intramuscular lorazepam plus haloperidol for treating patients exhibiting serious, acute agitated, or aggressive behavior did not result in greater overall reduction in aggressive or agitated behavior, but the medication regimen did produce a more rapid reduction in aggressive or agitated behavior and more patients who achieved clinically significant improvement in aggressive or agitated behavior98 (one RCT, insufficient SOE).
- In an urban university emergency department, intramuscular droperidol for intoxicated or psychiatrically ill, violently agitated patients requiring chemical restraint produced more rapid sedation and greater sedation overall than intramuscular lorazepam102 (one RCT, insufficient SOE).
- In an inpatient psychiatric hospital setting, treatments that included any olanzapine, any risperidone, or any haloperidol for treating patients with agitation did not differ from each other in reducing aggressive behavior or suicidality106 (one NRCT, insufficient SOE).
- In an inpatient psychiatric emergency service, oral risperidone, olanzapine, quetiapine, or haloperidol for treating patients with agitation did not differ from each other in reducing aggressive behavior99 (one NRCT, insufficient SOE).

In Table 6 for KQ 1b, we present information (supporting judgment) for our SOE grades for evidence based on studies with an eligible study design. For this subquestion, we had no relevant studies of staff training, risk assessment, multimodal, or environmental or group psychotherapeutic interventions. All findings for the medications protocols were underpowered to test noninferiority.

#### Key Question 1c Benefits of Strategies To Reduce Seclusion and Restraint Use in Aggressive Patients

##### Staff Training Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Risk Assessment Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Multimodal Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Environmental or Group Psychotherapeutic Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Medication Protocols Versus Other Medication Protocols or Alternative Strategies

- One RCT in an inpatient psychiatric unit involved acutely agitated and violent inpatients and compared a first choice of involuntary medication treatment with oral or intramuscular haloperidol plus promethazine with a first choice of seclusion.86 Compared with seclusion, the medication option did not produce differences either in subsequent mechanical restraint use (one RCT, insufficient SOE) or in subsequent coercive incidents (i.e., seclusion, restraint, or involuntary medications) (one RCT, insufficient SOE).
- For treating delirium in an inpatient ICU, immediate (within 24 hours) treatment with at least one dose of an antipsychotic medication led to fewer mean days in restraints than did delayed or no treatment85 (one retrospective cohort, insufficient SOE).

In Table 7 on KQ 1c, we present our supporting judgment for our SOE grades for each eligible study (in this case only for medication protocols).

### Detailed Synthesis

We describe in separate sections the studies with benefits data relevant to KQ 1a (prevention of aggressive behavior), KQ 1b (de-escalating aggressive behavior), and KQ 1c (de-escalating aggressive behavior and reducing seclusion and restraints). We present the studies by intervention, then by study design. Appendix D presents detailed SOE tables for each KQ 1 primary outcome, organized by intervention type. Appendix E contains detailed study characteristics tables across all intervention types. Summary tables presenting all characteristics and outcomes for all pre/post studies are available in Appendix F.

#### Key Question 1a Prevention of Aggressive Behavior

Evidence on prevention of aggressive behavior (Table 8) came from the following: (a) three CRTs (one staff training intervention, two risk assessment interventions), all with usual-care comparators. None of the CRTs controlled for interclass correlations, likely increasing the risk of detecting an effect that is not actually present. We also found three pre/post studies of staff training interventions and 11 pre/post studies of multimodal interventions (policies to prevent aggressive behavior); as explained earlier, however, we did not rate these types of studies for risk of bias or grade their SOE.

Table 8 Characteristics, outcomes, and risk of bias rating of three controlled studies to prevent aggressive behaviors (Key Question 1a)

Intervention First Author, Year Study Design Setting, Country | N Duration (Months) | Intervention Comparator | Aggressive Behavior | Restraint Use Seclusion Use | Seclusion and Restraint | Risk of Bias Rating
Staff Training: Smoot et al., 1995^103^ CRT Inpatient psychiatric recidivist units^a^ United States | NR^b^ 15 months^c^ | G1: Empathic interpersonal communication training program for hospital staff G2: Usual care | Percentage change from baseline in assaults on staff (n's at baseline, endpoint) G1: -20.0 (from 5 to 4) G2: -61.5 (from 13 to 5) p=NR | NR NR | Percentage change from baseline in incidents of use of seclusion and restraint G1: -30.0 G2: +100.0 p=NR | High
Risk Assessment: Abderhalden et al., 2008, 2011^78^ CRT Psychiatric inpatient treatment facilities Switzerland | 973 post-intervention 6 months (3 months baseline, 3 months intervention) | G1: Structured violence risk assessment, 4 unit cluster (n=390) G2: Usual care, 5-unit cluster (n=583) | Severe aggressive incidents over 3 months, total n G1: 60 G2: 100 p=NR Severe aggressive incidents, percentage change from baseline G1: -41% (RR 0.59, 95% CI, 0.41 to 0.83, p<0.001) G2: -15% (RR 0.85, 95% CI, 0.64 to 1.13) p=NR Physical attacks^e^ over 3 months, total n (% change) G1: 38 (-41%) G2: 55 (-7%) p<0.001 | NR NR | Coercive measures^d^ over 3 months, total n G1: 135 G2: 126 p=NR Coercive measures, percentage change from baseline G1: -27% G2: +10% p<0.001 | Medium
Risk Assessment: van de Sande et al., 2011^87^ CRT Acute psychiatric units Netherlands | 170 (baseline period), 458 (intervention period) 40 weeks (10 weeks baseline, 30 weeks intervention) | G1: Structured violence risk assessment, 2 unit cluster (n=80 [baseline period], 207 [intervention period]) G2: Usual care, 2-unit cluster (n=90 [baseline period], 251 [intervention period]) | Aggressive patients over 30 weeks, total n G1: 29 G2: 62 -50% decrease in G1 vs. G2 (in comparison of change from baseline and intervention periods) p>0.05 Incidents of aggression during first 3 days, total n G1: 4 G2: 19 p=0.001 Incidents of aggression over 30 weeks, total n G1: 52 G2: 117 -68% decrease in G1 vs. G2 (in comparison of change from baseline and intervention periods) p<0.0001 | NR Patients secluded during 30 weeks, total n G1: 60 G2: 42 +8% increase in G1 vs. G2 (in comparison of change from baseline and intervention periods) p<0.10 Incidents of seclusion over 30 weeks, total n G1: 93 G2: 75 -15% decrease in G1 vs. G2 (in a comparison of change between baseline and intervention periods) Unadjusted p>0.05 Duration of seclusion over 30 weeks, total hours G1: 1,624 G2: 2,149 -45% decrease in G1 vs. G2 (in comparison of change from baseline and intervention periods) p<0.0001 | NR | Medium

a The two study units specialized in caring for people with a primary diagnosis of mental illness who had returned to the hospital within one year of a prior discharge.103

b Mean of 92 patients discharged per month in each unit, meaning about 184 patients were included in the study each month.103

c Baseline period was 6 months long (July to December 1990), training period was 3 months long (April to June 1991), and post-training period was 6 months long (July to December 1991).103

d Coercive measures covered a wide range of measures, from forced injection of psychotropic medication to seclusion and mechanical restraint.87

e Physical attacks were defined as aggressive incidents in which the SOAS-R description met both of the following criteria: (1) means of aggression involved objects, dangerous objects, or parts of the body, and (2) the target of aggression was a person other than the patient him or herself.87

CRT = cluster randomized trial; G = group; N = number; NR = not reported; SOAS-R = Staff Observation Aggression Scale-Revised; vs. = versus.

##### Staff Training Interventions Versus Usual Care

###### Controlled Studies

One CRT (Table 8 above) tested a staff training intervention targeted at de-escalation of aggressive behavior.103 The study was conducted on two psychiatric units in the United States; both specialized in treating adults with a primary mental health diagnosis who returned to the hospital within one year of discharge. The units were similar in size and function, and they served approximately 92 patients per month. One unit was randomized to the intervention, and the other unit served as the control. Of the 35 staff on the intervention unit, 19 received a 32-hour program in four sequential, 8-hour sessions that were held weekly. The major skill taught was accurate empathy; training (through interpersonal communication training) included both didactic and role-playing components. Outcomes included incidents of seclusion and restraints, and assaults on staff. On the intervention unit, assaults on staff declined from five in the 1-year period before the intervention to four in the year following the intervention (20.0% decrease). On the control unit, assaults on staff decreased from 13 to 5 (61.5% decrease) during this time period. Seclusion and restraint incidents declined from 120 to 84 (30.0% decrease) on the intervention unit and increased on the control unit from 114 to 228 (100.0% increase). The investigators did not report tests of statistical significance.

###### Pre/Post Studies

Three staff training intervention studies targeted the de-escalation of aggressive behavior using a pre/post design.84,96,97 One study84 took place in an urban psychiatric inpatient unit in the United States and used a recovery-oriented cognitive therapy milieu training program for 29 staff members. Staff participated in 2-hour weekly sessions for 4 weeks (8 hours total). Psychiatrists and senior psychologists received a condensed version (4 hours total). The program aimed to promote staff empathy, warmth, and genuineness and an understanding of challenging behaviors, such as aggression, and to develop tools that allow staff to prevent patients' maladaptive behavior from escalating to the point of physical or chemical intervention. Outcomes included incidents of seclusion and restraint, which declined from 19 in the 4 months before the intervention to 7 incidents in the 4 months after the intervention. Because of the limited number of cases, the investigators did not perform statistical analyses.

Another pre/post study assessed the effects of training courses in prevention and management of violence and aggression and rates of violence.96 The intervention was conducted on 14 acute care psychiatric units in three hospitals in the United Kingdom. One unit was female only, the second was for assessments, and the remainder were mixed-gender units. Training consisted of either a 5-day foundation course or a 1-day annual update; it focused on prediction, anticipation, and prevention of violence, including response to aggression, de-escalation, communication skills, problem solving skills, and skills with restraints. Outcomes included incidents of verbal aggression, property damage, and physical aggression. Time frames for measurement of outcomes included 1- and 4-week periods. No results were reported for rates of aggression after the 5-day course, using the 4-week time frame. However, the investigators found significantly higher rates of physical (incidence rate ratio [IRR], 1.50; p<0.001) and verbal aggression (IRR, 1.34; p=0.042) in the week that staff received training in the 5-day course; the authors interpreted this as evidence that aggression increased when staff were in training. With regard to the update course, physical aggression increased 1 month after the update course (IRR, 1.17; p<0.001); verbal aggression dropped 1 month after the update course (IRR, 0.79; p=0.019) but increased 2 months after it (IRR, 1.13; p=0.026). Physical aggression also rose 3 weeks (IRR, 1.17; p=0.04) and 4 weeks after the update course (IRR, 1.20; p=0.019); verbal aggression rose in the week that staff received the update training (IRR, 1.21; p=0.038).

Finally, a pre/post study was conducted in a psychiatric intensive care unit in the United Kingdom.97 The intervention consisted of training in prevention of aggressive incidents, de-escalation, and restraints. Other details about the training, such as the extent (i.e., number of hours), were not specified. Outcomes included both the number of incidents and the severity of incidents. Severe incidents were those that required seclusion or increased staffing (e.g., 1:1 or 2:1) or rapid tranquilization. Outcomes were measured for the 6 months before and after the training intervention. The intervention had no effect on the rate of aggressive incidents in an unadjusted model (odds ratio [OR], 0.986; p=0.92). Similarly, the intervention had no effect on the proportion of incidents that were severe in an unadjusted model (OR, 0.577; p=0.064), or the proportion of incidents that required rapid tranquilization using an unadjusted model (OR, 0.876; p=0.704). The proportion of incidents requiring hands-on intervention was not statistically significantly different in an unadjusted model (OR, 0.517; p=0.097). Findings based on adjusted models for this study's outcomes are described in Appendix F.

##### Risk Assessment Interventions Versus Usual Care

###### Controlled Studies

Two CRTs compared the use of a structured risk assessment protocol with usual care78,87 (Table 8 above). Both trials used the Brøset Violence Checklist as part of the protocol. However, one trial used a more comprehensive protocol that included a Crisis Monitor form and the Kennedy-Axis V (short version) on a daily basis and the full version of the Kennedy-Axis V, the Brief Psychiatric Rating Scale, the Dangerousness Scale, and the Social Dysfunction and Aggression Scale on a weekly basis.87

The trials also differed in the length of time over which they evaluated their risk assessment protocols. For example, the first trial78 implemented the risk assessment protocol for the first 3 days, whereas the van de Sande et al. trial from The Netherlands87 used the risk assessment protocol throughout each patient's stay. To measure aggressive behavior, the trials used the Staff Observation Aggression Scale-Revised (SOAS-R); however, one trial evaluated “severe” aggression (i.e., SOAS-R score ≥9),78 whereas the other trial evaluated only aggression,87 preventing us from pooling results. All patients in both trials were at least 18 years old (mean ages from 38 to 40 years); the majority of patients were male. Only van de Sande et al.87 reported on patients' race or ethnicity. During the baseline period, the trial classified approximately one-quarter of patients as ethnic minorities; this proportion increased to approximately one-third during the intervention period.

The Swiss trial reported few baseline differences between intervention and comparison patients with regard to clinical or sociodemographic characteristics.78 However, the Dutch trial found more substantial baseline differences,87 including the proportion of patients involuntarily detained, the proportion of those with a psychotic or personality disorder, and the total number of seclusion hours; all comparisons showed an increased preponderance in the experimental units.87

These trials, both government funded, were conducted as CRTs. However, neither trial analyzed its data in a way that correctly made use of this study design.

Both trials found lower aggression incidents87 and rates78 when compared with the usual-care conditions. In the Abderhalden trial, both the risk assessment and usual-care conditions reported a reduction in the rate of severe aggression, but the reduction in the experimental arm (RR, 0.59; 95% CI, 0.41 to 0.83; p<0.001) was significantly larger than in the usual-care condition (RR, 0.85; 95% CI, 0.64 to 1.13).78 The intervention arm reported fewer attacks (p<0.001 a decline of 41% vs. 7% in the experimental and control conditions, respectively) and use of coercive measures (p<0.001, decrease of 27% vs. an increase of 10% in the experimental and control conditions, respectively) when compared with usual care.78 Finally, for evaluating any aggressive incidents (i.e., not limited to severe aggression), the van der Sande trial reported a relative risk reduction (RRR) of -68 percent (p<0.001).87 Specifically, the number of incidents per week decreased from 4.9 per week to 1.7 per week in the risk assessment arm, whereas the number of incidents per week in the usual-care condition increased from 3.5 per week during the baseline to 3.9 per week during the intervention period. The risk assessment protocol led to similar reductions in the relative risk of time spent in seclusion (RRR, -45%; p<0.05) and the number of patients engaging in aggression (RRR, -50%; p<0.10) when compared with the control condition; however, the later effect was not statistically significant.87

##### Multimodal Interventions Versus Usual Care

###### Controlled Studies

We found no eligible controlled studies of multimodal interventions.

###### Pre/Post Studies

We found 11 pre/post studies on multimodal interventions that reported on preventing aggressive behavior, including seclusion and restraint use.79,83,88-94,100,101 Please refer to Appendix F for detailed study characteristics and results; summaries appear below. Eight of these investigations demonstrated a reduction in seclusion and/or restraint use for either a component or all of the study population.79,83,89,91-94,100 These changes ranged in magnitude from 13.8 percent100 to 69 percent,89 and three89,91,93 of the eight studies reported statistically significant decreases.79,91,93 One of the eight studies reported an increase in restraint use post-intervention, but only on the unit for individuals with chemical abuse.94 Two additional pre/post studies looking at the same intervention, entitled City Nurse,90,101 reported lower use of forced medication, seclusion, and restraint, but only one study had significant results.101 The remaining study did not report on seclusion or restraint but did report a reduction in aggressive behavior.88

The preponderance of the data from pre/post studies does suggest the ability of multimodal interventions to reduce seclusion and restraint when that is the intention of the intervention. We cannot determine whether any specific component was more effective than another, because of the limitations in the design of these studies. We note, however, that 10 studies79,88-94,100,101 did include development of the workforce as one of the intervention components. Brief summaries of the studies are presented below beginning with studies reporting on seclusion and restraint rates and ending with studies reporting solely on aggressive behavior.

Currier et al. compared restraint use before and after implementation of the guideline for the “1 hour rule” issued in 1999 by the U.S. Health Care Financing Administration. This rule required face-to-face clinician assessment of patients within 1 hour of initiation of seclusion or restraint. Although the study took place on four psychiatric units at a U.S. academic medical center, only the data from the three adult units were eligible for this review.94 The number of calculated episodes of restraint and mean duration of episodes decreased by 85 percent and 72.1 percent, respectively, during the 3 months post-intervention on the general adult unit, and by 81 percent and 23 percent, respectively, on the neurogeriatric unit. Restraint use increased by 47 percent, while the mean duration of episodes decreased by 24.5 percent, on the chemical abusing unit. No measures of statistical significance were reported.

D'Orio et al. compared a multimodal intervention with previous usual care over 18 months in the psychiatric emergency service of a U.S. urban hospital.93 The investigators implemented a behavioral code team, staff training that emphasized verbal de-escalation, and use of rating scales to assist in patient risk assessment. They observed a statistically significant 41.5 percent reduction in the monthly number of episodes of seclusion and restraint, when comparing the 9 months before and the 9 months after the intervention.

Forster et al. examined a multimodal quality improvement intervention (including hospital seclusion and restraint policy review, staff training, and regular discussion of seclusion and restraint use) in an acute care county psychiatric hospital in California.100 The total annual rate of restraint decreased by 13.8 percent, and mean duration of seclusion or seclusion-and-restraint episodes also decreased by 54.7 percent, when comparing the 12 months before and the 12 months after the intervention.

Hellerstein et al. compared a multimodal intervention with usual care over 87 months in a U.S. urban psychiatric hospital.79 The intervention had three components: (1) decreasing allowed time in restraint or seclusion before order renewal, (2) risk identification and early intervention training for staff, and (3) use of a coping questionnaire to assess patient preferences for dealing with agitation. Only data from one of the study wards were eligible for this review; showing a reduction in the mean numbers of patients per month either secluded (2.29 to 0.56) or restrained (0.19 to 0.10); results also included decreases in the mean hours per month of seclusion (28.95 to 1.45) and restraint (1.48 to 0.44). Measures of statistical significance were not reported.

Jonikas et al. compared the implementation of a program to reduce use of physical restraints with previous usual care in three inpatient psychiatric units (the two adult units were eligible for this review) of a U.S. university hospital over a period of 30 months.92 The intervention program had two components: collaboratively obtained (staff and patient) individualized crisis management plans and nonviolent crisis intervention staff training. Quarterly rates of restraint decreased on both adult units after the intervention. An analysis of variance demonstrated a significant effect of training; however, because the study was not controlled, the authors could not determine a definitive correlation.

Khadivi et al. compared a multimodal intervention with usual care in a large U.S. inner city community hospital.91 The intervention, which was compatible with the mandates of Joint Commission on Accreditation of Healthcare Organizations, included staff education, addition of the history of inpatient violence to admission forms, continuous nursing monitoring to minimize the duration of episodes of seclusion and restraint, post-episode debriefing of the staff and the patient, and a review of each episode by the senior nurse and a physician. Calculated seclusion and restraint use decreased by 52 percent after the intervention; the authors noted this was statistically significant.

Melson et al. compared an alcohol withdrawal care management guideline with previous care in a large U.S. acute care hospital over 228 weeks.83 The intervention included adding an alcohol withdrawal risk tool to the standard nursing assessment for all patients and then using another rating scale to categorize alcohol withdrawal based on symptom severity. The calculated percentage of patients with delirium tremens requiring restraint decreased by 26 percent, although changes were not statistically significant.

Pollard et al. compared the implementation of Joint Commission on Accreditation of Healthcare Organizations 2000 standards for use of seclusion or restraint for behavioral health reasons with previous usual care over 46 months on the mental health units of a VA hospital.89 The multimodal intervention broadly included changes to facility policies and procedures, discussions between leadership and staff about the alternatives to using seclusion and restraint, and leadership review of the use of behavioral restraints and documentation. The most important finding was that the mean hours of seclusion and restraint per patient decreased significantly even after adjusting for patient acuity. Finally, the investigators were able to demonstrate that the number of critical incidents in a 24-hour period did not increase despite significant reductions in the use of seclusion and restraint.

The City nurse multimodal intervention conducted in psychiatric wards in East End London was reported in two separate studies.90,101 The intervention comprised two nurses working with unit staff 3 days a week, for 1 year, to move the units toward low-conflict, low-containment, high-therapy nursing. The investigators evaluated outcomes before and after the intervention. Measures included the Patient-staff Conflict Checklist Shift Report, which consists of 21 conflict behavior items and nine containment items recorded after each shift. In the first study,90 no statistically significant reductions were seen for forced i.m. meds, seclusion, or restraint when comparing pre- and post-intervention periods; however, both verbal aggression and aggression against self and others did decrease significantly. In the later study,101 forced medication, seclusion, and restraint significantly decreased pre and post intervention, as well as verbal aggression and aggression against others and objects.

The eleventh study did not report rates of seclusion or restraint but did address aggressive behavior.88 Emmerson et al. compared a “4T Aggression Management Strategy” (team work, training, treatment, and tools) with previous usual care over 43 months in an Australian mental health hospital. Implementation of the strategy produced a 40 percent overall reduction and a 25.4 percent monthly reduction in aggressive incidents between patients and staff; both outcomes were statistically significant.

##### Environmental or Group Psychotherapeutic Interventions Versus Usual Care

###### Controlled Studies

We identified no eligible controlled studies.

###### Pre/Post Studies

Three pre/post investigations examined environmental or group psychotherapeutic efforts to de-escalate aggressive behavior. One naturalistic study compared a closed-door, locked psychiatric ICU with an open-door psychiatric ICU.80,81 The study assessed risk and incidents of violence using the Brøset Violence Checklist. Patients presented with similar clinical profiles at baseline, and mean length of stay did not differ across the units.

During the first 3 days of the admission, the open-door psychiatric ICU reported more violent incidents, by a magnitude of almost 6, than the closed-door unit (unadjusted RR, 5.72; 95% CI, 1.69 to 19.33; p=0.001). Also, patients on the closed-door unit displayed a statistically greater reduction in risk of aggressive behavior (using the Brøset measure) than the open-door unit (p=0.02). When examining the full length of stay, the closed-door unit continued to have significantly fewer incidents of violence than the open-door unit (p<0.001). The number of patients exhibiting violent behavior in the first 3 days (p=0.08) and use of mechanical restraints over the full stay (p=NR) did not differ between units. No mean changes occurred in psychiatric symptom severity and functioning (as measured with the Positive and Negative Syndrome Scale total score and Global Assessment of Functioning Scale's function or symptom scores).

Another naturalistic study tested a practice change initiative that emphasized removing verbally and physically threatening U.S. veteran inpatients in a psychiatric ICU from stimuli before implementing seclusion alone, or seclusion and restraint interventions.95 During the 15-month post-intervention period, a significantly lower percentage of patients received seclusion alone, or seclusion and restraint interventions than was present during the 9-month pre-intervention period (34% vs. 54%, respectively, p <0.05). The benchmark goal of requiring no further intervention after “removal from stimuli” in 90 percent or more of cases was achieved in 67 percent of post-intervention months. However, in the final 6 months of the observation period, more seclusion or restraint and seclusion interventions occurred than removals from stimuli interventions.

Another naturalistic study compared a manualized cognitive-behavioral group therapy intervention with usual care for adult psychiatric inpatients.104,105 The study took place in Italy in the psychiatric inpatient unit of a general hospital. The pre-intervention period lasted 1 year; the followup period lasted 3 years. During the post-intervention period, physical restraints were used one time each year. Physical restraints were used five times in the 1-year pre-intervention period, but no statistical tests were conducted on these differences). Additionally, ward atmosphere, which was used as an indirect measure of aggressive and violent behaviors (measured with the Ward Atmosphere Scale), significantly improved (i.e., less disturbing behavior or fewer coercive interventions required) in the post-intervention period compared to the pre-intervention period. Finally, compared with the pre-intervention period, the post-intervention period had significant decreases in the percentage of patients readmitted to the hospital and the percentage of patients readmitted under compulsory orders (both p<0.02) and significant improvements in patient satisfaction with care received, helpfulness and availability of professionals, information received, and ward activities (p<0.001).

##### Medication Protocols Versus Other Medication Protocols or Alternative Strategies

###### Controlled Studies

We identified no eligible controlled studies.

###### Pre/Post Studies

We identified no relevant pre/post studies.

#### Key Question 1b De-escalating Aggressive Behavior

We identified six studies, all involving medication protocols (four RCTs and two NRCTs) addressing this subquestion (Table 9). We identified no relevant studies involving staff training, risk assessment, multimodal, or environmental or group psychotherapeutic interventions that addressed the comparative benefits of strategies for de-escalating aggressive behavior.

Table 9 Characteristics, outcomes, and risk of bias ratings for controlled trials of medication protocols to de-escalate aggressive behavior (Key Question 1b)

Intervention First Author, Year Study Design Setting, Country | N Duration (Months) | Intervention Comparator | Aggressive Behavior | Restraint Use Seclusion Use | Seclusion and Restraints | Risk of Bias Rating
Dorevitch et al., 1999^82^ RCT (parallel) Acute inpatient psychiatric facility or facilities Israel | 28 NR | G1: Single dose, i.m. 5 mg haloperidol G2: Single dose, i.m. 1 mg flunitrazepam | Rate of reduction in total OAS score at 90 mins G1: 92% G2: 80% p=0.34 | NR NR | NR | Medium
Isbister et al., 2010^77^ RCT (parallel) Emergency department Australia | 91 44 weeks | G1: Single dose, i.m. 10 mg droperidol G2: Single dose, i.m. 10 mg midazolam G3: Single dose, i.m. 5 mg droperidol plus 5 mg midazolam | Violent and acute behavioral disturbance, median minute duration (IQR) G1: 20 (11 to 37) G2: 24 (13 to 35) G3: 25 (15 to 38) p=0.66 | NR NR | NR | Medium
Bieniek et al., 1998^98^ RCT (parallel) Psychiatric emergency service United States | 20 3 hours | G1: Haloperidol (5 mg i.m.) + lorazepam (2 mg i.m.) (n=9) G2: Lorazepam (2 mg i.m.) (n=11) | Clinically significant improvement^a^ in OAS score of aggressive or agitated behavior at 60 mins, N (%) G1: 9 (100) G2: 6 (55) p=0.03 Time to OAS improvement: Group-specific slopes of Kaplan-Meier survival curves NR, but haloperidol + lorazepam combination had a superior time to improvement p=0.028 Change in OAS scores (%) at 30 mins G1: 71 G2: 49 Change in OAS scores (%) at 60 mins G1: 85 G2: 71 Group-by-time interaction p=0.71 | NR NR | NR | Low
Richards et al., 1998^102^ RCT (parallel) Large urban university emergency department United States | 202 60 mins | G1: Droperidol, 2.5 mg i.v. (when weight <50 kg) or 5 mg i.v. (when weight >50 kg)^b^ G2: Lorazepam, 2 mg i.v. (when weight <50 kg) or 4 mg i.v. (when weight >50 kg)^b^ | Sedation scores (measure of combative, violent, and out of control behavior), mean (SD)^c^ Baseline G1: 5.6 (0.6) G2: 5.3 (0.7) p=0.08 5 mins post-baseline G1: 4.8 (0.7) G2: 4.7 (0.6) p=0.3 10 mins post-baseline G1: 2.8 (0.9) G2: 4.1 (0.8) p<0.001 15 mins post-baseline G1: 2.0 (0.6) G2: 3.5 (0.8) p<0.001 30 mins post-baseline G1: 1.6 (0.5) G2: 2.9 (0.7) p<0.001 60 mins post-baseline G1: 1.5 (0.5) G2: 2.5 (0.7) p<0.001 Response time to medication in combative, violent, and out of control behavior was statistically significantly faster following droperidol than lorazepam (p=NR). No statistical difference in sedation profile between patients with different ethanol intoxications in either group (p=NR). | NR NR | NR | High
Wilhelm et al., 2008^106^ NRCT Psychiatric or forensic hospitals (n=102) Germany | 558 6 days^d^ | G1: Olanzapine^e^ G2: Non-olanzapine medication^e^ G3: Risperidone^e^ G4: Non-risperidone medication^e^ G5: Haloperidol^e^ G6: Non-haloperidol medication^e^ | CGI-A: % of patients with scores ≥3^f^ % change from baseline to day 6 followup G1: -61.2 vs. G2: -67.0 G3: -67.2 vs. G4: -62.4 G5: -64.6 vs. G6: -62.4 p=NS Percentage change from baseline to last observation G1: -60.7 vs. G2: -66.0 G3: -66.4 vs. G4: -61.7 G5: -63.6 vs. G6: -61.9 p=NS CGI-SS: percentage of patients with scores ≥3^f^ Percentage change from baseline to day 6 follow-up G1: -18.1 vs. G2: -22.4 G3: -20.7 vs. G4: -19.2 G5: -21.2 vs. G6: -18.9 p=NS Percentage change from baseline to last observation G1: -18.2 vs. G2: -22.0 G3: -20.8 vs. G4: -19.1 G5: -21.4 vs. G6: -18.8 p=NS | NR NR | NR | High
Villari et al., 2008^99^ NRCT Psychiatric emergency service (in-hospital) Italy | 101 72 hours | G1: Risperidone (2–6 mg/day PO) G2: Olanzapine (10–20 mg/day PO) G3: Quetiapine (300–800 mg/day PO) G4: Haloperidol (5–15 mg/day PO) | Changes in mean MOAS total scores from baseline to 72 hours Drug-by-drug comparisons G1: -7.3 G2: -6.3 G3: -7.9 G4: -9.4 Group-by-time interaction p=0.478 SGAs (G1 through G3 combined) vs. G4 SGAs: -7.1 G4: -9.4 Group-by-time interaction p=0.166 Changes in mean MOAS verbal aggression scores from baseline to 72 hours Drug-by-drug comparisons G1: -1.3 G2: -1.2 G3: -1.4 G4: -1.6 Group-by-time interaction p=0.644 SGAs (G1 through G3 combined) vs. G4 SGAs: -1.3 G4: -1.6 Group-by-time interaction p=0.222 Changes in mean MOAS physical aggression against objects scores from baseline to 72 hours Drug-by-drug comparisons G1: -1.8 G2: -2.2 G3: -1.4 G4: -2.4 Group-by-time interaction p=0.512 SGAs (G1 through G3 combined) vs. G4 SGAs: -1.8 G4: -2.4 Group-by-time interaction p=0.277 Changes in mean MOAS physical aggression against self-scores from baseline to 72 hours Drug-by-drug comparisons G1: -1.3 G2: -1.2 G3: -1.2 G4: -1.8 Group-by-time interaction p=0.894 SGAs (G1 through G3 combined) vs. G4 SGAs: -1.2 G4: -1.8 Group-by-time interaction p=0.433 Changes in mean MOAS physical aggression against others scores from baseline to 72 hours Drug-by-drug comparisons G1: -3.0 G2: -1.7 G3: -3.9 G4: -3.6 Group-by-time interaction p=0.276 SGAs (G1 through G3 combined) vs. G4 SGAs: -2.8 G4: -3.6 Group-by-time interaction p=0.415 | NR NR | NR | Medium

a A decrease of four or more points on the OAS within 60 minutes of baseline was considered “clinically significant improvement.”98

b Dosages of study drugs were selected based on patients' weight, which the treating clinician estimated visually.102

c Sedation scores were measured on a 6-point scale, ranging from 6 (combative, violent, out of control) to 1 (deep sleep).102

d The study followed enrolled patients over the first 6 days of their hospitalizations. Baseline was day 1, and the following 5 days (days 2–6) represented the followup period.106

e Patients' antipsychotic treatment was categorized as including any olanzapine or not (OLZ or non-OLZ), including any risperidone or not (RIS or non-RIS), and including any haloperidol or not (HAL or non-HAL). The OLZ, RIS, and HAL cohorts thus overlap, because each cohort included all patients who received the respective drug in any amount and at any time throughout the 5-day study period.106

f CGI-A scores ≥3 correspond to at least a moderate level of aggression, and CGI-SS scores ≥3 correspond to patients who are at least moderately suicidal.106

CGI-A = Clinical Global Impression Severity of Illness – Aggression; CGI-SS = Clinical Global Impression Severity of Illness – Suicidality; G = group; IQR = interquartile range; i.m. = intramuscular; i.v. = intravenous; kg = kilogram; mg = milligram; mins = minutes; MOAS = Modified Overt Aggression Scale; N = number; NR = not reported; NRCT = nonrandomized controlled trial; NS = not sufficient; OAS = Overt Aggression Scale; PO = by mouth, oral medication; RCT = randomized controlled trial; SD = standard deviation; SGA = second generation antipsychotic; vs. = versus.

##### Medication Protocols Versus Other Medication Protocols or Alternative Strategies

###### Controlled Studies

We found four RCTs and two NRCTs meeting the eligibility criteria (Table 9 above). Two of the RCTs involved haloperidol. In one RCT involving 20 emergency service patients, 5 mg i.m. haloperidol plus 2 mg i.m. lorazepam resulted in a shorter time to achieve clinically significant reductions in aggressive behavior (4+ point reduction in OAS score) and clinician-rated agitation and hostility; the combined medication regimen did not produce a significantly greater reduction in aggressive behavior or agitation and hostility overall than 2 mg i.m. lorazepam alone.98 In a second RCT, single-dose 5 mg i.m. haloperidol did not yield a greater reduction in aggressive behavior than 1 mg i.m. flunitrazepam in 28 patients in an acute inpatient psychiatric facility.82

The other two RCTs investigated the comparative efficacy of droperidol with another medication or combination of medications. One double-blind RCT compared single-dose 10 mg i.m. midazolam (considered the standard treatment) with 10 mg i.m. droperidol and with 5 mg i.m. midazolam plus 5 mg i.m. droperidol in 79 patients who presented a total of 91 times to the emergency department.77 After study drug administration, the treatment groups did not differ significantly in median duration of aggressive behavior (p=0.66); however, over the ensuing 6 hours, more midazolam-treated patients required additional sedative medication than droperidol-treated patients (hazard ratio [95% CI], 2.31 [1.01 to 4.71]). In contrast, patients treated with midazolam plus droperidol were no more likely to require additional sedative medication than droperidol-treated patients (hazard ratio [95% CI], 1.18 [0.46 to 2.5]). This trial also collected data on the number of calls to security staff for additional assistance and the percentage of patients sedated after 20 minutes of receiving sedative medication, but it did not statistically compare between-group differences for either outcome. Another RCT compared i.v. lorazepam with i.v. droperidol in 202 acutely agitated adult emergency department patients.102 Physician-estimated body weight (< or > 50 kg) determined dose of lorazepam (2 mg or 4 mg) and droperidol (2.5 mg or 5 mg), and sedation (i.e., used to measure reduction in combative, violent, and out-of-control behavior) was rated on a 6-point scale (1 = deep sleep, 6 = combative, violent, out of control). Droperidol resulted in faster time to sedation than lorazepam (2.8 ± 0.9 vs. 4.1 ± 0.8 at minute 10, p<0.001) and greater sedation overall than lorazepam (1.5 ± 0.5 vs. 2.5 ± 0.7 at minute 60, p<0.001). In addition, patients who were discharged home spent significantly (p<0.001) fewer hours in the emergency department if treated with droperidol (5.9 ± 1.3) than those treated with lorazepam (8.6 ± 1.4).

The two NRCTs both involved haloperidol. In one NRCT, involving 101 psychiatric inpatients requiring emergency medication to control agitation, oral daily doses of 5 mg to 15 mg haloperidol did not result in greater reductions in aggressive behavior over 72 hours than either one of three second-generation antipsychotics (6 mg risperidone, 10 mg–20 mg olanzapine, or 300 mg–800 mg quetiapine).99 However, risperidone did result in greater reduction in anergia. The comparison of haloperidol with the second-generation antipsychotics collectively also did not yield any significant differences in the reduction in aggressive behavior. The other NRCT of 558 acutely agitated psychiatric inpatients compared three cohorts of patients: those who received any olanzapine vs. any risperidone vs. any haloperidol as part of their treatment over a 5-day period.106 Oral dosing was most common, but some patients received i.v. and i.m. formulations. The three treatment cohorts exhibited similar reductions in aggressive behavior and suicidality.

#### Key Question 1c Reducing Seclusion and Restraint Use

We identified two controlled trials involving medication protocols (one RCT, one retrospective cohort study). Both investigations targeted actively aggressive individuals in an attempt to reduce seclusion and restraint use (Table 10). We also identified one pre/post medication protocol study. We found no eligible studies that compared staff training, risk assessment, multimodal interventions, or environmental or group psychotherapeutic interventions with other strategies to reduce seclusion or restraints for those with active aggression.

Table 10 Characteristics, outcomes, and risk of bias ratings for controlled trials of medication protocols to de-escalate aggressive behavior and reduce use of seclusion or restraints (Key Question 1c)

Intervention First Author, Year Study Design Setting, Country | N Duration (Months) | Intervention Comparator | Aggressive Behavior | Restraint Use | Seclusion Use | Seclusion and Restraints | Risk of Bias Rating
Georgieva et al., 2013^86^ RCT (parallel) Psychiatric hospital (no other details reported) Netherlands | 659 34 months | G1: Involuntary medication as first choice (single dose oral, 10 mg haloperidol plus 100 mg promethazine or 2.5–5 mg lorazepam, or single-dose i.m. 5 mg haloperidol plus 50 mg promethazine or 2.5–5 mg lorazepam) G2: Seclusion as first choice | NR | Mechanical restraint incidents, n per 1,000 admission days G1: 1.3 G2: 0.9 (RR, 1.44; 95% CI, 0.38 to 5.36) p=NS Involuntary medication incidents (overall) G1: 47 G2: 21 p=NR Involuntary medication incidents (per 1000 admission days) G1: 4.6 G2: 11.8 (RR, 2.58; 95% CI, 1.54 to 4.31) p<0.001 | Seclusion incidents (per 1,000 admission days): G1: 15 G2: 7.8 (RR, 0.51; 95% CI, 0.34 to 0.79) p<0.001 Seclusion hours (overall) G1: 988 G2: 2,098 p=NR Seclusion hours (per 1,000 admission days) G1: 10 G2: 19.1 (RR, 0.54; 95% CI, 0.5 to 0.58) p<0.001 Duration of seclusion incidents in hours, mean (SD) G1: 32 (40) G2: 30 (44) p=NR | Coercive^a^ incidents (individual or combined), n per 1,000 admission days G1: 14.6 G2: 15.3 (RR, 0.95; 95% CI, 0.67 to 1.35) p=NS | High
Michaud et al., 2014^85^ Retrospective cohort Intensive care unit United States | 200 35 months | G1: Single dose, delirium txt in 24 hours G2: No delirium txt in 24 hours | NR | Median days in restraints (range) G1: 3 (1 to 12) G2: 6 (1 to 21) p<0.001 | NR | NR | High

a “Coercion” refers to a sequence of coercive episodes (seclusion, mechanical restraint, or involuntary medication) for less than 24 hours.

CI = confidence interval; G = group; i.m. = intramuscular; mg = milligram; n = number; NR = not reported; NS = not significant; RCT = randomized controlled trial; RR = relative risk; SD = standard deviation; txt = treatment.

##### Medication Protocols Versus Other Medication Protocols or Alternative Strategies

###### Controlled Studies

One RCT compared a first-choice treatment of involuntary medication with a first-choice treatment of seclusion (considered “treatment as usual” in the Netherlands) in 520 patients (who accounted for 659 admissions covering 8,544 hospitalization days).86 Involuntary medication comprised 10 mg haloperidol plus either 100 mg promethazine or 2.5 mg lorazepam, given orally; if patients refused, they received i.m. 5 mg haloperidol plus either 50 mg promethazine or 2.5 to 5 mg lorazepam. During seclusion, further administration of “as needed” medications were considered “involuntary medication.” Per 1,000 admission days, for those assigned to first-choice involuntary medication, both the use of seclusion (RR, 0.51; 95% CI, 0.34 to 0.79; p<0.001) and the duration of seclusion (RR, 0.54; 95% CI, 0.50 to 0.58; p<0.001) were significantly lower. Because the use of involuntary medication was also allowable in the seclusion group and because the choice and dosing of medications used potentially could have been equivalent to those in the first-choice involuntary medication group, the authors compared the use of involuntary medications in the two groups. Use of involuntary medication was significantly higher (RR, 2.58; 95% CI, 1.54 to 4.31; p<0.001) in patients assigned to first-choice involuntary medication than in those in first-choice seclusion. In contrast, neither use of mechanical restraint nor coercive incidents (defined as a sequence of coercive episodes including seclusion, mechanical restraint, or involuntary medication over a 24-hour period) differed significantly between groups.

One retrospective cohort study compared pharmacological delirium treatment with no treatment in 200 intubated patients with delirium.85 The delirium treatment group comprised 98 patients that received at least one dose of quetiapine, olanzapine, risperidone, ziprasidone, haloperidol, or dexmedetomidine within 24 hours of their first positive delirium screen; the no treatment group comprised 102 patients who received delirium treatment more than 24 hours after screening (n=18) or received no pharmacological intervention during their delirium course (n=84). The treatment group spent significantly fewer days in restraint compared with the no treatment group (median of 3 vs. 6 days, p<0.001).

###### Pre/Post Studies

One retrospective pre/post study reported changes in the use of seclusion and restraint following implementation of a hospital-wide ban on p.r.n. (“when necessary”) orders for psychotropic medications.76 During the 3-month baseline period when p.r.n. medications were permitted, 8 incidents of restraint and 48 incidents of seclusion occurred during 223 admissions. During the subsequent 3-month period when p.r.n medications were not permitted, fewer incidents of restraint (4) and seclusion (41) occurred among 224 admissions, although the mean duration of seclusion was higher (13.1 vs. 19.2 hours). None of these observed differences was statistically significant.

## Comparative Harms of Strategies (Key Question 2)

We describe in separate sections the studies that reported harms data relevant to KQ 2a (preventing aggressive behavior); KQ 2b (de-escalating aggressive behavior); and KQ 2c (reducing restraints or seclusion). In Appendix D, we present detailed SOE tables for each primary outcome, organized by intervention type. Summary tables presenting characteristics and outcomes for all pre/post studies are available in Appendix F.

### Key Points

#### Key Question 2a Harms of Strategies To Prevent Aggressive Behavior

##### Staff Training Interventions Versus Usual Care

- One CRT (Table 11) addressed staff training. A unit on which staff received interpersonal communication training had fewer patient rights complaints, staff resignations and transfers, and sick leave compared to a control unit. Further, the intervention unit experienced a greater decrease in these outcomes during the study period, compared to the control unit103 (one CRT, insufficient SOE).

Table 11 Summary of findings with strength of evidence: Comparative harms of staff training strategies for preventing aggressive behavior (KQ 2a)

Intervention and Comparison | Primary Outcome of Interest | Outcome N of Patients Analyzed | Strength of Evidence | Supporting Judgment | Findings and Direction of Effect
Staff training vs. usual care | Staff distress | Change in staff resignations and transfers NR | Insufficient | High risk of bias, consistency unknown—single study, indirect, imprecise | Fewer staff resignations and transfers in unit that received the staff training than in control unit (4 vs. 9), no statistical testing reported103
Staff training vs. usual care | Staff distress | Change in staff sick leave NR | Insufficient | High risk of bias, consistency unknown—single study, indirect, imprecise | Greater percentage decrease in number of sick leave hours in unit that received the staff training than in control unit (-28.2% vs. +7.7%), no statistical testing reported103
Staff training vs. usual care | Patient distress | Change in patients' rights complaints NR | Insufficient | High risk of bias, consistency unknown—single study, indirect, imprecise | Fewer patients' rights complaints occurred in unit that received the staff training than in control unit (from 6 to 2 vs. from 1 to 4), no statistical testing reported103

N = number; NR = not reported; vs. = versus.

##### Risk Assessment Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Multimodal Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Environmental or Group Psychotherapeutic Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Medication Protocols Versus Other Medication Protocols or Alternative Strategies

- We identified no eligible studies (insufficient SOE).

#### Key Question 2b Harms of Strategies to De-escalate Aggressive Behavior

##### Staff Training Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Risk Assessment Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Multimodal Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Environmental or Group Psychotherapeutic Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Medication Protocols Versus Other Medication Protocols or Alternative Strategies

- Four RCTs provided harms data for medication protocols for de-escalating aggressive behavior; all reported small numbers of events and performed no statistical testing (all insufficient SOE). These studies (Table 12) generally reported their harms findings as indicating no differences, but they were underpowered to test noninferiority.
  ○ One RCT examined three possible harms: incidence of staff injury; drug-related adverse effects; and incidence of abnormal QT (QRS complex to T wave interval) interval after use of midazolam, droperidol, or their combination for patients with active aggression77 (one RCT, insufficient SOE).
  ○ Another RCT reported on acute extrapyramidal events and incidence of marked sedation in a comparison between haloperidol and flunitrazepam82 (one RCT, insufficient SOE).
  ○ A third RCT reported the incidence of side effects of i.m. 2 mg lorazepam alone or in combination with i.m. 5 mg haloperidol for 20 adults treated in a psychiatric emergency service setting98 (one RCT, insufficient SOE).
  ○ Finally, one RCT reported the incidence of differences in changes in vital signs in 202 acutely agitated emergency department patients treated with intravenous droperidol or lorazepam102 (one RCT, insufficient SOE).
- One NRCT (Table 12) reported the incidence of extrapyramidal events in 101 adult inpatients with psychosis receiving either risperidone, olanzapine, quetiapine, or haloperidol99 (one NRCT, insufficient SOE).
- Another NRCT (Table 12) reported the incidence of treatment-emergent side effects, including extrapyramidal events, for patients receiving olanzapine, risperidone, or haloperidol 106 (one NRCT, insufficient SOE).

Table 12 Summary of findings with strength of evidence: Comparative harms of medication protocols for addressing aggressive behavior (Key Question 2b)

Intervention and Comparison | Primary Outcome of Interest | Outcome of Interest N of Patients Analyzed | Strength of Evidence | Supporting Judgment | Findings and Direction of Effect
Medication protocols vs. other medication protocols | Staff harm | Staff injury 91 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Very small numbers of events with no statistical testing for detecting differences in droperidol vs. midazolam vs. a combination of droperidol plus midazolam (3 vs. 1 vs. 2, p=NR).77
Medication protocols vs. other medication protocols | Adverse effects from medication | Acute extrapyramidal events 28 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | No acute extrapyramidal events^a^ with either in haloperidol vs. flunitrazepam at 90 minutes.82
Medication protocols vs. other medication protocols | Adverse effects from medication | Marked sedation 28 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Very few events at 90 minutes with either haloperidol vs. flunitrazepam, no statistical testing reported (3 vs. 3, p=NR).82
Medication protocols vs. other medication protocols | Adverse effects from medication | Drug-related adverse events 91 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Very small numbers of events with no statistical testing for detecting differences in droperidol vs. midazolam vs. a combination of droperidol plus midazolam (2 vs. 8 vs. 2, p=NR).77
Medication protocols vs. other medication protocols | Adverse effects from medication | Abnormal QT interval 91 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Very small numbers of abnormal QT intervals with no statistical testing for detecting differences in droperidol vs. midazolam vs. a combination of droperidol plus midazolam (2 vs. 2 vs. 4, p=NR).77
Medication protocols vs. other medication protocols | Adverse effects from medication | Medication side effects 20 | Insufficient | Low risk of bias, consistency unknown—single study, direct, imprecise | No medication side effects reported with either haloperidol plus lorazepam vs. lorazepam.98
Medication protocols vs. other medication protocols | Adverse effects from medication | Reduction in vital signs 202 | Insufficient | High risk of bias, consistency unknown—single study, direct, precise | No significant difference for any reduced vital signs between droperidol vs. lorazepam.102
Medication protocols vs. other medication protocols | Adverse effects from medication | Overall treatment-emergent adverse events 558 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | Few overall treatment-emergent adverse events with olanzapine vs. risperidone vs. haloperidol vs. other comparator groups (p=NR).106
Medication protocols vs. other medication protocols | Adverse effects from medication | Adverse events considered related to primary antipsychotic medication 558 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | Very few events considered related to primary antipsychotic medication with olanzapine vs. risperidone vs. haloperidol (p=NR).106
Medication protocols vs. other medication protocols | Adverse effects from medication | Extrapyramidal symptoms 558 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | No significant difference (very few events) with olanzapine vs. risperidone vs. haloperidol vs. other comparator groups.106
Medication protocols vs. other medication protocols | Adverse effects from medication | Discontinuation due to clinically significant adverse events 558 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | No significant difference in discontinuation due to clinically significant adverse events with olanzapine vs. risperidone vs. haloperidol vs other comparator groups.106
Medication protocols vs. other medication protocols | Adverse effects from medication | Extrapyramidal events 101 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Significant difference but very few extrapyramidal events in risperidone vs. olanzapine vs. quetiapine vs. haloperidol (p=0.012).99

a Also no excitation or disinhibition in patients receiving flunitrazepam, not reported for the haloperidol.82

N = number; NR = not reported; NS = not significant; QT = QRS complex to T wave interval; vs. = versus.

#### Key Question 2c Harms of Strategies To Reduce Seclusion and Restraint Use

##### Staff Training Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Risk Assessment Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Multimodal Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Environmental or Group Psychotherapeutic Interventions Versus Usual Care

- We identified no eligible studies (insufficient SOE).

##### Medication Protocols Versus Other Medication Protocols or Alternative Strategies

- We identified no eligible studies (insufficient SOE).

### Detailed Synthesis

We identified 15 studies in 16 articles for this KQ with harms data: seven controlled trials and eight pre/post studies. Below, we detail the results by subquestion, then by intervention, and then by study design. In Appendix D, we present detailed SOE tables for each KQ 2 primary outcome, organized by intervention type. Appendix E contains detailed study characteristics tables across all intervention types. Appendix F provides a summary of findings for the pre/post studies.

#### Key Question 2a Prevention of Aggressive Behavior

This section describes the eight included studies evaluating the effectiveness of interventions designed to prevent aggressive behavior in those without active aggression. One study was a controlled trial using a CRT design to assess staff training interventions;103 seven (reported in eight articles) used a pre/post design.80,81,88,90,91,94,100,101 Of those seven pre/post studies, six evaluated the implementation of a multimodal intervention,88,90,91,94,100,101 and one evaluated an environmental or group psychotherapeutic intervention.80,81

We did not identify any studies that addressed the comparative harms of either risk assessment interventions or medication protocols with other early intervention techniques or usual care for preventing aggressive behavior or use of seclusion and restraints.

##### Staff Training Interventions Versus Usual Care

###### Controlled Studies

The staff training CRT (see Table 8 for de-escalating aggressive behavior), which focused on empathy training, also investigated patient complaints, staff resignations and transfers, and sick leave.103 On the intervention unit, patients' rights complaints declined from 6 in the 1-year period before the intervention to 2 in the year following the intervention (66.7% decrease). On the control unit, patients' rights complaints increased from 1 to 4 (300.0% increase) during the same period. Staff resignation and transfers declined from 11 to 4 (63.6% decrease) on the intervention unit; these outcomes increased on the control unit from 8 to 9 (12.5% increase). Sick leave (in hours) declined from 1,470 hours to 1,056 (28.2% decrease) on the intervention unit and increased on the control unit from 1,404 to 1,512 (7.7% increase). The investigators did not report tests of statistical significance.

##### Multimodal Interventions Versus Usual Care

###### Controlled Studies

We identified no eligible controlled studies.

###### Pre/Post Studies

Six pre/post studies addressed harms related to preventing aggression in those without active aggression.88,90,91,94,100,101 We discussed these studies in detail for KQ 1a (with additional details in Appendix F); data relevant to KQ 2a are presented here with studies in alphabetical order. Both the initial and followup studies of the City Nurse intervention, by Bowers et al.,90,101 compared the rate of suicide attempts before and after intervention implementation. The overall rate of suicide attempts was very low in both studies (0.004 and 0.008 mean attempts per shift pre-intervention, respectively); neither study showed a statistically significant reduction after the intervention. Currier et al.94 reported that the rate of injuries to staff by patients did not increase after the intervention (designed to reduce seclusion and restraint), although the investigators did not present data by unit or report any specific numbers or measures of statistical significance. They also reported that the number of patient falls increased on the neurogeriatric unit post-intervention, but they simultaneously noted that these falls were without injuries. Emmerson et al.,88 for their 4T aggression Management Strategy, reported statistically significant overall and mean monthly reductions in staff injuries and a lack of a potentially anticipated harm from medication protocols to decrease aggression (no significant increase in sedation-related adverse effects). Forster et al.100 reported that the rate of staff injuries were reduced by 18.8 percent, when comparing the 12 months before and the 12 months after the multimodal quality improvement intervention. Finally, Khadivi et al.91 reported a statistically significant decrease in assaults on staff and assaults on patients after reducing seclusion and restraint; they also observed a nonsignificant decrease in self-destructive behavior. Although the pre/post design of these studies does not allow causal inference, this available information is consistent with evidence suggesting that multimodal interventions lower seclusion and restraint use and aggressive behavior without harms.

##### Environmental or Group Psychotherapeutic Interventions Versus Usual Care

###### Controlled Studies

We identified no eligible studies.

###### Pre/Post Studies

One pre/post study comparing a closed-door, locked psychiatric ICU with an open-door psychiatric ICU examined suicide as a potential harm to patients (see KQ 1 for a more detailed study description).80,81 A single serious suicide attempt took place in the open-door ICU. The investigators did not statistically compare the risk of suicidal behaviors between the two units and did not report any other harms.

##### Medication Protocols Versus Other Medication Protocols or Alternative Strategies

###### Controlled Studies

We identified no eligible studies.

###### Pre/Post Studies

We identified no relevant studies.

#### Key Question 2b De-escalating Aggressive Behavior

No studies of staff training, risk assessment, multimodal, or environmental or group psychotherapeutic interventions reported on the comparative harms of strategies for de-escalating aggressive behavior. All six eligible studies addressed the use of medication protocols (Table 13).

Table 13 Characteristics, main outcomes, and risk of bias ratings for harms from medication protocol studies to de-escalate aggressive behaviors (Key Question 2b)

Intervention First Author, Year Study Design Setting, Country | N Duration (Months) | Intervention Comparator | Staff Injury | Medication Side Effects | Risk of Bias Rating
Isbister et al., 2010^77^ RCT (parallel) Public psychiatric hospital Australia | 91 6 hours | G1: Droperidol: 10 mg i.m. G2: Midazolam: 10 mg i.m. G3: Droperidol (5 mg i.m.) plus Midazolam (5 mg i.m.) | Staff injury, n (%) [95% CI] G1: 3 (9%) [2 to 25%] G2: 1 (3%) [0 to 20%] G3: 2 (7%) [1 to 24%] p=NR | Drug-related adverse events, n (%) [95% CI] G1: 2 (6%) [1 to 22%] G2: 8 (28%) [13 to 47%] G3: 2 (7%) [1 to 24%] p=NR Abnormal QT interval, n (%) [95% CI] G1: 2 (6%) [1 to 23%] G2: 2 (7%) [1 to 24%] G3: 4 (14%) [5 to 33%] p=NR | Medium
Dorevitch et al., 1999^82^ RCT (parallel) Acute inpatient psychiatric facility or facilities Israel | 28 90 mins | During aggressive event: G1: Haloperidol (5 mg i.m.) G2: Flunitrazepam (1 mg i.m.) | NR | Acute extrapyramidal events^a^, n G1: 0 G2: 0 p=NR Incidence of marked sedation, n G1: 3 G2: 3 p=NR | Medium
Bieniek et al., 1998^98^ RCT (parallel) Psychiatric emergency service United States | 20 3 hours | G1: Haloperidol (5 mg i.m.) + lorazepam (2 mg i.m.) (n=9) G2: Lorazepam (2 mg i.m.) (n=11) | NR | Medication side effects, n G1: 0 G2: 0 | Low
Richards et al., 1998^102^ RCT (parallel) Large urban university emergency department United States | 202 60 mins | G1: Droperidol, 2.5 mg i.v. (when weight <50 kg) or 5 mg i.v. (when weight >50 kg)^b^ G2: Lorazepam, 2 mg i.v. (when weight <50 kg) or 4 mg i.v. (when weight >50 kg)^b^ | NR | Acute dystonic reaction G1: 1^c^ G2: 0 p=NR Patients in both groups experienced statistically significant reductions in vital signs within 60 mins of receiving drugs, including pulse, SBP, and respiratory rate (all p's <0.001), but not body temperature (p=0.2 after droperidol and 0.4 after lorazepam). However, no statistically significant between-group differences for any vital sign (all p's >0.05). Additionally, no adverse events with respect to vital signs in either group. No acute allergic reactions to either drug, and no patient required airway intervention. | High
Villari et al., 2008^99^ NRCT Psychiatric emergency service (in-hospital) Italy | 101 72 hours | G1: Risperidone (2–6 mg/day PO) G2: Olanzapine (10–20 mg/day PO) G3: Quetiapine (300–800 mg/day PO) G4: Haloperidol (5–15 mg/day PO) | NR | Abnormal gait, n (%) G1: 2 (7.4) G2: 2 (8.3) G3: 1 (4.6) G4: 2 (7.1) p=0.964 Dizziness, n (%) G1: 1 (3.7) G2: 3 (12.5) G3: 4 (18) G4: 1 (3.6) p=0.204 EPS, n (%) G1: 2 (7.4) G2: 0 (0) G3: 0 (0) G4: 6 (21.4) p=0.012 Headache, n (%) G1: 1 (3.7) G2: 2 (8.3) G3: 1 (4.6) G4: 2 (7.1) p=0.888 Hypotension, n (%) G1: 2 (7.4) G2: 4 (17) G3: 3 (14) G4: 4 (14) p=0.78 | Medium
Medication Protocol | | | | Somnolence, n (%) G1: 3 (11.1) G2: 5 (21) G3: 7 (32) G4: 5 (18) p=0.338
Wilhelm et al., 2008^106^ NRCT Psychiatric or forensic hospitals (n=102) Germany | 558 6 days^d^ | G1: Olanzapine G2: Non-olanzapine medication G3: Risperidone G4: Non-risperidone medication G5: Haloperidol G6: Non-haloperidol medication | NR | AEs considered related to primary antipsychotic medication, n (%) G1: 21 (5.4) vs. G2: 12 (7.1) G3: 8 (11.1) vs. G4: 25 (5.1) G5: 12 (9.1) vs. G6: 21 (4.9) p=NS Discontinuation due to clinically significant AEs, n (%) G1: 1 (0.3) vs. G2: 1 (0.6) G3: 1 (1.4) vs. G4: 1 (0.2) G5: 0 (0.0) vs. G6: 2 (0.5) p=NS Overall treatment-emergent AEs, n (%)^e^ G1: 24 (6.2) vs. G2: 13 (7.7) G3: 8 (11.1) vs. G4: 29 (6.0) G5: 13 (9.8) vs. G6: 24 (5.6) p=NS Serious AEs considered related to primary antipsychotic medication, n (%) G1: 1 (0.3) vs. G2: 1 (0.6) G3: 0 (0.0) vs. G4: 2 (0.4) G5: 2 (1.5) vs. G6: 0 (0.0) p=NS Overall serious AEs, n (%) G1: 2 (0.5) vs. G2: 2 (1.2) G3: 0 (0.0) vs. G4: 4 (0.8) G5: 3 (2.3) vs. G6: 1 (0.2) p=NS Dyskinesia^f^, n (%) G1: 2 (0.5) vs. G2: 2 (1.2) G3: 0 (0.0) vs. G4: 4 (0.8) G5: 3 (2.3) vs. G6: 1 (0.2) p=NS EPS^g^, n (%) G1: 1 (0.3) vs. G2: 3 (1.8) G3: 1 (1.4) vs. G4: 3 (0.6) G5: 2 (1.5) vs. G6: 2 (0.5) p=NS Sedation, n (%) G1: 3 (0.8) vs. G2: 1 (0.6) G3: 1 (1.4) vs. G4: 3 (0.6) G5: 2 (1.5) vs. G6: 2 (0.5) p=NS Postural dizziness, n (%) G1: 3 (0.8) vs. G2: 0 (0.0) G3: 0 (0.0) vs. G4: 3 (0.6) G5: 2 (1.5) vs. G6: 1 (0.2) p=NS Increased weight, n (%) G1: 3 (0.8) vs. G2: 0 (0.0) G3: 1 (1.4) vs. G4: 2 (0.4) G5: 0 (0.0) vs. G6: 3 (0.7) p=NS Akathisia, n (%) G1: 2 (0.5) vs. G2: 0 (0.0) G3: 1 (1.4) vs. G4: 1 (0.2) G5: 0 (0.0) vs. G6: 2 (0.5) p=NS Oculogyric crisis, n (%) G1: 2 (0.5) vs. G2: 0 (0.0) G3: 1 (1.4) vs. G4: 1 (0.2) G5: 0 (0.0) vs. G6: 2 (0.5) p=NS Salivary hypersecretion, n (%) G1: 1 (0.3) vs. G2: 1 (0.6) G3: 1 (1.4) vs. G4: 1 (0.2) G5: 0 (0.0) vs. G6: 2 (0.5) p=NS Very few discontinuations due to clinically significant adverse events with olanzapine vs. risperidone vs. haloperidol medication, p=NR. | High

a Also no excitation or disinhibition in patients receiving flunitrazepam, not reported for the haloperidol.82

b Dosages of study drugs were selected based on patients' weight, which the treating clinician estimated visually.102

c The one case of dystonic reaction occurring in the droperidol group was characterized by torticollis and tongue protrusion. The patient responded well to i.v. diphenhydramine.102

d The study followed enrolled patients over the first 6 days of their hospitalizations. Baseline was day 1, and the following 5 days (days 2–6) represented the followup period.106

e A total of 37 patients experienced one or more treatment-emergent adverse events, but some patients were included in more than one category of adverse event.106

f Included early (n=3) and perioral dyskinesias (n=1).106

g Extrapyramidal symptoms were described as “extrapyramidal disorder” by study authors.106

AE = adverse event; CI = confidence interval; EPS = extrapyramidal symptoms; G = group; i.m. = intramuscular; i.v. = intravenous; kg = kilogram(s); mg = milligram; mins = minutes; n = number of events; NR = not reported; NS = not significant; PO = orally; QT = Q and T wave intervals; RCT = randomized controlled trial; SBP = systolic blood pressure; vs. = versus.

##### Medication Protocols Versus Other Medication Protocols or Alternative Strategies

###### Controlled Studies

Four RCTs77,82,98,102 and two NRCTs99,106 reported medication side effects (Table 13).

One double-blind RCT compared single-dose 10 mg i.m. midazolam (considered the standard treatment) with 10 mg i.m. droperidol and with 5 mg i.m. midazolam plus 5 mg i.m. droperidol in 79 patients. Midazolam resulted in a higher incidence of medication side effects (n=8) compared with droperidol (n=2) or with a lower-dose combination of the two (n=2); and the medication regimens did not differ in the incidence of abnormal QT interval (n=2 vs. 2 and 4, respectively). The investigators did not report statistical significance of these findings.

A second RCT compared single-dose intravenous droperidol (2.5 mg or 5 mg if weight < or > 50 kg) with lorazepam (2 mg or 4 mg if weight < or > 50 mg) in 202 acutely agitated patients in an emergency department who were at risk of placing themselves and staff at danger and required constant supervision.102 No patients experienced an acute allergic reaction or needed airway intervention, but one droperidol-treated patient experienced an acute dystonic reaction. Between-group differences in reductions in vital signs (pulse, respiratory rate, blood pressure, and body temperature) were not statistically significant.

Two RCTs compared i.m. haloperidol with a different psychotropic medication in actively psychotic patients. One compared single-dose 5 mg i.m. haloperidol plus 2 mg lorazepam (considered the standard treatment) with lorazepam alone in 20 adults treated in a psychiatric emergency service setting.98 The other compared 5 mg i.m. haloperidol with 1 mg i.m. flunitrazepam in 28 patients.82 Neither trial reported any statistically different incidences of medication-related adverse events or side effects.

One NRCT reported no statistically significant differences in the incidence of abnormal gait, dizziness, extrapyramidal events, headache, hypotension, or somnolence in 101 adult inpatients with psychosis who were treated for 72 hours with one of three oral second-generation antipsychotics (2–6 mg/day risperidone, 10–20 mg/day olanzapine, 300–800 mg/day quetiapine) or with oral 5–15 mg/day haloperidol.99

One naturalistic, observational NRCT of 588 agitated psychiatric inpatients reported the percentage of adverse events considered related to primary antipsychotic medication as 5.4 percent for olanzapine, 11.1 percent for risperidone, and 9.1 percent for haloperidol. The percentage of serious medication adverse events was low for all treatments: haloperidol (1.5%), olanzapine (0.3%), and risperidone (0.0%).106

#### Key Question 2c Reducing Seclusion and Restraint Use

No studies provided information on the comparative harms of staff training, risk assessment, multimodal, or environmental or group psychotherapeutic interventions to reduce use of seclusion and restraint for patients with active aggression. We identified one study, a pre/post study, that addressed the use of medication protocol interventions to reduce the use of seclusion and restraint for actively aggressive patients. Thus, all SOE grades were insufficient.

##### Medication Protocols Versus Other Medication Protocols or Alternative Strategies

###### Controlled Studies

We identified no eligible studies.

###### Pre/Post Studies

One pre/post study compared the number of employee injuries before and after implementation of a hospital-wide ban on p.r.n. orders for psychotropic medications.76 Fourteen staff injuries occurred during the 3-month period when p.r.n orders were permitted, and 12 staff injuries occurred during the 3-month period when p.r.n. orders were not permitted.

## Key Question 3 Characteristics Modifying the Comparative Benefits or Harms of Strategies

For this KQ, we had intended to evaluate potential moderators of the benefits or harms of strategies to prevent or de-escalate aggressive behavior or reduce the use of seclusion or restraints. However, we found no eligible studies of staff training, risk assessment, environmental or group psychotherapeutic, multimodal, or medication protocol interventions for KQ 3. SOE is, therefore, insufficient in all cases.