# References

1 Morrison EF. Violent psychiatric inpatients in a public hospital. Sch Inq Nurs Pract. Spring. 1990;4(1):65-82. discussion 3-6. [pmid: 2326569].
2 National Association of State Mental Health Program Directors. National Virginia Mental Health Institute, Department of Nursing Services, Policies and Procedures. Seclusion or Restraint. Alexandria, VA. 2008. http://www.nasmhpd.org/sites/default/files/I_2_B_VA_NMHI_SRPolicies.pdf. 19 January 2015.
3 U.S. Department of Health and Human Services, Health Care Financing Administration. Medicare and Medicaid Programs: Conditions of Participation: Patients' Rights. Interim Final Rule, 42 CFR 482. Fed Regist. 1999;64:36069-89.
4 Joint Commission on Accreditation of Healthcare Organizations. Comprehensive Accreditation Manual for Hospitals: The Official Handbook. Oakbrook Terrace, IL. Joint Commission Resources. 2000.
5 Centers for Medicare & Medicaid Services. State Operations Manual. Department of Health and Human Services. 2008. https://www.cms.gov/Regulations-and-Guidance/Guidance/Transmittals/downloads/R37SOMA.pdf.
6 DeLacy L, Edner B, Hart C, et al. Learning from Each Other: Success Stories and Ideas for Reducing Restraint/Seclusion in Behavioral Health. American Psychiatric Association, American Psychiatric Nurses Association, National Association of Psychiatric Health Systems, and American Hospital Association Section for Psychiatric and Substance Abuse Services. 2003. http://c.ymcdn.com/sites/www.copaa.org/resource/collection/662B1866-952D-41FA-B7F3-D3CF68639918/Learning_from_each_other_-reducing_restraint.pdf. 19 January 2015.
7 Janssen WA, van de Sande R, Noorthoorn EO, et al. Methodological issues in monitoring the use of coercive measures. Int J Law Psychiatry. Nov-Dec. 2011;34(6):429-38. [pmid: 22079087].
8 Cornaggia CM, Beghi M, Pavone F, et al. Aggression in psychiatry wards: a systematic review. Psychiatry Res. Aug. 30. 2011;189(1):10-20. [pmid: 21236497].
9 Bowers L, Stewart D, Papadopoulos C, et al. Inpatient violence and aggression: a literature review. Report from the Conflict and Containment Reduction Research Programme. Section of Mental Health Nursing Health Service and Population Research Institute of Psychiatry Kings College London. Institute of Psychiatry, Kings College London. May. 2011. http://www.kcl.ac.uk/ioppn/depts/hspr/research/ciemh/mhn/projects/litreview/litrevagg.pdf.
10 Hem E, Steen O, Opjordsmoen S. Thrombosis associated with physical restraints. Acta Psychiatr Scand. Jan. 2001;103(1):73-5. discussion 5-6. [pmid: 11202132].
11 National Alliance on Mental Illness. Policy Topics: What are Restraints and Seclusion?. http://www.nami.org/Template.cfm?Section=issue_spotlights&template=/ContentManagement/ContentDisplay.cfm&ContentID=7803. 14 January 2015.
12 Sailas E, Fenton M. Seclusion and restraint for people with serious mental illnesses. Cochrane Database Syst Rev. 2000;2(2). CD001163. [pmid: 10796606].
13 Steinert T, Lepping P, Bernhardsgrutter R, et al. Incidence of seclusion and restraint in psychiatric hospitals: a literature review and survey of international trends. Soc Psychiatry Psychiatr Epidemiol. Sep. 2010;45(9):889-97. [pmid: 19727530].
14 Bowers L, van der Werf B, Vokkolainen A, et al. International variation in containment measures for disturbed psychiatric inpatients: a comparative questionnaire survey. Int J Nurs Stud. Mar. 2007;44(3):357-64. [pmid: 16524581].
15 Muralidharan S, Fenton M. Containment strategies for people with serious mental illness. Cochrane Database Syst Rev. 2006;(3). CD002084. Epub: 2006/07/21. [pmid: 16855984].
16 Batscha C, O'Reilly C, Allen D. Position Statement: The Use of Seclusion and Restraint. 2014 APNA Institute for Safe Environments Workgroup to Seclusion & Restraint Position Paper. 2014.
17 International Society of Psychiatric-Mental Health Nurses ISPN position statement on the use of restraint and seclusion. J Child Adolesc Psychiatr Nurs. Jul-Sep. 2001;14(3):100. 2. Epub: 2002/01/30. [pmid: 11814075].
18 National Alliance on Mental Illness. National Alliance on Mental Illness's (NAMI) Position on Seclusion and Restraints. Arlington, VA. National Alliance on Mental Illness. 2015. https://www.nami.org/NAMI/media/NAMI-Media/downloads/Public-Policy-Platform-11th-ed-2016.pdf. 13 May 2015.
19 Richmond JS, Berlin JS, Fishkind AB, et al. Verbal de-escalation of the agitated patient: consensus statement of the American Association for Emergency Psychiatry Project BETA de-escalation workgroup. West J Emerg Med. Feb. 2012;13(1):17-25. [pmid: 22461917].
20 American Hospital Association, National Association of Psychiatric Health Systems. Guiding Principles on Restraint and Seclusion for Behavioral Health Services. Washington, DC. National Association of Psychiatric Health Systems. 1999. https://www.naphs.org/resources/home.aspx?product-tab=1. 13 May 2015.
21 Huckshorn KA. Re-designing state mental health policy to prevent the use of seclusion and restraint. Adm Policy Ment Health. Jul. 2006;33(4):482-91. Epub: 2005/10/26. [pmid: 16244812].
22 Mental Health: Improper Restraint or Seclusion Use Places People at Risk. United States General Accounting Office Report to Congressional Requesters. GAO/HEHS-99-176. 1999. http://www.gao.gov/archive/1999/he99176.pdf.
23 Metzner JL, Tardiff K, Lion J, et al. Resource document on the use of restraint and seclusion in correctional mental health care. J Am Acad Psychiatry Law. 2007;35:417-25. [pmid: 18086731].
24 Curie CG. SAMHSA's commitment to eliminating the use of seclusion and restraint. Psychiatr Serv. Sep. 2005;56(9):1139-40. [pmid: 16148330].
25 Donat DC. An analysis of successful efforts to reduce the use of seclusion and restraint at a public psychiatric hospital. Psychiatr Serv. Aug. 2003;54(8):1119-23. [pmid: 12883139].
26 International Quality Indicator Project. Performance Assessment Tool for Quality Improvement in Hospitals. Copenhagen, Denmark. World Health Organization Regional Office for Europe. 2009. January 19, 2015. http://www.pathqualityproject.eu/other_organizations_and_networks.html. 19 January 2015.
27 Hospital-Based Inpatient Psychiatric Services (HBIPS) Core Measure Set Selection Form. www.jointcommission.org/assets/1/18/HBIPS_CM_selection_form_revised082408.pdf. 13 January 2015.
28 American Nurses Association. ANA Position Statement. Reduction of Patient Restraint and Seclusion in Health Care Settings. American Nurses Association. 2012. http://www.nursingworld.org/MainMenuCategories/EthicsStandards/Ethics-Position-Statements/Reduction-of-Patient-Restraint-and-Seclusion-in-Health-Care-Settings.pdf. 20 January 2015.
29 Smith GM, Davis RH, Bixler EO, et al. Pennsylvania State Hospital system's seclusion and restraint reduction program. Psychiatr Serv. Sep. 2005;56(9):1115-22. Epub: 2005/09/09. [pmid: 16148327].
30 Substance Abuse and Mental Health Services Administration. Alternatives to Seclusion and Restraint in Behavioral Health Care. Washington, DC. U.S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration. 2011. http://www.integration.samhsa.gov/clinical-practice/promoting_alternatives_to_seclusion_and_restraint.pdf. 19 January 2015.
31 Substance Abuse and Mental Health Services Administration. Roadmap to Seclusion and Restraint Free Mental Health Services (CD). Washington, DC. U.S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration. 2006. http://store.samhsa.gov/product/Roadmap-to-Seclusion-and-Restraint-Free-Mental-Health-Services-CD-/SMA06-4055. 19 January 2015.
32 Huckshorn KA. Six Core Strategies for Reducing Seclusion and Restraint Use. Alexandria, VA. National Association of State Mental Health Program Directors. 2006. http://www.nasmhpd.org/sites/default/files/Consolidated%20Six%20Core%20Strategies%20Document.pdf. 18 May 2016.
33 Azeem MW, Aujla A, Rammerth M, et al. Effectiveness of six core strategies based on trauma informed care in reducing seclusions and restraints at a child and adolescent psychiatric hospital. J Child Adolesc Psychiatr Nurs. Feb. 2011;24(1):11-5. Epub: 2011/01/29. [pmid: 21272110].
34 Huckshorn KA. Reducing seclusion and restraint use in mental health settings: core strategies for prevention. J Psychosoc Nurs Ment Health Serv. 2004;42(9):22-33. Review. [pmid: 15493493].
35 Champagne T, Stromberg N. Sensory approaches in inpatient psychiatric settings: innovative alternatives to seclusion and restraint. J Psychosoc Nurs Ment Health Serv. Sep. 2004;42(9):34-44. Epub: 2004/10/21. [pmid: 15493494].
36 Ashcraft L, Anthony W. Eliminating seclusion and restraint in recovery-oriented crisis services. Psychiatr Serv. Oct. 2008;59(10):1198-202. Epub: 2008/10/04. [pmid: 18832507].
37 Ashcraft L, Anthony WA. Crisis services in the ‘living room’. Behavioral Healthcare. Jul. 2006;26(7):12. 4. 228068997. [pmid: 16915881].
38 Substance Abuse and Mental Health Services Administration. SAMHSA's Concept of Trauma and Guidance for a Trauma-Informed Approach. HHS Publication No. (SMA) 14-4884. Substance Abuse and Mental Health Services Administration. Rockville, MD. 2014.
39 Ehmann TS, Ross D, Au T, et al. 26. Aggression among patients with treatment refractory psychoses. Schizophr Res. 1997;24(1–2):14.
40 Sears M. Humanizing Health Care: Creating Cultures of Compassion With Nonviolent Communication. Encinitas, CA. Independent Publishers Group. 2010.
41 Knox DK, Holloman GH Jr. Use and avoidance of seclusion and restraint: consensus statement of the american association for emergency psychiatry project Beta seclusion and restraint workgroup. West J Emerg Med. Feb. 2012;13(1):35-40. Epub: 2012/03/31. [pmid: 22461919].
42 Wisdom JP, Wenger D, Robertson D, et al. The New York State Office of Mental Health Positive Alternatives to Restraint and Seclusion (PARS) Project. Psychiatr Serv. 2015. May. 1. appips201400279. Epub: 2015/05/02. [pmid: 25930039].
43 Wale JB, Belkin GS, Moon R. Reducing the use of seclusion and restraint in psychiatric emergency and adult inpatient services- improving patient-centered care. Perm J. Spring. 2011;15(2):57-62. [pmid: 21841927].
44 Recupero PR, Price M, Garvey KA, et al. Restraint and seclusion in psychiatric treatment settings: regulation, case law, and risk management. J Am Acad Psychiatry Law. 2011;39(4):465-76. Epub: 2011/12/14. [pmid: 22159974].
45 Gaskin CJ, Elsom SJ, Happell B. Interventions for reducing the use of seclusion in psychiatric facilities: review of the literature. Br J Psychiatry. Oct. 2007;191:298-303. Epub: 2007/10/02. [pmid: 17906239].
46 Loucks J, Rutledge DN, Hatch B, et al. Rapid response team for behavioral emergencies. J Am Psychiatr Nurses Assoc. Mar. 2010;16(2):93-100. [pmid: 21659266].
47 Smith GM, Ashbridge DM, Davis RH, et al. Correlation between reduction of seclusion and restraint and assaults by patients in Pennsylvania's state hospitals. Psychiatr Serv. Mar. 1. 2015;66(3):303-9. Epub: 2015/03/03. [pmid: 25727119].
48 Wilson MP, Pepper D, Currier GW, et al. The psychopharmacology of agitation: consensus statement of the american association for emergency psychiatry project Beta psychopharmacology workgroup. West J Emerg Med. Feb. 2012;13(1):26-34. Epub: 2012/03/31. [pmid: 22461918].
49 Zyprexa: Highlights of Prescribing Information (December 2014). U.S. Food and Drug Administration. 2014. http://www.accessdata.fda.gov/drugsatfda_docs/label/2014/020592s062021086s040021253s048lbl.pdf. May 12, 2015.
50 Geodon: Highlights of Prescribing Information (December 2014). U.S. Food and Drug Administration. 2014. http://www.accessdata.fda.gov/drugsatfda_docs/label/2014/020825s053,020919s040,s021483s013lbl.pdf. May 12, 2015.
51 Otsuka America Pharmaceutical I. Abilify: Highlights of prescribing information (December 2014). Tokyo. Otsuka America Pharmaceutical, Inc. 2014. December. http://www.accessdata.fda.gov/drugsatfda_docs/label/2014/021436s038,021713s030,021729s022,021866s023lbl.pdf. May 12, 2015.
52 Alexza Pharmaceuticals I. Adasuve (Loxapine): Highlights of Prescribing Information. Mountain View, CA. Alexza Pharmaceuticals, Inc. 2012. http://www.accessdata.fda.gov/drugsatfda_docs/label/2012/022549s000lbl.pdf. May 15, 2015.
53 Keski-Valkama A, Sailas E, Eronen M, et al. Who are the restrained and secluded patients: a 15-year nationwide study. Soc Psychiatry Psychiatr Epidemiol. Nov. 2010;45(11):1087-93. Epub: 2009/10/22. [pmid: 19844645].
54 Möhler R, Richter T, Köpke S, et al. Interventions for preventing and reducing the use of physical restraints in long-term geriatric care. Cochrane Database of Syst Rev. Feb. 16. 2011;(2). CD007546. [pmid: 21328295].
55 Agency for Healthcare Research and Quality. Evidence-based Practice Center Systematic Review Protocol. Non-Pharmacologic Interventions for Agitation and Aggression in Dementia. Rockville, MD. Agency for Healthcare Research and Quality. 2014. http://effectivehealthcare.ahrq.gov/ehc/products/559/1999/dementia-agitation-aggression-protocol-141113.pdf. July 2, 2015.
56 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders (3rd edition, revised; DSM–III–R). Washington, DC. American Psychiatric Association. 1987.
57 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders (4th Edition; DSM-IV). Washington, DC. American Psychiatric Association. 1994.
58 American Psychiatric Association. Diagnostic and Statistical Manual of Mental Disorders (5th edition; DSM-5). Washington, DC. American Psychiatric Association. 2013.
59 Centers for Medicare & Medicaid Services. Appendix A - Survey Protocol, Regulations and Interpretive Guidelines for Hospitals. Atlanta, GA. Centers for Medicaire and Medicaid Services. 2015. http://www.cms.gov/Regulations-and-Guidance/Guidance/Manuals/downloads/som107ap_a_hospitals.pdf. 2 July.
60 Kovich LA. Request For Proposals: For the development of psychiatric involuntary inpatient beds as an alternative to state hospitalization. New Jersey, US. New Jersey State Division of Mental Health and Addiction Services. 2012. http://www.state.nj.us/humanservices/providers/grants/rfprfi/RFPfiles/RFPExtendedAcuteCareBeds2012.pdf.
61 Agency for Healthcare Research and Quality. Methods Guide for Effectiveness and Comparative Effectiveness Reviews. AHRQ Publication No. 10(14)-EHC063-EF. Rockville, MD. Agency for Healthcare Research and Quality. January. 2014. Chapters available at http://effectivehealthcare.ahrq.gov/index.cfm/search-for-guides-reviews-and-reports/?pageaction=displayproduct&productid=318.
62 Moher D, Liberati A, Tetzlaff J, et al. Preferred reporting items for systematic reviews and meta-analyses: the PRISMA statement. J Clin Epidemiol. Oct. 2009;62(10):1006-12. Epub: 2009/07/28. [pmid: 19631508].
63 U.S. Department of Health and Human Services, Health Care Financing Administration. 42 CFR §483.13 - Resident behavior and facility practices. Fed Regist. 1991;56(187):46626-8842.
64 Balshem H, Stevens A, Ansari M, et al. Finding Grey Literature Evidence and Assessing for Outcome and Analysis Reporting Biases When Comparing Medical Interventions: AHRQ and the Effective Health Care Program. Methods Guide for Comparative Effectiveness Reviews. (Prepared by the Oregon Health and Science University and the University of Ottawa Evidencebased Practice Centers under Contract Nos. 290-2007-10057-I and 290-2007-10059-I.) AHRQ Publication No. 13(14)-EHC096-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
65 United Nations Development Programme (UNDP). Human Development Report 2014 - Sustaining Human Progress: Reducing Vulnerabilities and Building Resilience. United Nations Development Programme. 2014. http://hdr.undp.org/en/2014-report.
66 Penfold RB, Zhang F. Use of interrupted time series analysis in evaluating health care quality improvements. Acad Pediatr. Nov-Dec. 2013;13(6 Suppl):S38-44. Epub: 2013/12/07. [pmid: 24268083].
67 Viswanathan M, Ansari MT, Berkman ND, et al. Assessing the Risk of Bias of Individual Studies in Systematic Reviews of Health Care Interventions. AHRQ Publication No. 12-EHC047-EF. Rockville, MD. Agency for Healthcare Research and Quality Methods Guide for Comparative Effectiveness Reviews. March. 2012. www.effectivehealthcare.ahrq.gov/.
68 Cochrane Collaboration. Part 3: Special topics. Chapter 16: Special topics in statistics. 16.3: Cluster-randomized trials. 16.3.2: Assessing risk of bias in cluster-randomized trials. Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions. Version 5.1.0. London, UK. The Cochrane Collaboration. 2011.
69 Viswanathan M, Berkman ND. Development of the RTI item bank on risk of bias and precision of observational studies. J Clin Epidemiol. Feb. 2012;65(2):163-78. Epub: 2011/10/01. [pmid: 21959223].
70 Gartlehner G, Gaynes BN, Amick HR, et al. Nonpharmacological Versus Pharmacological Treatments for Adult Patients with Major Depressive Disorder. Comparative Effectiveness Review No.161. (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290-2012-00008i) AHRQ Publication No. 15(16)-EHC031-EF. Rockville, MD. Agency for Healthcare Research and Quality. December. 2015. http://www.effectivehealthcare.ahrq.gov/reports/final.cfm.
71 Shea BJ, Grimshaw JM, Wells GA, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. Epub: 2007/02/17. [pmid: 17302989].
72 West SL, Gartlehner G, Mansfield AJ, et al. Comparative Effectiveness Review Methods: Clinical Heterogeneity. Methods Research Paper AHRQ Publication No. 10-EHC070-EF. Rockville MD. Agency for Healthcare Research and Quality. September. 2010. http://effectivehealthcare.ahrq.gov/. [pmid: 21433337].
73 Berkman ND, Lohr KN, Ansari M, et al. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Comparative Effectiveness Reviews. (Prepared by the RTI International-University of North Carolina Evidence-based Practice Center under Contract No. 290- 2007-10056-I) AHRQ Publication No. 13(14)-EHC130-EF. Rockville, MD. Agency for Healthcare Research and Quality. November. 2013. www.effectivehealthcare.ahrq.gov/reports/final.cfm.
74 Berkman ND, Lohr KN, Ansari MT, et al. Grading the strength of a body of evidence when assessing health care interventions: an EPC update. J Clin Epidemiol. 2014. Dec. 20. Epub: 2015/02/28. [pmid: 25721570].
75 Atkins D, Chang SM, Gartlehner G, et al. Assessing applicability when comparing medical interventions: AHRQ and the Effective Health Care Program. J Clin Epidemiol. Nov. 2011;64(11):1198-207. Epub: 2011/04/06. [pmid: 21463926].
76 Thapa PB, Palmer SL, Owen RR, et al. PRN (as-needed) orders and exposure of psychiatric inpatients to unnecessary psychotropic medications. Psychiatr Serv. Sep. 2003;54(9):1282-6. [pmid: 12954947].
77 Isbister GK, Calver LA, Page CB, et al. Randomized controlled trial of intramuscular droperidol versus midazolam for violence and acute behavioral disturbance: the DORM study. Ann Emerg Med. Oct. 2010;56(4):392-401 e1. Epub: 2010/09/28. [pmid: 20868907].
78 Abderhalden C, Needham I, Dassen T, et al. Structured risk assessment and violence in acute psychiatric wards: randomised controlled trial. Br J Psychiatry. Jul. 2008;193(1):44-50. Epub: 2008/08/14. [pmid: 18700217].
79 Hellerstein DJ, Staub AB, Lequesne E. Decreasing the use of restraint and seclusion among psychiatric inpatients. J Psychiatr Pract. Sep. 2007;13(5):308-17. Epub: 2007/09/25. [pmid: 17890979].
80 Vaaler AE, Morken G, Flovig JC, et al. Effects of a psychiatric intensive care unit in an acute psychiatric department. Nord J Psychiatry. 2006;60(2):144-9. Epub: 2006/04/26. [pmid: 16635934].
81 Vaaler AE, Iversen VC, Morken G, et al. Short-term prediction of threatening and violent behaviour in an acute psychiatric intensive care unit based on patient and environment characteristics. BMC Psychiatry. 2011;11:44. Epub: 2011/03/23. [pmid: 21418581].
82 Dorevitch A, Katz N, Zemishlany Z, et al. Intramuscular flunitrazepam versus intramuscular haloperidol in the emergency treatment of aggressive psychotic behavior. Am J Psychiatry. Jan. 1999;156(1):142-4. Epub: 1999/01/19. [pmid: 9892313].
83 Melson J, Kane M, Mooney R, et al. Improving alcohol withdrawal outcomes in acute care. Perm J. Spring. 2014;18(2):e141-5. Epub: 2014/05/29. [pmid: 24867561].
84 Chang NA, Grant PM, Luther L, et al. Effects of a recovery-oriented cognitive therapy training program on inpatient staff attitudes and incidents of seclusion and restraint. Community Ment Health J. May. 2014;50(4):415-21. Epub: 2013/12/18. [pmid: 24337473].
85 Michaud CJ, Thomas WL, McAllen KJ. Early pharmacological treatment of delirium may reduce physical restraint use: a retrospective study. Ann Pharmacother. Mar. 2014;48(3):328-34. Epub: 2013/11/22. [pmid: 24259659].
86 Georgieva I, Mulder CL, Noorthoorn E. Reducing seclusion through involuntary medication: a randomized clinical trial. Psychiatry Res. Jan. 30. 2013;205(1-2):48-53. Epub: 2012/09/07. [pmid: 22951334].
87 van de Sande R, Nijman HL, Noorthoorn EO, et al. Aggression and seclusion on acute psychiatric wards: effect of short-term risk assessment. Br J Psychiatry. Dec. 2011;199(6):473-8. Epub: 2011/10/22. [pmid: 22016437].
88 Emmerson B, Fawcett L, Ward W, et al. Contemporary management of aggression in an inner city mental health service. Australas Psychiatry. Apr. 2007;15(2):115-9. Epub: 2007/04/28. [pmid: 17464653].
89 Pollard R, Yanasak EV, Rogers SA, et al. Organizational and unit factors contributing to reduction in the use of seclusion and restraint procedures on an acute psychiatric inpatient unit. Psychiatr Q. Mar. 2007;78(1):73-81. Epub: 2006/11/15. [pmid: 17102932].
90 Bowers L, Brennan G, Flood C, et al. Preliminary outcomes of a trial to reduce conflict and containment on acute psychiatric wards: City Nurses. J Psychiatr Ment Health Nurs. Apr. 2006;13(2):165-72. Epub: 2006/04/13. [pmid: 16608471].
91 Khadivi AN, Patel RC, Atkinson AR, et al. Association between seclusion and restraint and patient-related violence. Psychiatr Serv. Nov. 2004;55(11):1311-2. Epub: 2004/11/10. [pmid: 15534024].
92 Jonikas JA, Cook JA, Rosen C, et al. A program to reduce use of physical restraint in psychiatric inpatient facilities. Psychiatr Serv. Jul. 2004;55(7):818-20. Epub: 2004/07/03. [pmid: 15232023].
93 D'Orio BM, Purselle D, Stevens D, et al. Reduction of episodes of seclusion and restraint in a psychiatric emergency service. Psychiatr Serv. May. 2004;55(5):581-3. Epub: 2004/05/07. [pmid: 15128969].
94 Currier GW, Farley-Toombs C. Datapoints: use of restraint before and after implementation of the new HCFA rules. Psychiatr Serv. Feb. 2002;53(2):138. Epub: 2002/02/01. [pmid: 11821540].
95 Canatsey K, Roper JM. Removal from stimuli for crisis intervention: using least restrictive methods to improve the quality of patient care. Issues Ment Health Nurs. Jan-Feb. 1997;18(1):35-44. [pmid: 9052099].
96 Bowers L, Nijman H, Allan T, et al. Prevention and management of aggression training and violent incidents on U.K. acute psychiatric wards. Psychiatr Serv. Jul. 2006;57(7):1022-6. [pmid: 16816288].
97 Laker C, Gray R, Flach C. Case study evaluating the impact of de-escalation and physical intervention training. J Psychiatr Ment Health Nurs. Apr. 2010;17(3):222-8. [pmid: 20465771].
98 Bieniek SA, Ownby RL, Penalver A, et al. A double-blind study of lorazepam versus the combination of haloperidol and lorazepam in managing agitation. Pharmacotherapy. Jan-Feb. 1998;18(1):57-62. [pmid: 9469682].
99 Villari V, Rocca P, Fonzo V, et al. Oral risperidone, olanzapine and quetiapine versus haloperidol in psychotic agitation. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 15. 2008;32(2):405-13. [pmid: 17900775].
100 Forster PL, Cavness C, Phelps MA. Staff training decreases use of seclusion and restraint in an acute psychiatric hospital. Arch Psychiatr Nurs. Oct. 1999;13(5):269-71. Epub: 1999/11/24. [pmid: 10565060].
101 Bowers L, Flood C, Brennan G, et al. A replication study of the City Nurse intervention: reducing conflict and containment on three acute psychiatric wards. J Psychiatr Ment Health Nurs. Nov. 2008;15(9):737-42. [pmid: 18844799].
102 Richards JR, Derlet RW, Duncan DR. Chemical restraint for the agitated patient in the emergency department: lorazepam versus droperidol. J Emerg Med. Jul-Aug. 1998;16(4):567-73. [pmid: 9696171].
103 Smoot SL, Gonzales JL. Cost-effective communication skills training for state hospital employees. Psychiatr Serv. Aug. 1995;46(8):819-22. [pmid: 7583484].
104 Veltro F, Falloon I, Vendittelli N, et al. Effectiveness of cognitive-behavioural group therapy for inpatients. Clin Pract Epidemiol Ment Health. 2006;2:16. [pmid: 16859548].
105 Veltro F, Vendittelli N, Oricchio I, et al. Effectiveness and efficiency of cognitive-behavioral group therapy for inpatients: 4-year follow-up study. J Psychiatr Pract. Sep. 2008;14(5):281-8. Epub: 2008/10/04. [pmid: 18832959].
106 Wilhelm S, Schacht A, Wagner T. Use of antipsychotics and benzodiazepines in patients with psychiatric emergencies: results of an observational trial. BMC Psychiatry. 2008;8:61. Epub: 2008/07/24. [pmid: 18647402].
107 Campbell MK, Grimshaw JM, Elbourne DR. Intracluster correlation coefficients in cluster randomized trials: empirical insights into how should they be reported. BMC Med Res Methodol. Apr. 28. 2004;4:9. [pmid: 15115554].
108 Bak J, Brandt-Christensen M, Sestoft DM, et al. Mechanical restraint--which interventions prevent episodes of mechanical restraint?- a systematic review. Perspect Psychiatr Care. Apr. 2012;48(2):83-94. Epub: 2011/10/05. [pmid: 21967236].
109 Hermanstyne KA, Mangurian C. Behavioral strategies to mitigate violent behavior among inpatients: a literature review. Psychiatr Serv. May. 1. 2015;66(5):557-8. Epub: 2015/05/02. [pmid: 25930227].
110 Nelstrop L, Chandler-Oatts J, Bingley W, et al. A systematic review of the safety and effectiveness of restraint and seclusion as interventions for the short-term management of violence in adult psychiatric inpatient settings and emergency departments. Worldviews Evid Based Nurs. 2006;3(1):8-18. [pmid: 17040518].
111 Zeller SL, Rhoades RW. Systematic reviews of assessment measures and pharmacologic treatments for agitation. Clin Ther. Mar. 2010;32(3):403-25. [pmid: 20399981].
112 Putkonen A, Kuivalainen S, Louheranta O, et al. Cluster-randomized controlled trial of reducing seclusion and restraint in secured care of men with schizophrenia. Psychiatr Serv. Sep. 1. 2013;64(9):850-5. Epub: 2013/06/19. [pmid: 23771480].
113 Krakowski MI, Czobor P, Citrome L, et al. Atypical antipsychotic agents in the treatment of violent patients with schizophrenia and schizoaffective disorder. Arch Gen Psychiatry. Jun. 2006;63(6):622-9. [pmid: 16754835].
114 Bosanac P, Hollander Y, Castle D. The comparative efficacy of intramuscular antipsychotics for the management of acute agitation. Australas Psychiatry. Dec. 2013;21(6):554-62. Epub: 2013/09/03. [pmid: 23996795].
115 National Registry of Evidenced-Based Programs and Practices Six Core Strategies© to prevent confl ict and violence: Reducing the use of seclusion and restraint. Washington, DC. US Department of Health and Human Services, Substance Abuse and Mental Health Services Administration. 2012. http://legacy.nreppadmin.net/ViewIntervention.aspx?id=278. 3 October 2016.
116 American Psychiatric Nurses Association. APNA Position Statement on the Use of Seclusion and Restraint. (Original, 2000; Revised, 2007; Revised, 2014). Falls Church, VA. American Psychiatric Nurses Association. 2014. http://www.apna.org/i4a/pages/index.cfm?pageid=3728#sthash.qeeOHEkL.dpuf http://www.apna.org/i4a/pages/index.cfm?pageid=3728. 3 October 2016.
117 LeBel JL, Duxbury JA, Putkonen A, et al. Multinational experiences in reducing and preventing the use of restraint and seclusion. J Psychosoc Nurs Ment Health Serv. Nov. 2014;52(11):22-9. [pmid: 25310674].