# Methods

The methods for this comparative effectiveness review (CER) follow the guidance provided in the Agency for Healthcare Research and Quality (AHRQ) Methods Guide for Effectiveness and Comparative Effectiveness Reviews (www.effectivehealthcare.ahrq.gov/methodsguide.cfm) for the Evidence-based Practice Center (EPC) program.61 Certain methods map to the Preferred Reporting Items for Systematic Reviews and Meta-Analyses (PRISMA) checklist.62 All methods and analyses were determined a priori.

The AHRQ Effective Health Care (EHC) program's Topic Triage group developed and reviewed the topic; because this group deemed the topic sufficiently relevant, they moved it forward for the Topic Refinement phase. All topics are reviewed and assessed for appropriateness for systematic review (see EHC Web site for information on the process for selecting topics: http://www.effectivehealthcare.ahrq.gov/index.cfm/submit-a-suggestion-for-research/how-are-research-topics-chosen/). Once a topic is assessed and determined to be appropriate for further product development in the EHC program, AHRQ assigns it to a research team. Further development of the topic occurs with the input of Key Informants and Technical Experts (see the EHC Web site for information on the research process: http://www.effectivehealthcare.ahrq.gov/index.cfm/submit-a-suggestion-for-research/what-is-the-research-process/).

## Topic Refinement and Review Protocol

During topic refinement for this topic, we engaged in a public process to develop Key Questions (KQs) for the review. We also developed a draft and then final review protocol. Specifically, we generated an analytic framework, preliminary KQs, and preliminary inclusion/exclusion criteria; these reflect PICOTS constructs (patients or populations, interventions, comparators, outcomes, timing, and settings) and other details about eligible studies. Information from the topic nominator helped guide our processes. A panel of 10 Key Informants (KIs) gave input on the scope and details of initial KQs; they supported the KQs as described, but suggested adding gender and staff training and competence as important potential effect modifiers for KQ 3. These KQs were posted on AHRQ's Web site for public comment (www.effectivehealthcare.ahrq.gov) from June 8, 2015, through June 29, 2015. We then revised the KQs as needed.

In addition, we consulted with seven experts (members of a Technical Expert Panel), who provided feedback as we developed our review protocol. Their inputs addressed points such as sample size thresholds for eligible studies and whether and how to limit assessments of risk of bias of individual studies.

## Literature Search Strategy

### Search Strategy

To identify relevant KQ-specific articles, we searched MEDLINE^®^ (via PubMed), Embase®, the Cochrane Library, Academic Search Premier, PsycINFO, and CINAHL (Cumulative Index to Nursing and Allied Health Literature) from January 1, 1991, through February 3, 2016. Appendix A presents the full search strategy (limiting searches to English and human-only studies). We selected this opening date because this year marks the time that the Health Care Financing Administration (now the Centers for Medicare & Medicaid Services) first released rules to minimize the use of seclusion and restraints in health care facilities, with this first rule addressing nursing homes.63 An experienced information scientist—our EPC librarian—ran all searches.

Our searches focused on comparative studies of de-escalation strategies (seclusion, restraints, or alternatives to seclusion or restraints) for patients with psychiatric disorders or severe psychiatric symptomatology who are at risk of, or presenting with, aggressive behavior across various acute health care settings. Search strings included various Medical Subject Heading (MeSH) terms for psychiatric disorders, acute health care settings, and aggressive behavior. Our inclusion criteria limited populations to patients 18 years of age and older.

Also, they included any psychiatric or substance use disorder, as well as delirium. If the study population was limited to patients with dementia, we deemed that article ineligible. Acute health care settings could include general hospitals, psychiatric hospitals, and emergency departments in these hospitals. To capture aggressive behavior, we used MeSH terms for aggression, violence, psychomotor agitation, hostility, crisis intervention, physical restraint, patient isolation, and psychotropic medications.

We also manually searched reference lists of pertinent reviews, included trials, and background articles to identify relevant citations that our searches might have missed. We imported all citations into an EndNote® X7 electronic database.

To find relevant gray literature we followed guidance from the AHRQ Methods Guide for Effectiveness and Comparative Effectiveness Reviews for these steps.64 Sources of gray literature included ClinicalTrials.gov, the World Health Organization's Library Database, the National Institutes of Health Research Portfolio Online Reporting Tools (RePORTer) database, the National Institute of Mental Health Web site, the American Psychological Association Web site, the American Psychiatric Association Web site, and the Substance Abuse and Mental Health Services Administration Web site. We opted not to search all of the gray literature sources described in our published protocol, specifically, Drugs@FDA, the European Medicines Agency, Scopus, and the Conference Proceedings Citation Index, because we felt confident that our other searches would have already captured any literature relevant to our Key Questions that these sources might have yielded.

The AHRQ Scientific Resource Center requested scientific information packets or information on unpublished studies or data relevant for this systematic review from relevant pharmaceutical manufacturing companies and other stakeholders and organizations related to the use of pharmacologic and nonpharmacologic alternatives to seclusion or restraints. No responses were received.

### Inclusion and Exclusion Criteria

For the above KQs, the following PICOTS criteria for populations, interventions, comparators, outcomes, time frames, and settings apply (see also Table 1):

Table 1 Eligibility criteria for review of strategies to de-escalate aggressive behavior

PICOTS | Inclusion | Exclusion
Populations | KQs 1 through 3:; - Adult individuals (ages 18 or older) with an identified psychiatric disorder (if in an inpatient setting), including substance use disorders and delirium (but not dementia), or with severe psychiatric symptomatology (if in an emergency department setting where a formal psychiatric diagnosis often is not made), who are at risk of or actively exhibiting aggressive behavior toward self, others, or property. | All other populations
Interventions | KQs 1a and 2a:; - Strategies (early intervention techniques) targeted to reduce the likelihood of aggressive behavior (examples provided in the PICOTS criteria); KQs 1b/1c and 2b/2c:; - Strategies targeted to decrease aggression for those who are actively aggressive (examples provided in the PICOTS criteria); KQ 3: Same as KQs 1 and 2 | All other interventions; - For medication-based interventions, those that are not FDA-approved for any indication
Comparators | KQs 1a and 2a:; - Other strategies (early intervention techniques), but not seclusion and restraints, targeted to reduce the likelihood of aggressive behavior, as described above for KQs 1a and 2a; - Usual care, defined as the standard of care for a particular setting before implementation of an intervention designed to decrease the likelihood of aggression and/or the use of seclusion and restraint; KQs 1b/1c and 2b/2c:; - Other strategies targeted to decrease aggression for those who are actively aggressive, as described above for KQs 1b/1c and 2b/2c; - Seclusion or restraint (for 1b and 2b only) (as defined in the PICOTS criteria); - Usual care, defined as the standard of care for a particular setting before implementation of an intervention designed to decrease aggression and/or the use of seclusion and restraint; KQ 3: Same as KQs 1 and 2 | All KQs:; - A study with no comparison group; - For medication-based strategies, placebo-only comparisons and those comparing different doses or routes of administration
Outcomes | KQs 1a, 1b, and 1c:; - Intermediate outcomes:; – Primary outcomes:; ○ Decreased aggression in terms of frequency, severity, or duration (as measured by direct counts or by validated aggression scales); ○ KQs 1a [underlined: and] 1c [underlined: only]: Reduced use of seclusion or restraints (decreased rate, amount, or duration); ○ To be eligible, each study must have reported on at least one of the outcomes above; – Secondary outcomes:; ○ As defined in the PICOTS criteria; - Final health outcomes:; – As defined in the PICOTS criteria; KQs 2a, 2b, and 2c: As defined in the PICOTS criteria KQ 3: Same as KQs 1 and 2 | None
Timing | All KQs: Imminently or within current episode of care (e.g., inpatient hospitalization, emergency department stay) | All KQs: Outside current episode of care
Settings | All KQs: Acute care settings, including emergency department or hospital (e.g., private or public psychiatric hospitals, general medical hospitals at which discharge occurs within 35 days of beginning treatment)^a^ | All KQs: Outpatient, community-based, jails, prisons, schools, chronic care, forensic-only,^b^ or long-term care settings
Study designs | All KQs:; - Systematic reviews, with or without meta-analyses; - Randomized controlled trials; - Nonrandomized controlled trials; - Cohorts (prospective and retrospective); - Case-control studies; - Single group pre/post studies (including pre/post studies with <3 pre- and <3 post-intervention time points)^c, d^; - Interrupted time-series designs (i.e., time-series studies with ≥3 pre-intervention and ≥3 post-intervention measurements with one or more groups)^c^ | All KQs:; - Case studies or series; - Cross-sectional studies; - Studies without a comparison group; - Nonsystematic review
Publications | All KQs: Original research | All KQs: Not original research (e.g., editorials without original data, newspaper articles)
Geographic locations | Developed countries (“very high” human development index per the United Nations Development Programme65) | All other countries
Language | English | All other languages

a Studies of settings that treated patients receiving both acute and chronic care were excluded. To be clear, a single unit or wing of a hospital could be eligible if inpatient stays were 35 days or less, even if other sections of the larger hospital provided longer-term care. We assumed that studies describing their sample's inpatient clinical services as “acute care” referred to discharge within 35 days of admission, when no specific information about lengths of stay was available. We attempted to locate information about the types of care provided in study-specific settings if there was concern that study analyses may have included a mixture of acute-care and chronic-care patients. When no information was available to confirm that a study's inpatient clinical services were acute care or that lengths of inpatient stays were 35 days or less, we excluded it.

b We excluded studies focusing only on forensic units or hospitals, but studies conducted in acute care settings were eligible if their samples included both forensic and nonforensic patients.

c A “group” could indicate a group of patients, acute care unit, or hospital evaluated before and after implementation of an intervention.

d We considered time-series studies with 2 pre-intervention and/or 2 post-intervention measurements as pre/post studies.

FDA = U.S. Food and Drug Administration; KQ = Key Question; PICOTS = populations, interventions, comparators, outcomes, timing, and settings.

Population(s)
- KQs 1 through 3
  – Adult individuals (ages 18 or older) with an identified psychiatric disorder, including substance use disorders and delirium (but not dementia), or with severe psychiatric symptomatology, who are at risk of or actively exhibiting active aggression toward self, others, or property.
    ○ We excluded mixed-age samples if data for adults were not reported separately.
    ○ We included studies that did not specify the age distributions of their samples when their measures of central tendency (e.g., mean or median ages) strongly suggested that only adults were included.

Interventions
- KQs 1a and 2a: Strategies (early intervention techniques) targeted to reduce the likelihood of active aggression, such as:
  – Supportive language and verbal de-escalation;
  – Milieu-based changes, such as sensory rooms or staffing changes (including increased staff-to-patient ratios), specific staff training programs (including psychoeducation about collaborating with patients to reduce risk of aggression), or peer-based interventions;
  – Adjustments to the primary psychotropic regimen for the purpose of decreasing agitation or preventing aggression; these approaches (adjustments) may include an increase in an antipsychotic or mood stabilizer that treats the underlying psychiatric disorder);
  – Any intervention, or combination of interventions, different from seclusion and restraints that is aimed at preventing aggressive behavior (e.g., implementation of a procedure informed by the Six Core Strategies of the National Association of State Mental Health Program Directors (NASMHPD).
- KQs 1b, 1c, 2b, and 2c: Strategies targeted to decrease aggression for those who are actively aggressive, such as:
  – Psychiatric Emergency Response Teams
  – Medication protocols to treat aggressive behavior that use on- or off-label medications approved by the US Food and Drug Administration (FDA),32 such as those described in project BETA (Best practices in Evaluation and Treatment of Agitation)
  – Any intervention, or combination of interventions, different from seclusion and restraints that is aimed at decreasing aggressive behavior (e.g., implementation of a procedure informed by NASMHPD's Six Core Strategies).
- KQ 3: Same as KQs 1 and 2.

Comparators
- KQs 1a and 2a:
  – Other strategies (early intervention techniques), but not seclusion and restraints, targeted to reduce the likelihood of active aggression, as described above for KQs 1a and 2a
  – Usual care, defined as the standard of care for a particular setting before implementation of an intervention designed to decrease the likelihood of active aggression and/or the use of seclusion and restraints
- KQs 1b, 1c, 2b, and 2c:
  – Other strategies targeted to decrease aggression for those who are actively aggressive, as described above for KQs 1b and 1c and for KQs 2b and 2c
  – Seclusion or restraints (for 1b and 2b only):
    ○ Seclusion (involuntary confinement where individual is physically prevented from leaving)
    ○ Restraints, whether physical (e.g., any manual method, physical or mechanical device, material, or equipment that immobilizes or reduces the ability of a patient to move freely) or chemical (e.g., a psychotropic drug or medication when it is used as a restriction to manage the patient's behavior)
  – Usual care, defined as the standard of care for a particular setting before implementation of an intervention designed to decrease aggression and/or the use of seclusion and restraints
- KQ 3: Same as KQs 1 and 2

Outcomes
- KQs 1a, 1b, and 1c (benefits):
  – Intermediate outcomes:
    ○ Primary outcomes:
      ▪ Decreased aggression in terms of frequency, severity, or duration (as measured by direct counts or by validated aggression scales)
      ▪ KQs 1a and 1c only: Reduced use of seclusion or restraints (decreased rate, amount, or duration)
      ▪ To be eligible, each study must have reported on at least one of these two primary outcomes
    ○ Secondary outcomes:
      ▪ For studies eligible for inclusion for primary outcomes, we also considered secondary outcomes, including: need for (and time to) additional sedation for patients presenting with violent and acute behavioral disturbances; need for additional security in response to violent and acute behavioral disturbances; number of patients sedated by emergency medication; psychiatric symptom severity scores (i.e., the Positive and Negative Symptom Scale, Total; the Clinical Global Impressions – Severity scale; the 5-item Acute-Agitation Cluster Score; and the Global Assessment of Functioning scale – Symptom score (GAF-S); medication-specific adverse events; incidence of delirium tremens in patients with alcohol withdrawal syndrome; and number of patients with alcohol withdrawal syndrome requiring transfer to an intensive care unit.
  – Final health outcomes:
    ○ improved quality of life, functioning, or patient experience
    ○ improved therapeutic relationship
    ○ decreased subsequent aggressive behavior
      ▪ decreased subsequent use of seclusion or restraints
      ▪ general resource use or costs
- KQs 2a, 2b, and 2c (harms): Patient injury or accidental death, staff injury, staff distress, patient distress (per self-report or clinical assessment); decreased adherence or engagement with treatment by patient; other side effects of interventions (e.g., medication side effects, such as excessive sedation, acute dystonia, and akathisia)
- KQ 3: Same as KQs 1 and 2

Timing
- KQs 1 through 3:
  – Imminently or within current episode of care (e.g., inpatient hospitalization, emergency department stay)

Setting
- KQs 1 through 3:
  – Acute care settings: emergency department or hospital (e.g., private or public psychiatric hospitals, general medical hospitals at which discharge occurs within 35 days of beginning treatment)
    ○ Studies of settings that treated patients receiving both acute and chronic care were excluded.
    ○ To be clear, a single unit or wing of a hospital could be eligible if inpatient stays were 35 days or less, even if other sections of the larger hospital provided longer-term care. We assumed that studies describing their sample's inpatient clinical services as “acute care” referred to discharge within 35 days of admission, when no specific information about lengths of stay was available. We attempted to locate information about the types of care provided in study-specific settings if there was concern that study analyses may have included a mixture of acute-care and chronic-care patients. When no information was available to confirm that a study's inpatient clinical services were acute care or that lengths of inpatient stays were 35 days or less, we excluded it.

In addition to the foregoing PICOTS, we considered the following other inclusion or exclusion criteria. Given concerns about risk of bias in observational and noncontrolled trials, and drawing from the experience of prior systematic reviews, we required a total sample size (or N) of 100 or more patients for any nonrandomized study after discussions with our Technical Expert Panel.

Study Design
- Systematic reviews, with or without meta-analyses
- Randomized controlled trials (RCTs), including cluster randomized trials
- Nonrandomized controlled trials (N ≥ 100)
- Cohort studies (prospective and retrospective, N ≥ 100)
- Case-control studies (N ≥ 100)
- Pre/post studies (N ≥ 100)
  – Note: A “group” could indicate a group of patients, acute care unit, or hospital evaluated before and after implementation of an intervention.
  – Note: We considered studies with 2 pre-intervention and/or 2 post-intervention measurements as pre/post studies.
  – Note: When the number of patients was not reported in a study we calculated it based on the number of beds, average length of stay and occupancy rate of the unit (if available).
    ○ Interrupted time-series designs (i.e., time-series studies with ≥3 pre-intervention and ≥3 post-intervention measurements with one or more groups and that reported an interrupted time series analysis)66 (N ≥ 100)
  – Note: A “group” could indicate a group of patients, acute care unit, or hospital evaluated before and after implementation of an intervention.

Geographic location
- Developed countries (“very high” human development index as defined by the United Nations Development Programme65)

Language
- English language only

### Study Selection

Two members of the research team independently reviewed all titles and abstracts (generated by searches) against our inclusion/exclusion criteria (Table 1). We retrieved any publications marked for inclusion by either reviewer for evaluation of the full text. For titles and abstracts that lacked adequate information to determine inclusion or exclusion, we retrieved the full text for review. Then, two investigators independently reviewed the full texts to determine final inclusion or exclusion. The reviewers resolved any disagreements by discussion and consensus or by consulting a third member of the review team.

We considered systematic reviews for eligibility by determining whether their inclusion/exclusion criteria for population, comparisons, outcomes, and settings met our own criteria. However, we did not identify any eligible systematic reviews.

All results in both review stages were tracked in an EndNote® database. We recorded the principal reason that each excluded full-text publication did not satisfy the eligibility criteria (Appendix B).

### Data Extraction

We designed, pilot-tested, and used a structured data abstraction form generated in AHRQ's Systematic Review Data Repository (http://srdr.ahrq.gov/) to ensure consistency of data abstraction. Trained reviewers initially abstracted data from each study. The data were then exported from Systematic Review Data Repository into a Microsoft® Excel spreadsheet, a senior reviewer then read each abstracted record and evaluated the completeness and accuracy of the data abstraction. We resolved discrepancies by consensus or by involving a third, senior reviewer.

We abstracted the following data from included trials and studies: study designs, eligibility criteria, population characteristics (such as age, sex, race, ethnicity), interventions, comparators, additional medications or interventions allowed, outcomes of interest and methods of outcome assessment, sample sizes, attrition, settings, geographic locations, and study funders. We recorded intention-to-treat results (i.e., all patients were analyzed as randomized with missing values imputed) if available. When eligible studies reported other data that were incomplete or missing, we contacted authors.

## Quality (Risk of Bias) Assessment of Individual Studies

To assess the risk of bias of trials and studies, we followed EPC methods guidance67 and rated the risk of bias for each relevant outcome as low, medium, or high. In general terms, results of a study with low risk of bias are considered to be valid. Medium risk of bias implies some confidence that the results represent true treatment effect. The study is susceptible to some bias, but the problems are not sufficient to invalidate the results (i.e., no flaw is likely to cause major bias). A study with high risk of bias has significant methodological flaws (e.g., stemming from serious errors in design or analysis) that may invalidate its results.

Ratings of risk of bias are not comparable across study designs. That is, a low-risk-of-bias nonrandomized study does not necessarily equal a low-risk-of-bias RCT. We considered the limitations of certain study designs when grading the strength of the evidence (explained below).

To determine risk of bias in a standardized way, we used the Cochrane Risk of Bias tool to appraise RCTs. We also used it to appraise the few cluster randomized trials (hereafter CRTs, where clusters were based on specific units in the facilities where the studies took place). Guidance for assessing risk of bias is similar for RCTs and CRTs68 but the latter may need special attention to issues such as recruitment bias, baseline imbalance, loss of clusters, and inadequate or incorrect analytic techniques, and we made an effort to consider these matters in reviewing eligible CRTs.

For nonrandomized trials and observational studies, we employed criteria from the RTI Risk of Bias Tool for Observational Studies.69 To minimize risk of bias in observational and noncontrolled studies addressing adverse outcomes (i.e., harms, a key focus of our report), we required a minimum total sample of 100 patients in nonrandomized studies (consistent with our work in prior reviews70). We did not assess risk of bias in noncontrolled or pre/post studies. The main reason is that the ability of these study designs to support causal inferences is very limited because of potential confounding from multiple sources that generally do not affect controlled studies as much (e.g., secular, time-based changes in outcomes of interest, selection bias, the influence of concurrent interventions, and attrition-related bias). We made an exception for single-group studies using an interrupted time-series design (i.e., using ≥3 pre-intervention measurements and ≥3 post-intervention measurements). That is, we included them in our assessments of risk of bias because their longitudinal assessment of outcomes before and after an intervention provided for a more specific evaluation of the intervention apart from secular, time-related changes, thereby reducing any related risk of bias. We reviewed each of these considerations with our Technical Expert Panel, who agreed with our approach.

Although no systematic review met our inclusion/exclusion criteria, we had intended to review eligible SRs that addressed any parts of our KQs and dually assess them for quality using a modified AMSTAR (Assessment of Multiple Systematic Reviews) instrument.71

Two independent reviewers assigned risk of bias ratings. Disagreements were resolved by discussion and consensus or by consulting a third, senior reviewer. Appendix C presents the risk of bias assessments of individual studies included in this review.

## Data Synthesis

We synthesized all literature qualitatively and included all eligible studies regardless of risk of bias. We stratified study data by whether they came from controlled studies (e.g., RCT, cohort studies) or noncontrolled studies (e.g., pre/post, interrupted time-series).

A study might report data relevant to both preventive measures (subquestion [a]) and actively aggressive measures (subquestion [b] or [c]). Data for study groups not restricted to highly aggressive patients (i.e., the denominator involved both aggressive and non-aggressive patients) were considered relevant for subquestion (a). Data for groups restricted to highly aggressive patients were considered relevant to subquestion (b) and/or (c).

To determine whether quantitative analyses (i.e., meta-analysis) were appropriate, we assessed the clinical and methodological heterogeneity of the studies under consideration following established guidance.72 After qualitatively assessing the PICOTS of included studies, looking for similarities and differences, we determined that our body of evidence was too heterogeneous to justify quantitative analyses.

We followed EPC guidance to assess publication bias for the final report.61 However, we did not find enough comparative evidence to warrant quantitative tests of publication bias, such as funnel plot asymmetry, the trim and fill method, or selection modeling.73

## Strength of the Body of Evidence

We graded the strength of evidence (SOE) for primary outcomes based on the guidance established by the EPC Program.69 Developed to grade the overall strength of a body of evidence, this approach incorporates five key domains: study limitations (study design and aggregate risk of bias), consistency, directness, precision, and reporting bias. For some scenarios, this approach also considers other optional domains that may be relevant: a dose-response association, plausible confounding that would decrease the observed effect, and strength of association (magnitude of effect). SOE receives one of four grades: high, moderate, low, or insufficient.

Grades reflect the strength of the body of evidence to answer KQs on the comparative benefits and harms of the interventions in this review. Table 2 defines the four SOE grades.69

Table 2 Definition of strength of evidence grades

Grade | Definition
High | We are very confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has few or no deficiencies. We believe that the findings are stable (i.e., another study would not change the conclusions).
Moderate | We are moderately confident that the estimate of effect lies close to the true effect for this outcome. The body of evidence has some deficiencies. We believe that the findings are likely to be stable, but some doubt remains.
Low | We have limited confidence that the estimate of effect lies close to the true effect for this outcome. The body of evidence has major or numerous deficiencies (or both). We believe that additional evidence is needed before concluding either that the findings are stable or that the estimate of effect is close to the true effect.
Insufficient | We have no evidence, we are unable to estimate an effect, or we have no confidence in the estimate of effect for this outcome. No evidence is available or the body of evidence has unacceptable deficiencies, precluding reaching a conclusion.

Source: Berkman et al., 2014^74^

In grading evidence from single trials or studies (typically regarded as insufficient evidence), we gave more weight to those in which the reported findings were precise and graded some as low SOE. Mirroring our decision not to assess the risk of bias of pre/post studies, we did not grade the SOE from such studies, as they cannot be used to draw causal inferences about comparative benefits and harms.

Two trained reviewers assessed each domain for each primary outcome; differences were resolved by consensus. One of the two reviewers was always a senior researcher with experience in grading SOE. Appendix D presents tables showing our assessments for each domain and the resulting SOE grades for KQ 1's primary outcomes (i.e., measures of aggressive behavior and use of seclusion and/or restraints) and for KQ 2's harms outcomes, organized by outcome category.

## Applicability

We assessed applicability of the evidence following guidance from the Methods Guide for Effectiveness and Comparative Effectiveness Reviews.75 We used the PICOTS framework to explore factors that affect applicability. Some factors identified a priori that may limit the applicability of evidence include the following: age of enrolled populations, sex of enrolled populations (e.g., fewer men may be enrolled in some studies), race or ethnicity of enrolled populations, diagnoses of involved sample, and location of and staffing for specific interventions.

## Peer Review and Public Commentary

This report was posted for public comment and peer review. We addressed all comments in the final report, making revisions as needed. A disposition of comments report will be publicly posted 3 months after release of the final report.