# Introduction

## Background

### Aggressive Behavior

Aggressive behavior connotes using actual physical violence toward self, others, or property or making specific imminent verbal threats.1 In health care setting, approaches for actively aggressive patients have historically involved using either seclusion (involuntary placement of a patient in a locked room or area from which the patient is not allowed to leave) or restraints (involuntary administration of mechanical, pharmacologic, or physical interventions, which is seen as more restrictive than seclusion); these practices continue today.2,3 Since the late 1990s, the Centers for Medicaid & Medicare Services (CMS, formerly the Health Care Financing Administration [HCFA]3) and the Joint Commission4 (an accrediting body that evaluates health care organizations with performance standards) have required that seclusion and restraints must be used only for a behavior that “jeopardizes the immediate physical safety of the patient, a staff member, or others”5 (including other patients) and when less restrictive measures have failed. Despite practice guidelines advocating limitations of seclusion or restraints as much as possible,6 data in the United States and Europe show that 10 percent to 30 percent of patients (adolescents, adults and to elderly) admitted to acute psychiatric units receive these interventions.7-9

Deciding to use seclusion or restraints raises several significant clinical or policy issues. First is how to best balance the benefits and risks of seclusion or restraints with those of various alternatives to those practices.7 Benefits of seclusion and restraints can include reduced physical risk to the patient, other patients, and staff; quick reduction of aggressive behaviors; and increased likelihood of receiving effective treatment for the psychiatric disorder (if the aggression is preventing proper treatment). Potential harms to patients include increased physical harm to the patient, such as severe and even fatal side effects,10 with estimates of 50 to 150 seclusion- or restraint-related deaths annually.11 Others may face the risk of various harms as well: e.g., other patients or even staff may experience assault. Yet other possible harms may involve punishment (perceived or real) of patients; loss of dignity; re-traumatization of patients; new traumatic effects of such coercion; and future aversion to returning to the hospital even if a patient is in great need (e.g., is suicidal).

Second, whether an evidence base even exists to support using seclusion or restraints is debatable.7,12-15 Third, usual care (often represented in comparative studies as whatever was done before a new intervention was tried) varies substantially. Given the considerable potential harms and the availability of alternative strategies (briefly described below), most guidelines and standards from regulatory agencies and accrediting bodies now recommend using seclusion and restraints only as a last resort.16-24

Finally, using seclusion and restraints is closely followed as a quality-of-care measure, particularly for psychiatric patients in hospital settings.25 Various organizations have defined quality care as the lowest possible use of seclusion and restraint, making it important to understand what evidence base exists in support of this definition.26 The Joint Commission collects publically available, comparative data on patient hours of seclusion and restraints for acute care hospitals that offer hospital-based inpatient psychiatric services (HBIPS-2, HBIPS-3); it also includes time in seclusion or in restraints as part of its inpatient psychiatric services core measure for accreditation.27 In 2010, the organization reported more than 200 deaths related to seclusion or restraints over a prior 5-year period.28

In addition, some state psychiatric hospital systems have undertaken comprehensive efforts to reduce use of seclusion and restraints and collected data on their progress. For example, in Pennsylvania from 1990 to 2000, rates of seclusion decreased from 4.2 to 0.3 episodes per 1,000 patient days, and rates of restraints decreased from 3.5 to 1.2.^29^ The authors cited many factors contributing to the change, including advocacy, policy change, staffing ratios, response teams, and second-generation antipsychotics. The federal government also gives this issue high priority—the Substance Abuse and Mental Health Services Administration, for one, makes consistent and active efforts to reduce and ultimately abolish the use of seclusion and restraints.30,31

### Treatment Strategies

Much interest now focuses on using alternatives to seclusion and restraints. These strategies can address preventing aggressive behavior or reducing aggressive behavior once it has already developed (or both). Most of these alternatives are strongly influenced by the National Association of State Mental Health Program Directors' Six Core Strategies.32 These principles are (1) leadership toward organization change, (2) use of data to inform change, (3) workforce development (strongly influenced by the principles of trauma-informed care),33 (4) use of seclusion and restraint prevention tools, (5) consumer roles in inpatient settings, and (6) debriefing techniques. Such approaches appear to be comprehensive, noninvasive, and low risk; they offer promising results.34

These Six Core Strategies ultimately aim to forestall or at least decrease aggressive behavior. Strategies to prevent aggressive behavior can involve general, multicomponent strategies (applied to a whole group, usually via policy) or specific strategies (applied to specific individuals who are at especially high risk of becoming aggressive). Use of these two preventive approaches can overlap; specific strategies may also be applied as a general approach on a unit-wide basis. Other approaches aim to de-escalate or manage aggressive behavior once it has already developed.

Preventing aggressive behavior (general strategies): The vast majority of patients who are admitted to an acute care health setting because of a psychiatric illness or are being treated in an emergency department because of severe psychiatric symptomatology are at some increased risk of aggression relative to the general population. Preventive strategies to reduce the likelihood that such patients might become acutely aggressive focus on providing a calm environment in which aggression is less likely to develop.

Such approaches tend to focus on entire care units. They include the following: risk assessment, milieu-based changes such as sensory rooms, which provide a calm and supportive environment for patients;35 staffing changes, such as increased staff-to-patient ratios;19 specific staff training programs;36 and peer-based interventions.37 For example, one program introduced a 12-hour staff training program focused on previously identified barriers to reducing the use of seclusion or restraints.36 These barriers for the staff included fear, prejudices, hopelessness, and negative attitudes. The focus of the peer-based intervention was to build trust and confidence in the patient and engage the patient on a mutual level.37 The strengths of such approaches are that they are collaborative and pose only a low risk to patients and staff.38 They also can help address the risk in groups that are harder to identify as being at risk of acute aggression—those who isolate themselves and withdraw from the unit environment (milieu).39

Preventing aggressive behavior (specific strategies): Agitation, commonly although not always, precedes aggression. Thus, specific strategies to prevent aggression often try to intercede at the point of agitation. If a patient becomes agitated (reflected in behaviors such as pacing, yelling, or making verbal threats or threatening gestures toward others), the patient is generally thought to be at increased risk of aggressive behavior, including physical violence. For agitated patients, the goal of an intervention is to decrease that agitation to prevent aggressive behavior.

Early agitation often resolves with supportive (often referred to as nonconfrontational) language and other verbal de-escalation techniques to help diffuse the interpersonal interaction. The use of restrictive interventions, such as restraints, at this early stage may only further escalate the situation.19 More serious agitation may require cognitive behavioral techniques aimed at helping the patient manage his or her emotions and distress, so as to regain control of behavior. Such aggression prevention approaches40 form the basis of guidelines for managing agitated patients in different settings.41-45

Pharmacologic intervention treating the underlying psychiatric illness is also a common specific strategy for preventing aggressive behavior. A case in point might be increasing the dose or adding an as-needed dose of an antipsychotic medication for a patient with a history of aggression and schizophrenia; the aim is to decrease current reactivity and impulsivity and, thereby, reduce the risk for current aggression. When successful, such medication-based steps can help prevent aggression.45

Furthermore, recognition of triggers for aggressive behavior can inform prevention strategies by identifying individualized patterns that can be addressed. For example, certain sensory stimuli, such as excessive noise, can trigger aggression in some patients. This problem could theoretically be addressed by offering ear plugs or headphones to those individuals. Similarly, paranoid patients may benefit from having only prepackaged foods on their meal tray to decrease agitation related to concerns about poisoning.

Managing acute aggression: If patients do become actively aggressive (i.e., exhibiting actual physical violence toward property, self, or others, or making specific imminent verbal threats), clinicians can use either seclusion or restraints or alternative strategies. In such cases, alternatives can include Emergency Response Teams; these encompass Behavioral Emergency Response Teams,46 Rapid Response Teams,46 and Psychiatric Emergency Response Teams.47

In addition, clinicians can employ pharmacologic interventions to reduce agitation quickly, rather than more gradually treating the underlying illness. These include, for example, the medication protocols described in the emergency department-focused Project BETA (Best Practices in Evaluation and Treatment of Agitation).48 These involve medications approved by the U.S. Food and Drug Administration (FDA) whose indications specifically include use for agitation in adults (olanzapine, ziprasidone, aripiprazole, and inhaled loxapine).49-52 Pharmacologic agents can also include those that do not have formal FDA approval for these specific purposes (e.g., haloperidol, risperidone, and lorazepam).

## Scope and Key Questions

### Scope of the Review

This small systematic review addresses interventions to prevent or de-escalate aggressive behavior and to reduce the use of seclusion and restraint for aggressive behaviors. Behaviors indicating the potential need for these types of interventions occur in both acute care settings (such as public and private mental hospitals, state mental hospitals, emergency departments, Veterans Affairs hospitals, and medical or surgical units in general hospitals) and chronic care settings (such as nursing homes and psychiatric residential treatment facilities).24 Although psychotic disorders account for 44 percent of individuals requiring seclusion or restraint (or both), multiple psychiatric diagnoses, including substance misuse and delirium, are associated with aggression in health care settings.24,47,53 In addition, in some acute care settings (e.g., the emergency department) the psychiatric diagnosis may not yet be clear or patients may not have been formally diagnosed; treatment decisions are then often based on the presence of psychiatric symptoms including aggressive behaviors.

Although dementia is frequently associated with aggression and the use of seclusion and restraints,54 individuals with dementia are often managed in chronic care settings; a separate report is covering this evidence.55 Thus, our review focuses on adults in acute care settings. We include in the review studies of inpatients with any psychiatric diagnosis, including delirium and substance misuse (but not dementia), and patients in emergency departments with severe psychiatric symptomatology.

To our knowledge, no systematic review focusing on acute care settings has directly compared either (1) the effectiveness of different available alternative strategies to prevent aggressive behavior or (2) the effectiveness of alternative strategies compared with each other or with seclusion and restraints to de-escalate aggressive behaviors or improve health outcomes for those who are acutely aggressive. Existing systematic reviews of pharmacological de-escalation strategies often include placebo-controlled studies, focus only on a small subset of our eligible population, and are rarely limited to the acute care setting.

This review focuses on the comparative effectiveness of strategies to de-escalate aggressive behavior in psychiatric patients in acute care settings. In this case, we conceptualize “de-escalate” in terms of both preventing aggressive behaviors and reducing use of seclusion and restraints. We do not assess the accuracy of available risk assessment tools (a crucial step in the process of reducing aggressive behavior) or consider chronic care settings; although these are important considerations, they are beyond the scope of this review.

Based on our preliminary literature search and input from key informants, we appreciate that risk assessment is a crucial step in the process of reducing aggressive behavior and the potential use of seclusion and restraints for psychiatric patients. We understand that a practical need exists to assess the accuracy of available risk assessment tools. Similarly, we appreciate that seclusion and restraints are applied across a span of settings, including chronic care settings such as skilled nursing facilities and psychiatric residential treatment facilities. Nevertheless, risk assessment and consideration of chronic care settings are beyond the immediate scope of this comparative effectiveness review (CER); thus, we do not specifically address such topics or settings in this report.

### Key Questions (KQ)

KQ 1: Regarding benefits for adult psychiatric patients in acute care settings:

a. For those without active aggression, what are the comparative benefits of strategies to prevent aggressive behavior?
b. For those with active aggression, what are the comparative benefits of strategies, including seclusion and restraints, to de-escalate aggressive behavior?
c. For those with active aggression, what are the comparative benefits of strategies to reduce the use of seclusion and restraints?

KQ 2: Regarding harms for adult psychiatric patients in acute care settings:

a. For those without active aggression, what are the comparative harms of strategies to prevent aggressive behavior?
b. For those with active aggression, what are the comparative harms of strategies, including seclusion and restraints, to de-escalate aggressive behavior?
c. For those with active aggression, what are the comparative harms of strategies to reduce the use of seclusion and restraints?

KQ 3: What characteristics of patients (including age, sex or gender, diagnosis, motivation to receive treatment), of intervention components, or of acute care settings modify the benefits or harms of interventions for psychiatric patients at risk of, or presenting with, active aggression?

For the three KQs in this review, we define aggressive behavior as making specific imminent verbal threats or using actual physical violence toward self, others, or property. As discussed above, we focus on patients with any psychiatric diagnosis per the Diagnostic and Statistical Manual of Mental Disorders, Third Edition-Revised, Fourth Edition, or Fifth Edition (DSM-III-R, DSM-IV, or DSM-5).56-58 Diagnostic categories include delirium and substance misuse (but not dementia); additionally, for patients in emergency departments, we include displaying severe psychiatric symptomatology. We view effectiveness in terms of both benefits and harms, so we frame our questions to address each class of outcomes.

We envision a continuum of risk and behavior, so the KQs cover a range of patients. This spectrum can include patients with these disorders who may be at risk of aggressive behavior (i.e., are not actively aggressive), in which case interventions are preventive. It can also include those who are exhibiting aggressive behaviors (i.e., are actively aggressive), in which case interventions are directly active. Interventions can occur at any point along this continuum, and they can involve a wide variety of strategies that can have educational, behavioral, emotional, organizational, environmental, and/or pharmacologic components. The interventions must target a reduction either in aggressive behavior or in use of seclusion and restraints.

For these KQs, we define and classify interventions to reflect either prevention or direct intercession. A preventive intervention is one applied to a group of individuals not wholly identified as being actively aggressive; i.e., some patients may not be actively aggressive but others may be. It can involve unit- or hospital-wide policies that address all patients on a unit, not just those who are actively aggressive. It can also involve patients identified as being at an increased risk of becoming aggressive (e.g., were assessed as being agitated) but who were not yet actively aggressive.

KQ 1 (benefits) and KQ 2 (harms) address such preventive interventions in these groups in their subquestion (a). KQs 1 and 2, in their subquestions (b) and (c), examine interventions targeted specifically to de-escalate aggressive behavior among actively aggressive patients. KQ 3 addresses specific patient, intervention, or setting factors that may modify benefits or harms of various strategies.

Our two primary comparative outcome benefits, which are intermediate outcomes, are a decrease in (1) aggressive behaviors and (2) use of seclusion and restraints. For patients who are not acutely aggressive (i.e., not threatening the immediate physical safety of themselves, the staff, or others), use of seclusion and restraints is not allowed under current regulatory statutes.59 Here, the potential outcomes include a reduction in aggressive behaviors or in the eventual use of seclusion and restraints (or both). However, for those who are actively aggressive, use of seclusion and restraints may be an option; in comparative studies where seclusion and restraints are used, reduction in aggressive behaviors is the primary benefit outcome.

We also look at longer term or final health outcomes. These include improved quality of life, functioning, or patient experience; improved therapeutic relationship; and decreased subsequent aggressive behavior. In addition, we consider general resource use or costs. Although measures such as staff turnover or the sustainability of interventions are also important, our scope did not allow us to address these issues in this report.

Because of safety concerns in relation to aggressive behavior, our harms outcomes, addressed in KQ2, are more inclusive. Also, we note that harms to staff members or to patients can come from the use of seclusion or restraints as well as the failure to use seclusion or restraints. Any comparison study we examine must account for this complexity.

Acute health care settings are defined as public and private mental hospitals, acute care units at state mental hospitals, acute care components of Veterans Health Administration (VA) hospitals, medical or surgical units in general hospitals, and emergency departments. In all cases, patient discharges occur within 35 days of beginning treatment.60 Stays longer than 35 days would indicate a chronic care setting.

We present our analytic framework that guided this review (Figure 1); it identifies specific KQs.

Figure 1 Analytic framework for comparative effectiveness of strategies to de-escalate aggressive behavior in psychiatric patients

KQ = Key Question; QOL = Quality of Life; S/R = Seclusion or Restraint

^a^ Usual care is defined as the standard of care for a particular setting before implementation of an intervention designed to further decrease aggression and/or the use of seclusion and restraints

This figure depicts the key questions within the context of the PICOTS described in a subsequent section. The framework goes from left to right, beginning on the left side with the population of interest (individuals with psychiatric disorder or severe psychiatric symptomatology in acute health care settings) and an arrow on the right leading into the main body of the framework. As shown in the upper branch of the framework, Preventive Strategies (KQ1a) can be applied to prevent individuals identified as being at risk of aggressive behavior from becoming actively aggressive, and also to reduce the need for use of seclusion or restraints. These strategies may also affect final health outcomes (such as quality of life, patient experience, therapeutic relationship, subsequent aggressive behavior, and subsequent use of seclusion or restraints), as well as general resource usage or costs. KQ2a addresses potential adverse events that can result from Preventive Strategies (such as patient or staff injury, accidental death, patient psychological trauma, decreased adherence). The lower branch of the framework depicts management strategies for patients presenting with active aggression, with the goals of de-escalating aggressive behavior (KQ 1b) and reducing the use of seclusion or restraints for de-escalating such behavior (KQ1c). Specifically, KQ1b considers how alternative strategies to seclusion or restraints compare with other alternatives, use of seclusion or restraint themselves, or usual care for decreasing aggressive behavior (an intermediate outcome) and for improving final health outcomes (such as quality of life, patient experience, therapeutic relationship, subsequent aggressive behavior, and subsequent use of seclusion or restraints), as well as general resource usage or costs. KQ2b addresses the potential for adverse events (e.g., injury, accidental death, patient psychological trauma, decreased adherence) following the use of de-escalation strategies meant to reduce active aggression. Similarly, KQ1c focuses on how alternative de-escalation strategies to seclusion or restraints compare with other alternatives or usual care for reducing the use of seclusion or restraints, as well as aggressive behavior and the same final health just described for KQ1b. KQ2c addresses the potential for the same adverse events described for KQ1b. For both individuals presenting and those not presenting with aggressive behavior, KQ3 aims to identify the characteristics of patients (including age, gender, diagnosis, and cognitive impairment), intervention components, or settings that modify the benefits or harms of the previously described strategies.