# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Les Citrome, M.D., M.P.H.•
  • This member of the Technical Expert Panel also reviewed and commented on the draft report.
  New York Medical College
  Valhalla, NY
- Lisa Dixon, M.D., M.P.H.•
  New York State Psychiatric Institute
  New York, NY
- Joan Gillece, Ph.D.
  National Association of State Mental Health Program
  Directors and Substance Abuse and Mental Health Services Administration
  Alexandria, VA
- Kim J. Masters, M.D.^*^•
  * Also represented the American Psychiatric Association
  Three Rivers Residential Treatment
  Midlands Campus
  Columbia, SC
- Michael Rice, PhD, APN, FAAN •
  University of Colorado College of Nursing
  Anschutz Medical Center
  Aurora, CO
- Eric Schmidt, Ph.D.•
  Stanford University
  Stanford, CA
- Jennifer P. Wisdom, Ph.D., M.P.H.
  George Washington University
  Washington, DC