# Key Informants

In designing the study questions, the EPC consulted several Key Informants who represent the end-users of research. The EPC sought the Key Informant input on the priority areas for research and synthesis. Key Informants are not involved in the analysis of the evidence or the writing of the report. Therefore, in the end, study questions, design, methodological approaches, and/or conclusions do not necessarily represent the views of individual Key Informants.

Key Informants must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their role as end-users, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any conflicts of interest.

The list of Key Informants who provided input to this report follows:

- Les Citrome, M.D., M.P.H.•
  • This Key Informant also reviewed and commented on the draft report.
  New York Medical College
  Valhalla, NY
- Sarah Desmarais, Ph.D.
  North Carolina State University
  Raleigh, NC
- Ken Duckworth, M.D.
  National Alliance on Mental Illness
  Cambridge, MA
- Susan Hardesty, M.D.^*^
  * Also represented the American Psychiatric Association
  The Menninger Clinic
  Houston, TX
- Don Howard, M.S.W.
  Centers for Medicare and Medicaid Services
  Baltimore, MD
- Larke N. Huang, Ph.D.
  Substance Abuse and Mental Health Services Administration
  Rockville, MD
- Janice LeBel, E.D., Ph.D.
  Massachusetts Department of Mental Health
  Boston, MA
- Kathleen McCann, R.N., Ph.D.•
  National Association of Psychiatric Health Systems
  Washington, DC
- Michael Rice, PhD, APN, FAAN•
  University of Colorado College of Nursing
  Anschutz Medical Center
  Aurora, CO
- Joyce B. Wale, L.C.S.W.
  UnitedHealthcare Community Plan NY
  New York, NY