# Acknowledgments

The authors gratefully acknowledge the continuing support of our AHRQ Task Order Officer, Suchitra Iyer, Ph.D., to this project. We thank our Associate Editor, Mark Helfand, M.D., M.S., M.P.H., for his helpful comments on a draft version of the report.

The authors gratefully acknowledge the following RTI-UNC EPC staff for their contributions to this project and deeply appreciate their considerable support and commitment: Loraine Monroe, our publications specialist; Sharon Barrell, M.A., our editor; Claire Baker, who provided assistance retrieving publications and with manually searching reference lists of pertinent reviews; Charli Randolph, B.A., who provided assistance with preparing our Appendices; Catherine A. Grodensky, M.P.H., who helped record Key Informant discussion notes during the project's Topic Refinement phase; and Lynn Whitener, Dr.P.H., M.S.L.S. who provided library services.

Additionally, the authors gratefully acknowledge and deeply appreciate the contributions of Atlas Research staff during the process of abstracting data from this project's eligible studies. We express our gratitude to the following individuals: Reva Stidd, M.S., M.B.A., the primary data abstractor at Atlas; Jason Ormsby, Ph.D., M.B.A., M.H.S.A., who assisted Ms. Stidd with data abstractions; and Abby Friedman, the Atlas project manager.