# Discussion

Our review aims to address two gaps in the available literature involving the effectiveness of strategies to de-escalate aggressive behavior. We synthesized available data about (1) the effectiveness of different alternative strategies to prevent aggressive behavior and (2) the effectiveness of alternative strategies compared with each other or with seclusion and restraints to de-escalate aggressive behaviors or improve health outcomes for those who are acutely aggressive.

This chapter summarizes key findings and how they relate to published findings and current clinical practices and policies. We also briefly examine the applicability of our findings and their implications for decisionmaking. We comment on limitations of both the review process and the entire evidence base as a segue into our discussion of research gaps in this field.

## Key Findings and Strength of Evidence

Identifying and implementing effective strategies to de-escalate aggressive behaviors in acute care and emergency department settings is a key concern for patients, clinicians and policymakers. The emphasis is on safe and effective means of limiting the use of seclusion and restraints. Alternative strategies include staff training, risk assessment, multimodal interventions (which include multiple components that may be part of other strategies), environmental interventions (including group psychotherapeutic options), and use of medications. Our report provides a comprehensive summary of the available evidence on the comparative benefits and harms of alternatives to seclusion and restraints versus each other and versus the use of seclusion and restraints.

In this review, we focus on three key issues that decisionmakers commonly face:

1. What is the comparative effectiveness of general strategies that can be applied unit-wide to prevent aggressive behavior?
2. Once patients are actively aggressive, what is the comparative effectiveness of strategies, including the use of seclusion and restraints, to de-escalate aggressive behavior?
3. Once patients are actively aggressive, what is the comparative effectiveness of strategies to reduce the use of seclusion and restraints?

Overall, the evidence base is extremely limited. What evidence was available came largely from pre/post studies. Their inherent high risk of bias precludes drawing inferences of causality (and so we did not grade strength of evidence [SOE] for such studies), but we note the existence of these studies in the text below.

No Key Questions (KQs) had data supporting a SOE grade that exceeded low SOE (based on criteria as described in the Evidence-based Practice [EPC] Methods Guide).74 Although 15 of 29 studies involved acute inpatient psychiatric settings, most of which involved serious mental illness diagnoses, the majority of articles did not give the proportion of patients with agitated or aggressive behavior. Consequently, we are not able to describe clinical demographics.

We focus here on the 11 studies (mainly randomized controlled trials [RCTs] or cluster randomized trials [CRTs]) for which we could grade SOE of one or more outcomes. Of these, three were CRTs (for KQ 1. We rated all as medium risk of bias, most commonly because of failure to control either for potential confounding or for intraclass correlations in the CRTs that were eligible for inclusion. No KQs had comparative data supporting an SOE grade that exceeded low strength of evidence. By definition, all findings were of unknown inconsistency (because they were single studies), but all provided direct evidence. In most cases, however, the data reported were imprecise. Thus, we graded these findings as insufficient SOE. In a very small number of cases in which data were precise, we graded SOE as low.

The tables below summarize only those findings with low SOE and those outcomes with eligible studies but with an SOE grade of insufficient. The variety of measures used to assess aggressive behavior and seclusion and restraint use prevented quantitative synthesis of the meager data that were available.

Most evidence addressed preventive, unit-wide programs rather than interventions specifically targeting actively aggressive patients; this focus essentially represents the core difference between the CRTs and the RCTs. Moreover, these analyses could involve samples of patients who were not actively aggressive as well as those who were. These factors prevented us from attributing reduction of aggressive behavior in actively aggressive patients to any particular intervention.

Furthermore, the inexact description of many interventions made it difficult to attribute a change to a particular component. For example, multimodal interventions had components of risk assessment and staff training, and distinguishing between them was sometimes challenging.

We report on our findings, by benefits and harms for each subquestion (e.g., KQs 1a and 2a) together, organized by intervention and specific outcomes. We also summarize our SOE findings for each subquestion in accompanying tables. If an eligible study provided relevant data, but we graded SOE as insufficient, we note this in the text and the table. If no eligible studies provided relevant data, we graded the SOE as insufficient and mention it in the text but not in the table.

As noted earlier, some SOE grades for KQ 1 were low (when we could assign a grade other than insufficient). Findings from eligible studies for KQ 2 were all insufficient. We had no studies for KQ 3.

Table 13 documents benefits and harms for risk assessment and staff training for preventing aggressive behaviors (KQs 1a and 2a); Table 14 documents benefits and harms of medication protocols for decreasing aggressive behaviors (KQs 1b and 2b); and Table 15 documents benefits and harms of medication protocols for reducing seclusion or restraints (KQs 1c and 2c).

The low confidence in these SOE grades (very few low grades; mainly insufficient grades that are not included in these tables because we had no relevant studies) reflects a critical limitation of the reviewed research. This pattern also calls into question both the reproducibility or replicability and the generalizability of results. Subsequent studies, assuming they are well designed and take statistical issues accurately into account, are likely to affect these findings substantially, although in what direction remains unclear. Future research, with the same assumptions, may confirm some findings but provide more information that might lead to higher SOE grades.

### Strategies To Prevent Aggressive Behavior: Benefits (KQ 1a) and Harms (KQ 2a)

Two of the interventions had eligible studies, only one of which (risk protocol assessment) led primarily to low SOE findings (Table 14). For units implementing structured risk assessment protocols, which matches needs to identified risks to reduce the likelihood of aggressive behavior, we graded the SOE as low that these protocols produced fewer aggressive incidents and a reduction in the use of seclusion and restraints compared with usual care. This low SOE rating was attributable, in the main, to a small number of trials; other issues involved diverse operationalizations of key concepts across studies, which precluded direct comparisons; and the failure of analyses of the CRTs to account for intra-class correlations.107 We identified no data addressing the harms of such an intervention (so the SOE rating of insufficient).

Table 14 Summary of findings with strength of evidence grades: Comparative benefits and harms of two strategies for preventing aggressive behavior^a^ (KQs 1a and 2a)

Intervention and Comparison | Primary Outcome of Interest | Outcome N of Patients Analyzed | Strength of Evidence | Supporting Judgment | Findings and Direction of Effect
Staff training vs. usual care | Change in aggressive behavior | Aggressive behavior resulting in staff injury NR | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | Fewer assaults on staff occurred in unit that received the staff training vs. the control unit (4 vs. 5); no statistical testing reported.103
Staff training vs. usual care | Change in seclusion or restraint | Incidents of seclusion or restraint NR | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | Fewer incidents of seclusion or restraint on the unit that received the training vs. the control unit (84 vs. 228); no statistical testing reported.103
Staff training vs. usual care | Staff distress | Change in staff resignations and transfers NR | Insufficient | High risk of bias, consistency unknown—single study, indirect, imprecise | Fewer staff resignations and transfers in unit that received the staff training than in control unit (4 vs. 9), no statistical testing reported.103
Staff training vs. usual care | Staff distress | Change in staff sick leave NR | Insufficient | High risk of bias, consistency unknown—single study, indirect, imprecise | Greater percentage decrease in number of sick leave hours in unit that received the staff training than in control unit (-28.2% vs. +7.7%), no statistical testing reported.103
Staff training vs. usual care | Patient distress | Change in patients' rights complaints NR | Insufficient | High risk of bias, consistency unknown—single study, indirect, imprecise | Fewer patients' rights complaints occurred in unit that received the staff training than in control unit (from 6 to 2 vs. from 1 to 4), no statistical testing reported.103
Risk assessment vs. usual care | Change in aggressive behavior | Number of aggressive patients 170 during baseline period, 458 during intervention period | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Nonsignificant 50% RR reduction with risk assessment.87
Risk assessment vs. usual care | Change in aggressive behavior | Aggressive incidents 170 during baseline period, 458 during intervention period | Low | Medium risk of bias, consistency unknown—single study, direct, precise | Significant 68% RR reduction with risk assessment, p<0.0001 reported; failure to control for intraclass correlations weakens the finding.87
Risk assessment vs. usual care | Change in aggressive behavior | Rate of severe aggressive incidents 973 post-intervention | Low | Medium risk of bias, consistency unknown—single study, direct, precise | Significantly lower risk with structured risk assessment: (RR, 0.59; 95% CI, 0.41 to 0.83) p<0.001 reported; failure to control for intraclass correlations weakens the finding. Decrease achieved since baseline with risk assessment (-41%) vs. usual care (-15%), no statistical testing reported.78
Risk assessment vs. usual care | Change in seclusion or restraint | Change in physical attacks 973 post-intervention | Low | Medium risk of bias, consistency unknown—single study, direct, precise | Significantly greater decrease with risk assessment (-41%) vs. usual care (-7%), p<0.001 reported, failure to control for intraclass correlations weakens the finding.78
Risk assessment vs. usual care | Change in seclusion or restraint | Secluded patients 170 during baseline period, 458 during intervention period | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Nonsignificant 8% RR increase with risk assessment.87
Risk assessment vs. usual care | Change in seclusion or restraint | Seclusion incidents 170 during baseline period, 458 during intervention period | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Nonsignificant 15% RR reduction with risk assessment.87
Risk assessment vs. usual care | Change in seclusion or restraint | Hours in seclusion 170 during baseline period, 458 during intervention period | Low | Medium risk of bias, consistency unknown—single study, direct, precise | Significant 45% RR reduction with risk assessment, p<0.0001 reported; failure to control for intraclass correlations weakens the finding.87
Risk assessment vs. usual care | Change in seclusion or restraint | Change in coercive^b^ incidents 973 post-intervention | Low | Medium risk of bias, consistency unknown—single study, indirect, precise | Significant decrease from baseline with risk assessment (-27%) vs. usual care (+10%), p<0.001 reported; failure to control for intraclass correlations weakens the finding.78

a For KQ 1a, we had no studies of eligible study design for environmental or group psychotherapeutic interventions or multimodal interventions; thus, we could not rate risk of bias.

b Coercive measures covered a wide range of measures from forced injection of psychotropic medication to seclusion and mechanical restraint.78

CI = confidence interval; KQ = Key Question; N = number; NR = not reported; RR = relative risk; vs. = versus.

For staff training, for environmental interventions, and for medication use, we graded the evidence base addressing benefits and harms as insufficient. We identified no controlled trials or interrupted time-series studies to provide data for an SOE rating for either question.

### Strategies To Address Aggressive Behavior: Benefits (KQ 1b) and Harms (KQ 2b)

We identified no eligible studies for strategies involving staff training, risk assessment interventions, multimodal interventions, or environmental interventions. As a result, we rated all these strategies as having insufficient SOE for both benefit and harms. Although some of these strategies may have been applied to actively aggressive patients, reported data did not stratify by whether the outcomes happened specifically in the aggressive subgroup; rather, the data were reported for the group involving both those actively aggressive and those not, so we could not determine the effect specifically on the aggressive subgroup.

The interventions to address the comparative effectiveness of strategies to de-escalate aggressive behavior focused on medications. These studies provided the only direct comparisons of two active strategies (rather than with usual care). Here, too, the evidence was limited. For both benefits and harms, we graded SOE as insufficient for each comparison assessing whether any specific medication or programmatic approach involving the timing of medication use emerged as a superior method for de-escalating aggressive behavior (Table 15). All comparisons occurred in single trials only, and the metric used to assess aggressive behavior differed across studies. All studies assessing benefits were underpowered to test noninferiority, and those studies reporting harms reported small numbers of events, preventing any statistical comparisons.

Table 15 Summary of findings with strength of evidence grades: Comparative benefits and harms of medication protocols for de-escalating aggressive behavior (KQs 1b and 2b)

Intervention and Comparison | Primary Outcome of Interest | Outcome N of Patients Analyzed | Strength of Evidence | Supporting Judgment | Findings and Direction of Effect
Medication protocols vs. other medication protocols: Benefits | Change in aggressive behavior | Aggression response rate 28 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Nonsignificant difference in rates of OAS score reduction at 90 minutes in haloperidol vs. flunitrazepam (92% vs. 80%).82
Medication protocols vs. other medication protocols: Benefits | Change in aggressive behavior | Duration of aggression 91 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Nonsignificant difference in the median duration of violent and acute behavioral disturbances with droperidol vs. midazolam vs. a combination of droperidol plus midazolam (20 vs. 24 vs. 25 minutes).77
Medication protocols vs. other medication protocols: Benefits | Change in aggressive behavior | Clinically significant change in OAS scores 20 | Insufficient | Low risk of bias, consistency unknown—single study, direct, imprecise | Significantly greater likelihood of improvement (decrease of four or more points) in OAS scores of aggressive or agitated behavior at 60 minutes with the combination of haloperidol plus lorazepam (100%) vs. lorazepam alone (55%), p=0.03 (note small sample size).98
Medication protocols vs. other medication protocols: Benefits | Change in aggressive behavior | Time to OAS improvement 20 | Insufficient | Low risk of bias, consistency unknown—single study, direct, imprecise | Significantly shorter time to OAS improvement with the combination of haloperidol plus lorazepam vs. lorazepam alone, data NR, p=0.028 (note small sample size).98
Medication protocols vs. other medication protocols: Benefits | Change in aggressive behavior | Sedation score at 5, 10, 15, 30, and 60 minutes 202 | Insufficient | High risk of bias, consistency unknown—single study, direct, precise | Significantly lower mean sedation scores (i.e., less combative, violent, or out of control behavior) at 10, 15, 30, and 60 minutes with droperidol vs. lorazepam, each p <0.001^102^
Medication protocols vs. other medication protocols: Benefits | Change in aggressive behavior | Change in CGI-A scores 558 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | No differences in changes in percentages of patients with CGI-A score ≥3 from baseline to day 6 or to last day of observation with olanzapine vs. risperidone vs. haloperidol, p=NR.106
Medication protocols vs. other medication protocols: Benefits | Change in aggressive behavior | Change in MOAS total aggression scores 101 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Nonsignificant differences between risperidone vs. olanzapine vs. quetiapine vs. haloperidol in changes in mean total MOAS scores from baseline to 72 hours.99
Medication protocols vs. other medication protocols: Harms | Staff harm | Staff injury 91 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Very small numbers of events with no statistical testing for detecting differences in droperidol vs. midazolam vs. a combination of droperidol plus midazolam (3 vs. 1 vs. 2, p=NR).77
Medication protocols vs. other medication protocols: Harms | Adverse effects from medication | Acute extrapyramidal events 28 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | No acute extrapyramidal events^a^ with either in haloperidol vs. flunitrazepam at 90 minutes.82
Medication protocols vs. other medication protocols: Harms | Adverse effects from medication | Marked sedation 28 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Very few events at 90 minutes with either haloperidol vs. flunitrazepam, no statistical testing reported (3 vs. 3, p=NR).82
Medication protocols vs. other medication protocols: Harms | Adverse effects from medication | Drug-related adverse events 91 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Very small numbers of events with no statistical testing for detecting differences in droperidol vs. midazolam vs. a combination of droperidol plus midazolam (2 vs. 8 vs. 2, p=NR).77
Medication protocols vs. other medication protocols: Harms | Adverse effects from medication | Abnormal QT interval 91 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Very small numbers of abnormal QT intervals with no statistical testing for detecting differences in droperidol vs. midazolam vs. a combination of droperidol plus midazolam (2 vs. 2 vs. 4, p=NR).77
Medication protocols vs. other medication protocols: Harms | Adverse effects from medication | Medication side effects 20 | Insufficient | Low risk of bias, consistency unknown—single study, direct, imprecise | No medication side effects reported with either haloperidol plus lorazepam vs. lorazepam.98
Medication protocols vs. other medication protocols: Harms | Adverse effects from medication | Reduction in vital signs 202 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | No significant difference for any reduced vital signs between droperidol vs. lorazepam.102
Medication protocols vs. other medication protocols: Harms | Adverse effects from medication | Overall treatment-emergent adverse events 558 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | Few overall treatment-emergent adverse events with olanzapine vs. risperidone vs. haloperidol p=NR.106
Medication protocols vs. other medication protocols: Harms | Adverse effects from medication | Adverse events considered related to primary antipsychotic medication 558 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | Very few events considered related to primary antipsychotic medication with olanzapine vs. risperidone vs. haloperidol p=NR.106
Medication protocols vs. other medication protocols: Harms | Adverse effects from medication | Extrapyramidal symptoms 558 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | No significant differences (very few events) with olanzapine vs. risperidone vs. haloperidol vs or comparator groups.106
Medication protocols vs. other medication protocols: Harms | Adverse effects from medication | Discontinuation due to clinically significant adverse events 558 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | No significant difference in discontinuation due to clinically significant adverse events with olanzapine vs. risperidone vs. haloperidol vs or comparator groups.106
Medication protocols vs. other medication protocols: Harms | Adverse effects from medication | Extrapyramidal events 101 | Insufficient | Medium risk of bias, consistency unknown—single study, direct, imprecise | Very small numbers of dizziness events in risperidone vs. olanzapine vs. quetiapine vs. haloperidol, p=0.012.^99^

a Also no excitation or disinhibition in patients receiving flunitrazepam, not reported for the haloperidol.82

CGI-A = Clinical Global Impression Severity of Illness – Aggression; KQ = Key Question; MOAS = Modified Overt Aggression Scale; N, n = number of patients; NR = not reported; NS = not significant; OAS = Overt Aggression Scale; QT = QRS complex to T wave interval; vs. = versus.

### Strategies To Address Aggressive Behavior: Benefits (KQ 1c) and Harms (KQ 2c)

We identified no eligible studies for strategies involving staff training, risk assessment interventions, multimodal interventions, or environmental interventions. We graded SOE for all these strategies as insufficient for both benefit and harms.

Again, only medication interventions addressed this question and provided any direct comparisons of strategies (Table 16). Although involuntary medication as a first choice in actively aggressive patients did decrease the use of seclusion compared with first choice of seclusion, this single study's high risk of bias led to a grade of insufficient SOE. This study reported no harms data, leading to an SOE grade of insufficient regarding the comparative harms of these strategies.

Table 16 Summary of findings with strength of evidence grades: Comparative benefits of medication-based strategies for reducing seclusion and restraint use in aggressive patients (KQ 1c)

Intervention and Comparison | Primary Outcome of Interest | Outcome N of Patients Analyzed | Strength of Evidence | Supporting Judgment | Findings and Direction of Effect
Medication protocols vs. other medication protocols or usual care | Change in seclusion or restraint | Seclusion incident rate 659 | Insufficient | High risk of bias, consistency unknown—single study, direct, precise | Significant lower risk with involuntary medication^a^ as first choice vs. seclusion as first choice (RR, 0.51; 95% CI, 0.34 to 0.79), p<0.001.^86^
Medication protocols vs. other medication protocols or usual care | Change in seclusion or restraint | Seclusion hours 659 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | Lower number of overall hours with involuntary medication^a^ as first choice vs. seclusion as first choice (998 vs. 2,098), no statistical testing reported.86
Medication protocols vs. other medication protocols or usual care | Change in seclusion or restraint | Seclusion duration 659 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | Longer mean duration with involuntary medication^a^ as first choice vs. seclusion as first choice (32 vs. 30 hours), no statistical testing reported.86
Medication protocols vs. other medication protocols or usual care | Change in seclusion or restraint | Seclusion duration rate 659 | Insufficient | High risk of bias, consistency unknown—single study, direct, precise | Significant lower risk with involuntary medication^a^ as first choice vs. seclusion as first choice (RR, 0.54; 95% CI, 0.5 to 0.58), p<0.001.^86^
Medication protocols vs. other medication protocols or usual care | Change in seclusion or restraint | Mechanical restraint incident rate 659 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | No significant difference in involuntary medication^a^ as first choice vs. seclusion as first choice (RR, 1.44; 95% CI, 0.38 to 5.36).86
Medication protocols vs. other medication protocols or usual care | Change in seclusion or restraint | Coercive incident rate^b^ 659 | Insufficient | High risk of bias, consistency unknown—single study, direct, imprecise | No significant difference in coercive incident rate in involuntary medication^a^ vs. seclusion as first choice options (RR, 0.95; 95% CI, 0.67 to 1.35).86
Medication protocols vs. other medication protocols or usual care | Change in seclusion or restraint | Duration in restraints 200 | Insufficient | High risk of bias, consistency unknown—single study, direct, precise | Significant decrease with single-dose delirium treatment vs. no delirium treatment, both in the first 24 hours, 3 vs. 6 days, p<0.001.^85^

a “Involuntary medication” refers to single dose haloperidol plus promethazine or lorazepam.86

b “Coercion” refers to a sequence of coercive episodes (seclusion, mechanical restraint, or involuntary medication) for less than 24 hours.86

CI = confidence interval; KQ = Key Question; N = number; RR = relative risk; vs. = versus.

Finally, in treating delirium in an intensive care setting, immediate treatment with psychotropic medications led to shorter time in restraints compared with delayed or no treatment. We graded this as insufficient SOE because the data came from a high risk of bias study. Again, the study reported no harms data, leading to an insufficient SOE grade.

### Characteristics of Patient, Intervention Components, or Settings Modifying Outcomes (KQ 3)

We identified no eligible studies that addressed whether these characteristics modified these results.

## Findings in Relationship to What Is Already Known

This limited body of evidence is consistent with prior findings. Older reviews emphasized the lack of high quality and effective intervention studies to prevent the development of aggressive behavior in acute-care settings.12,15,108,109 The absence of relevant literature has been similarly reported for patients with actively aggressive behavior, whether alternative strategies were being compared with seclusion and restraints12,15 or whether alternatives to seclusion and restraints were being compared with each other.12,13,15,108 The lack of literature about comparative harms of these interventions has also been identified.110 Our review updates and confirms these findings, and it additionally includes potentially relevant pharmacologic interventions.

What our review adds is the finding that a general application to all individuals on a inpatient psychiatric units (i.e., not just to those who are actively aggressive) of a strategy that involves a risk assessment component to can decrease subsequent aggressive behavior. Earlier reviews of risk assessments assessed whether they could decrease agitation, which is often considered a lower-level precursor to aggression. However, CRTs in both trials that evaluated the effectiveness of risk assessment had data analytic limitations related to using a cluster randomized design. Specifically, investigators had not analyzed their data to account appropriately for the clustered nature of the data; this drawback likely affected each trial's results (e.g., increased the risk of a type I error). Finally, our results can be considered in the context of prior research about the impact of risk assessment practice on patients' agitation.111 Specifically, our review identified a potential relationship between using risk assessment and lower aggression in acute care settings (albeit with the statistical limitations we noted); earlier research had found that using risk assessment is associated with reduced agitation.

## Applicability

The scope of our review encompassed adults with a diagnosed psychiatric disorder, including delirium, in an acute care hospital setting and adults with severe psychiatric symptomatology in an emergency department setting. In addition, we included studies of patients for whom attempts were made to prevent aggressive behavior or to de-escalate that behavior if they became actively aggressive.

The populations and settings in the included studies were relevant to those we were targeting. When reported, mean ages generally ranged from 38 to 40 years. Studies varied widely in the percentages of patients who were male or female. We found little information on other sociodemographic or clinical characteristics of patients.

Interventions were in line with clinical practice in acute care units. However, the specifics of how investigators implemented their interventions were not always clear; hence, how to reproduce or replicate them is also uncertain. This point is especially relevant to the multimodal protocols, where varying fidelity to multiple components makes it difficult to attribute benefits to specific components.

Studies generally compared interventions with usual care. Usual-care practices appeared to be consistent with standard practice on psychiatric and medical units. The only studies directly comparing alternative strategies with each other involved medication protocols. Only one study compared an alternative strategy (first choice involuntary medication) directly with seclusion (considered usual care in that country).

Outcomes measured were quite diverse; this fact precluded any kind of quantitative synthesis of data. For example, changes in any aggressive incidents versus changes in severe aggressive incidents were not regarded as combinable outcomes. Also, most studies reported short-term, but not long-term, outcomes. One study reported long-term outcomes such as quality of life, patient experience, and subsequent aggressive behavior. Two studies reported on use of services and economic outcomes.

Nineteen studies addressed individuals on an acute care psychiatric unit (rather than a medical or emergency department setting). Approximately half of the total number of identified studies were conducted in the United States. However, of the 11 eligible studies, only 4 were from U.S. settings (1 high risk of bias CRT in inpatient psychiatric settings,103 1 high risk of bias retrospective cohort study addressing delirium in an intensive care unit,85 and 1 high risk of bias RCT102 and 1 low risk of bias RCT98 both addressing aggression in an emergency department). Indeed, 5 of the 6 eligible studies involving inpatient psychiatric settings were conducted in countries other than the United States. The 2 studies forming the basis for the single low SOE intervention, risk assessment,78,87 were both conducted outside the United States. How substantially clinical practice in sites outside the United States differs from current U.S. practice is not clear. This finding implies that the applicability of findings from outside the United States may be questioned.

## Implications for Clinical and Policy Decisionmaking

The paucity of evidence means that most of our implications are for future research rather than clinical or policy judgments. Still, the handful of findings that we graded as low SOE may provide some implications for clinical practice or policy judgments.

In particular, a limited number of risk assessment interventions subsequently led to less aggressive behavior (low SOE) and reduced the subsequent use of seclusion and restraints (low SOE). These findings suggest the need for clinicians to consider carefully the role of these strategies as interventions on psychiatric inpatient units. Specifically, acute care practitioners and administrative staff will need to balance the low SOE with the reality that violence is a pressing (indeed growing) concern and poses significant disruptions to quality of care in such settings. The questions that may arise, for example, include: Is the limited evidence currently available sufficient for evaluating effectiveness? Should implementation decisions be delayed until more evidence becomes available? What is the role of quality measures designed to create incentives to improve the quality of care when the evidence base for those measures is unclear?

We are unaware of any ongoing trials that will add to the current sparse body of evidence regarding the benefits of risk assessments and multimodal interventions. Furthermore, we cannot comment on potential harms or costs associated with implementing risk assessment protocols. Indeed, with only one study (rated as high risk of bias) from U.S. inpatient psychiatric settings, determining how these interventions might be applied in and what modifications might be necessary are key next steps.

## Limitations of the Systematic Review Process

To find eligible studies, we employed an intensive search process in multiple electronic databases; we also conducted searches for gray literature. Because of time and monetary limitations, however, we limited eligible studies to those published in English. Methods research indicates that such an approach can introduce language bias; in general, however, it may also lead to overestimates of the effectiveness of interventions.61

We also limited the scope to focus on data relevant to adults in acute care settings. This restriction followed the request of the topic nominator, but our Key Informants and stakeholders supported this approach as we developed the scope of the review. This focus left out consideration of data in chronic care and psychiatric residential settings; it also omitted treatment of children and adolescents. In both these clinical areas, however use of seclusion and restraints is common and potentially concerning.22 Further, this focus on acute care settings (rather than psychiatric hospitals, which can involve both acute and longer-term lengths of stay) prevented inclusion of the few otherwise eligible studies that addressed the use of the Six Core Strategies,32 a key strategy in widespread use in psychiatric units worldwide. For example, some evidence of longer-stay psychiatric hospitals suggests benefit of multimodal interventions.112

Our review does not address those with a primary diagnosis of dementia in an acute care setting. Although systematic review evidence addressing the use of seclusion and restraints in patients with dementia in chronic care settings exists,54,55 we did not identify any reviews of the use of these approaches in acute care facilities treating patients with dementia.

To allow a meaningful synthesis of outcomes, we required that studies report at least one of our main outcomes—change in aggressive behavior or change in seclusion and restraint use. This restriction may have reduced the number of eligible studies and limited the number of patient-centered outcomes (e.g., improved quality of life and improved therapeutic relationship) we could examine. However, synthesizing such data with the other collected outcomes would have been difficult and would be unlikely to affect our SOE findings.

Distinguishing between benefits (KQ 1) and harms (KQ 2) in comparative effectiveness reviews can be challenging. For example, a benefit of a particular alternative strategy (e.g., decreased injury to staff) could be seen as a harm of the comparator (e.g., increased injury to staff). Given the limited evidence identified in our review, we do not think this difficulty affects interpretation of our results, but it is an important issue to consider in this work. Furthermore, although we group intervention types in our results section for ease of reporting, these types were not established a priori. The lack of a generally accepted nomenclature for types of interventions aimed at de-escalating aggressive behavior in psychiatric patients is another limitation of our review.

Publication bias and selective outcome reporting are potential limitations. Although we searched for gray and unpublished literature, the extent and impact of publication and reporting bias in this body of evidence are impossible to determine.

We excluded reviews and primary studies that examined agitation as the primary outcome when evaluating the effectiveness of inpatient or acute care risk assessment protocols.111 This exclusion limited consideration of interventions to reduce agitation, which may also lead to a decrease in aggression. An evidence base for reducing agitation does exist113,114 and may inform aggression management. This decision to focus on aggression and not agitation, while narrowing the scope of our review, also reduced the heterogeneity of the outcomes under examination. Each exclusion decision was made with the intention of focusing the review and controlling for important sources of heterogeneity.

Our review addressed only interventions for which an evidence base exists. Newer interventions, which might deal with aggressive behavior but for which data have not yet generated, were not ones we could have identified for this review.

Finally, our scope did not allow us to evaluate the accuracy of risk assessment tools. Risk assessment is an essential step to identify patients at high risk of aggressive behavior (i.e., those to whom interventions to de-escalate aggressive behavior need to be targeted).109 We found no systematic review of the psychometric evidence of these tools for identifying those at risk of aggressive behavior.

## Limitations of the Evidence Base

Overall, several major limitations characterize this body of evidence. First, the number and quality of eligible studies are quite low. We identified a small number of eligible trials, and for those eligible, all but one had medium or high risk of bias assessments, leading to only one intervention—risk assessment—with SOE greater than low. Most of the available evidence was from pre/post studies with designs that precluded conclusions of causal inference. Further, we were surprised that no eligible trials tested application of the Six Core Strategies for decreasing aggressive behavior, given its influence on practices both in the United States and internationally.115-117 This evidence base leaves clinicians, administrators, policymakers, and patients without clear guidance on how to best prevent and de-escalate aggressive behaviors in acute care settings.

Second, the analytic approaches employed to handle CRTs, particularly for evaluating risk assessment protocols, had substantial limitations that affected the assigned SOE ratings. More information in each primary study, including the standard error of each intraclass correlation coefficient, the average cluster size for each outcome, and the within- and between- variation for the outcomes, would have made it easier to determine how much the data clustering affected the results; this in turn which would have made for more precise SOE ratings.

Third, limited description of the nonmedication interventions in the articles and the lack of a reference standard for specific interventions made it difficult to clarify which specific parts of an intervention were being applied. This lack of clarity may have led to our inaccurately classifying interventions (e.g., components of staff training may overlap with environmental interventions, so that the difference between the two interventions may not be that substantial) and made it difficult to determine what specific components were effective. Similarly, this limited description makes it difficult to determine how to successfully replicate effective interventions, such as the implementation of risk assessment protocols, in an inpatient U.S. acute care setting.

Fourth, reporting on the relevant outcomes is varied. Although studies report on variables reflecting aggressive behavior and use of seclusion and restraint use, they use many different measures to do so, making synthesis of the data challenging. For example, aggressive behavior might be reported as a total count of aggressive incidents, or as a mean rate of aggressive incidents per 100 treatment days; such diversity prevents analysts from doing a clear quantitative synthesis of the results to determine a magnitude of effect. Similarly, seclusion and restraint outcomes might be measured in total counts, or rates per 100 treatment days, or duration in seclusion. Additionally, seclusion and restraints were sometimes reported as single summary measure; other times reported them separately. Determining which outcomes are more important, and then collecting them systematically (consistently), would be important future steps in research on these topics.

Fifth, some of the available interventions were targeted at slightly different populations, making the SOE assessment difficult. For example, the violence risk assessment studies evaluated not only different risk assessment protocols but also different classifications of aggression (i.e., severe aggression and any aggression). Therefore, for most outcomes, we graded the SOE as either low or insufficient.

Sixth, many relevant outcomes are not reported. In our eligible studies, we found limited reporting of patient-centered outcomes, such as improved quality of life or patient experience, and improved therapeutic relationship, that are key guides to selecting a strategy. Similarly, we found only limited information on harms and no information on costs or resource utilization. However, data on each of these issues are necessary to determine whether the balance of benefits and harms supports the use particular strategies, such as risk assessment interventions.

Seventh, most of the available acute care evidence is from inpatient psychiatric settings, with little eligible evidence for inpatient medical/surgical units and emergency departments.

Finally, we found no eligible evidence to guide decisionmakers about how these comparative effects might differ by key moderating variables, such as age, specific psychiatric diagnosis, and specific treatment component.

## Research Recommendations

Major evidence gaps exist in this important and increasingly worrisome clinical arena; they point to important next steps for research in preventing and de-escalating aggressive behavior in acute care settings. The SOE grades informing decisionmaking in this area are minimal. A major gap is well-designed, adequately powered, properly analyzed comparative trials that address questions of prevention and de-escalation. The validity of findings from the three reasonably well-designed CRTs was severely limited by analyses that did not properly control for the clustered nature of the data. We applaud the efforts to conduct comparative trials, but this evidence base does not convincingly show the efficacy of most of these strategies. That fact complicates the design of strong comparative studies and reflects a gap that may need to be addressed first.

Head-to-head trials that move beyond a usual-care comparator to examine various interventions against each other are needed to guide decisionmaking. The critical element is identifying the “right” interventions to compare, to make the most efficient use of research time and funding on this topic. More evidence that can speak to differential effectiveness of various interventions would allow clinicians and administrators to balance effectiveness with implementation and resource costs.

Investigators leading trials in the future must clearly describe their interventions. Only in this way can other research teams sensibly try to reproduce or replicate such studies and help confirm which components of the interventions may be the most (or least) effective. Risk assessment strategies, which have some evidence for preventing aggressive behavior, need to be described in more detail to enable them to be compared with each other and allow variations within these approaches to be compared.

Currently, clinicians and investigators do not know the accuracy of risk assessment tools. These are necessary to identify patients at high risk of aggressive behavior and, hence, to develop an effective plan to manage potential or real aggressive behavior. For that reason, more work on documenting the measurement properties of these tools is needed.

All future trials must report on consistently defined and clinically meaningful outcomes, both short term and long term. Selection of these outcomes needs to be informed by key stakeholders, including patients. Crucial short-term outcomes include reliable and valid measures of aggressive behavior and of seclusion and restraint actions. Using well-established, reliable, and valid assessments of aggression that can be harmonized across studies (and ideally countries) is crucial, as well, for future systematic reviews on these topics. In addition, research teams should increase adherence to the Consolidated Standards of Reporting Trials (CONSORT) statement regarding the reporting of clinical trials (including cluster randomized trials).

Key long-term outcomes must involve more patient-centered outcomes, including, for instance, quality of life or other patient-reported outcomes. Patient perspectives of harms, including treatment preferences, are largely missing from the literature in acute care settings, and this gap should be remedied. Measures of the use of health services are important, as are cost implications and data. Investigators should incorporate implementation factors, such as acceptability, feasibility, and sustainability, into their designs for intervention research in acute care settings.

Available acute care data are almost entirely from inpatient psychiatric settings and from settings outside the United States. In the latter case, standard practices, patient populations, insurance coverage, costs, and various other variables may differ, perhaps considerably. Future well-designed studies of inpatient psychiatric settings need to be conducted in U.S. settings. In addition, informative data must be collected from acute care medical and surgical units and from emergency department settings.

Finally, we clearly had no useful data on modifiers of treatment effectiveness. Thus, future studies (including comparative trials) need to assess how variables such as age and other sociodemographic or economic factors, specific diagnosis (and perhaps coexisting conditions), and specific treatment components modify or mediate the effects of the interventions studied. Consideration of effect modifiers must be powered appropriately, although we acknowledge that in this clinical area achieving adequate sample sizes for comparative trials of these types of interventions (perhaps apart from medication protocols) may prove challenging.

## Conclusions

Given the ethical imperative for treating all patients with dignity, the clinical mandate of finding evidence-based solutions to these mental health challenges, and the legal liability associated with failure to assess and manage violence risk across the treatment continuum, the need for evidence to guide clinical and policy decisionmaking for de-escalating aggressive behavior is critical. This point is particularly true of acute care settings for at least two reasons: comprehensive clinical and violence risk information may not always be readily available in such institutions, and patient management must be balanced against staffing and treatment limitations unique to each individual setting.

The current evidence base leaves clinicians, administrators, policymakers, and patients without clear guidance on how to best prevent and de-escalate aggressive behaviors in acute care settings. Only risk assessment had any evidence that they can decrease aggression and reduce seclusion and restraint; however, the strength of that evidence was, at best, low. Evidence for de-escalating aggressive behavior is even more limited. More research is needed to guide clinicians, administrators, and policymakers on how to best prevent and de-escalate aggressive behavior in acute care settings.