# Summary of Findings for Pre-Post Studies, Not Rated for Risk of Bias

## Appendix F References

1 Bowers L, Nijman H, Allan T, et al. Prevention and management of aggression training and violent incidents on U.K. acute psychiatric wards. Psychiatr Serv. Jul. 2006;57(7):1022-6. [pmid: 16816288].
2 Chang NA, Grant PM, Luther L, et al. Effects of a recovery-oriented cognitive therapy training program on inpatient staff attitudes and incidents of seclusion and restraint. Community Ment Health J. May. 2014;50(4):415-21. Epub: 2013/12/18. [pmid: 24337473].
3 Laker C, Gray R, Flach C. Case study evaluating the impact of de-escalation and physical intervention training. J Psychiatr Ment Health Nurs. Apr. 2010;17(3):222-8. [pmid: 20465771].
4 Bowers L, Brennan G, Flood C, et al. Preliminary outcomes of a trial to reduce conflict and containment on acute psychiatric wards: City Nurses. J Psychiatr Ment Health Nurs. Apr. 2006;13(2):165-72. Epub: 2006/04/13. [pmid: 16608471].
5 Bowers L, Flood C, Brennan G, et al. A replication study of the City Nurse intervention: reducing conflict and containment on three acute psychiatric wards. J Psychiatr Ment Health Nurs. Nov. 2008;15(9):737-42. [pmid: 18844799].
6 Currier GW, Farley-Toombs C. Datapoints: use of restraint before and after implementation of the new HCFA rules. Psychiatr Serv. Feb. 2002;53(2):138. Epub: 2002/02/01. [pmid: 11821540].
7 D'Orio BM, Purselle D, Stevens D, et al. Reduction of episodes of seclusion and restraint in a psychiatric emergency service. Psychiatr Serv. May. 2004;55(5):581-3. Epub: 2004/05/07. [pmid: 15128969].
8 Emmerson B, Fawcett L, Ward W, et al. Contemporary management of aggression in an inner city mental health service. Australas Psychiatry. Apr. 2007;15(2):115-9. Epub: 2007/04/28. [pmid: 17464653].
9 Forster PL, Cavness C, Phelps MA. Staff training decreases use of seclusion and restraint in an acute psychiatric hospital. Arch Psychiatr Nurs. Oct. 1999;13(5):269-71. Epub: 1999/11/24. [pmid: 10565060].
10 Hellerstein DJ, Staub AB, Lequesne E. Decreasing the use of restraint and seclusion among psychiatric inpatients. J Psychiatr Pract. Sep. 2007;13(5):308-17. Epub: 2007/09/25. [pmid: 17890979].
11 Jonikas JA, Cook JA, Rosen C, et al. A program to reduce use of physical restraint in psychiatric inpatient facilities. Psychiatr Serv. Jul. 2004;55(7):818-20. Epub: 2004/07/03. [pmid: 15232023].
12 Khadivi AN, Patel RC, Atkinson AR, et al. Association between seclusion and restraint and patient-related violence. Psychiatr Serv. Nov. 2004;55(11):1311-2. Epub: 2004/11/10. [pmid: 15534024].
13 Melson J, Kane M, Mooney R, et al. Improving alcohol withdrawal outcomes in acute care. Perm J. Spring. 2014;18(2):e141-5. Epub: 2014/05/29. [pmid: 24867561].
14 Pollard R, Yanasak EV, Rogers SA, et al. Organizational and unit factors contributing to reduction in the use of seclusion and restraint procedures on an acute psychiatric inpatient unit. Psychiatr Q. Mar. 2007;78(1):73-81. Epub: 2006/11/15. [pmid: 17102932].
15 Canatsey K, Roper JM. Removal from stimuli for crisis intervention: using least restrictive methods to improve the quality of patient care. Issues Ment Health Nurs. Jan-Feb. 1997;18(1):35-44. [pmid: 9052099].
16 Vaaler AE, Morken G, Flovig JC, et al. Effects of a psychiatric intensive care unit in an acute psychiatric department. Nord J Psychiatry. 2006;60(2):144-9. Epub: 2006/04/26. [pmid: 16635934].
17 Vaaler AE, Iversen VC, Morken G, et al. Short-term prediction of threatening and violent behaviour in an acute psychiatric intensive care unit based on patient and environment characteristics. BMC Psychiatry. 2011;11:44. Epub: 2011/03/23. [pmid: 21418581].
18 Veltro F, Falloon I, Vendittelli N, et al. Effectiveness of cognitive-behavioural group therapy for inpatients. Clin Pract Epidemiol Ment Health. 2006;2:16. [pmid: 16859548].
19 Veltro F, Vendittelli N, Oricchio I, et al. Effectiveness and efficiency of cognitive-behavioral group therapy for inpatients: 4-year follow-up study. J Psychiatr Pract. Sep. 2008;14(5):281-8. Epub: 2008/10/04. [pmid: 18832959].
20 Thapa PB, Palmer SL, Owen RR, et al. PRN (as-needed) orders and exposure of psychiatric inpatients to unnecessary psychotropic medications. Psychiatr Serv. Sep. 2003;54(9):1282-6. [pmid: 12954947].