# Detailed Study Characteristics Tables

Table E1 Detailed study characteristics: Staff training interventions

Table E2 Detailed study characteristics: Risk assessment interventions

Table E3 Detailed study characteristics: Multimodal interventions

Table E4 Detailed study characteristics: Environmental or group psychotherapeutic interventions

Table E5 Detailed study characteristics: Medication protocols

## References for Appendix E

1 Bowers L, Nijman H, Allan T, et al. Prevention and management of aggression training and violent incidents on U.K. acute psychiatric wards. Psychiatr Serv. Jul. 2006;57(7):1022-6. [pmid: 16816288].
2 Chang NA, Grant PM, Luther L, et al. Effects of a recovery-oriented cognitive therapy training program on inpatient staff attitudes and incidents of seclusion and restraint. Community Ment Health J. May. 2014;50(4):415-21. Epub: 2013/12/18. [pmid: 24337473].
3 Laker C, Gray R, Flach C. Case study evaluating the impact of de-escalation and physical intervention training. J Psychiatr Ment Health Nurs. Apr. 2010;17(3):222-8. [pmid: 20465771].
4 Smoot SL, Gonzales JL. Cost-effective communication skills training for state hospital employees. Psychiatr Serv. Aug. 1995;46(8):819-22. [pmid: 7583484].
5 Abderhalden C, Needham I, Dassen T, et al. Structured risk assessment and violence in acute psychiatric wards: randomised controlled trial. Br J Psychiatry. Jul. 2008;193(1):44-50. Epub: 2008/08/14. [pmid: 18700217].
6 van de Sande R, Nijman HL, Noorthoorn EO, et al. Aggression and seclusion on acute psychiatric wards: effect of short-term risk assessment. Br J Psychiatry. Dec. 2011;199(6):473-8. Epub: 2011/10/22. [pmid: 22016437].
7 Bowers L, Brennan G, Flood C, et al. Preliminary outcomes of a trial to reduce conflict and containment on acute psychiatric wards: City Nurses. J Psychiatr Ment Health Nurs. Apr. 2006;13(2):165-72. Epub: 2006/04/13. [pmid: 16608471].
8 Bowers L, Flood C, Brennan G, et al. A replication study of the City Nurse intervention: reducing conflict and containment on three acute psychiatric wards. J Psychiatr Ment Health Nurs. Nov. 2008;15(9):737-42. [pmid: 18844799].
9 Currier GW, Farley-Toombs C. Datapoints: use of restraint before and after implementation of the new HCFA rules. Psychiatr Serv. Feb. 2002;53(2):138. Epub: 2002/02/01. [pmid: 11821540].
10 D'Orio BM, Purselle D, Stevens D, et al. Reduction of episodes of seclusion and restraint in a psychiatric emergency service. Psychiatr Serv. May. 2004;55(5):581-3. Epub: 2004/05/07. [pmid: 15128969].
11 Emmerson B, Fawcett L, Ward W, et al. Contemporary management of aggression in an inner city mental health service. Australas Psychiatry. Apr. 2007;15(2):115-9. Epub: 2007/04/28. [pmid: 17464653].
12 Forster PL, Cavness C, Phelps MA. Staff training decreases use of seclusion and restraint in an acute psychiatric hospital. Arch Psychiatr Nurs. Oct. 1999;13(5):269-71. Epub: 1999/11/24. [pmid: 10565060].
13 Hellerstein DJ, Staub AB, Lequesne E. Decreasing the use of restraint and seclusion among psychiatric inpatients. J Psychiatr Pract. Sep. 2007;13(5):308-17. Epub: 2007/09/25. [pmid: 17890979].
14 Jonikas JA, Cook JA, Rosen C, et al. A program to reduce use of physical restraint in psychiatric inpatient facilities. Psychiatr Serv. Jul. 2004;55(7):818-20. Epub: 2004/07/03. [pmid: 15232023].
15 Khadivi AN, Patel RC, Atkinson AR, et al. Association between seclusion and restraint and patient-related violence. Psychiatr Serv. Nov. 2004;55(11):1311-2. Epub: 2004/11/10. [pmid: 15534024].
16 Melson J, Kane M, Mooney R, et al. Improving alcohol withdrawal outcomes in acute care. Perm J. Spring. 2014;18(2):e141-5. Epub: 2014/05/29. [pmid: 24867561].
17 Pollard R, Yanasak EV, Rogers SA, et al. Organizational and unit factors contributing to reduction in the use of seclusion and restraint procedures on an acute psychiatric inpatient unit. Psychiatr Q. Mar. 2007;78(1):73-81. Epub: 2006/11/15. [pmid: 17102932].
18 Canatsey K, Roper JM. Removal from stimuli for crisis intervention: using least restrictive methods to improve the quality of patient care. Issues Ment Health Nurs. Jan-Feb. 1997;18(1):35-44. [pmid: 9052099].
19 Vaaler AE, Morken G, Flovig JC, et al. Effects of a psychiatric intensive care unit in an acute psychiatric department. Nord J Psychiatry. 2006;60(2):144-9. Epub: 2006/04/26. [pmid: 16635934].
20 Vaaler AE, Iversen VC, Morken G, et al. Short-term prediction of threatening and violent behaviour in an acute psychiatric intensive care unit based on patient and environment characteristics. BMC Psychiatry. 2011;11:44. Epub: 2011/03/23. [pmid: 21418581].
21 Veltro F, Falloon I, Vendittelli N, et al. Effectiveness of cognitive-behavioural group therapy for inpatients. Clin Pract Epidemiol Ment Health. 2006;2:16. [pmid: 16859548].
22 Veltro F, Vendittelli N, Oricchio I, et al. Effectiveness and efficiency of cognitive-behavioral group therapy for inpatients: 4-year follow-up study. J Psychiatr Pract. Sep. 2008;14(5):281-8. Epub: 2008/10/04. [pmid: 18832959].
23 Bieniek SA, Ownby RL, Penalver A, et al. A double-blind study of lorazepam versus the combination of haloperidol and lorazepam in managing agitation. Pharmacotherapy. Jan-Feb. 1998;18(1):57-62. [pmid: 9469682].
24 Dorevitch A, Katz N, Zemishlany Z, et al. Intramuscular flunitrazepam versus intramuscular haloperidol in the emergency treatment of aggressive psychotic behavior. Am J Psychiatry. Jan. 1999;156(1):142-4. Epub: 1999/01/19. [pmid: 9892313].
25 Georgieva I, Mulder CL, Noorthoorn E. Reducing seclusion through involuntary medication: a randomized clinical trial. Psychiatry Res. Jan. 30. 2013;205(1-2):48-53. Epub: 2012/09/07. [pmid: 22951334].
26 Isbister GK, Calver LA, Page CB, et al. Randomized controlled trial of intramuscular droperidol versus midazolam for violence and acute behavioral disturbance: the DORM study. Ann Emerg Med. Oct. 2010;56(4):392-401 e1. Epub: 2010/09/28. [pmid: 20868907].
27 Michaud CJ, Thomas WL, McAllen KJ. Early pharmacological treatment of delirium may reduce physical restraint use: a retrospective study. Ann Pharmacother. Mar. 2014;48(3):328-34. Epub: 2013/11/22. [pmid: 24259659].
28 Richards JR, Derlet RW, Duncan DR. Chemical restraint for the agitated patient in the emergency department: lorazepam versus droperidol. J Emerg Med. Jul-Aug. 1998;16(4):567-73. [pmid: 9696171].
29 Thapa PB, Palmer SL, Owen RR, et al. PRN (as-needed) orders and exposure of psychiatric inpatients to unnecessary psychotropic medications. Psychiatr Serv. Sep. 2003;54(9):1282-6. [pmid: 12954947].
30 Villari V, Rocca P, Fonzo V, et al. Oral risperidone, olanzapine and quetiapine versus haloperidol in psychotic agitation. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 15. 2008;32(2):405-13. [pmid: 17900775].
31 Wilhelm S, Schacht A, Wagner T. Use of antipsychotics and benzodiazepines in patients with psychiatric emergencies: results of an observational trial. BMC Psychiatry. 2008;8:61. Epub: 2008/07/24. [pmid: 18647402].