# Strength of Evidence Grade Tables

Evidence Table D1 KQ 1a – Staff training intervention studies: Primary outcomes

Outcome Category | Outcome | N of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence
Aggressive behavior | Mean change from baseline in assaults on staff | 1 CRT1 (n=NR^a^) | High | Unknown, single study | Direct | Imprecise | Insufficient
Use of seclusion or restraints | Mean change from baseline in incidents of S/R | 1 CRT1 (n=NR^a^) | High | Unknown, single study | Direct | Imprecise | Insufficient

a Average of 92 patients discharged per month in each unit, meaning about 184 patients were included in the study each month.1

CRT = cluster randomized trial; n or N = number; NR = not reported; S/R = seclusion or restraints.

Evidence Table D2 KQ 1a – Risk assessment intervention studies: Primary outcomes

Outcome Category | Outcome | N of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence^c^
Aggressive behavior | N of aggressive patients | 1 RCT2 (n=170 during baseline period, 458 during intervention period) | Medium | Unknown, single study | Direct | Imprecise^d^ | Insufficient
Aggressive behavior | N or aggressive incidents | 1 RCT2 (n=170 during baseline period, 458 during intervention period) | Medium | Unknown, single study | Direct | Precise | Low
Aggressive behavior | Mean rate of aggressive incidents per 100 treatment days (SOAS score ≥9) | 1 RCT3 (n=973 post-intervention) | Medium | Unknown, single study | Direct | Precise | Low
Aggressive behavior | Change in physical attacks^a^ | 1 RCT3 (n=973 post-intervention) | Medium | Unknown, single study | Direct | Precise | Low
Use of seclusion or restraints | N of secluded patients | 1 RCT2 (n=170 during baseline period, 458 during intervention period) | Medium | Unknown, single study | Direct | Imprecise^d^ | Insufficient
Use of seclusion or restraints | N of seclusion incidents | 1 RCT2 (n=170 during baseline period, 458 during intervention period) | Medium | Unknown, single study | Direct | Imprecise^d^ | Insufficient
Use of seclusion or restraints | Hours in seclusion | 1 RCT2 (n=170 during baseline period, 458 during intervention period) | Medium | Unknown, single study | Direct | Precise | Low
Use of seclusion or restraints | Change in coercive incidents^b^ | 1 RCT3 (n=973 post-intervention) | Medium | Unknown, single study | Indirect | Precise | Low

a Physical attacks were defined as aggressive incidents in which the SOAS-R description met both of the following criteria: (1) means of aggression involved objects, dangerous objects, or parts of the body, and (2) the target of aggression was a person other than the patient him or herself.

b Coercive measures covered a wide range of measures, from forced injection of psychotropic medication to seclusion and mechanical restraint.

c Based on the comparisons, we graded the SOE as low for both the aggression and restraint and seclusion outcomes due to differential operationalization across studies; this precluded a direct comparison.

d Imprecise due to failure to control for clustering related to statistical analyses.

n or N = number; RCT = randomized controlled trial; SOAS = Staff Observation Aggression Scale; SOAS-R = Staff Observation Aggression Scale-Revised; SOE = strength of evidence.

Evidence Table D3 KQ 1b – Medication protocols: Primary outcomes

Outcome Category | Outcome | N of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence
Aggressive behavior | Aggression response rate in total OAS severity scores | 1 RCT4 (n=28) | Medium | Unknown, single study | Direct | Imprecise | Insufficient
Aggressive behavior | Clinically significant improvement^a^ in OAS scores | 1 RCT5 (n=20) | Low | Unknown, single study | Direct | Imprecise | Insufficient
Aggressive behavior | Change in MOAS total aggression scores | 1 NRCT6 (n=101) | Medium | Unknown, single study | Direct | Imprecise | Insufficient
Aggressive behavior | Time to OAS improvement | 1 RCT5 (n=20) | Low | Unknown, single study | Direct | Imprecise | Insufficient
Aggressive behavior | Sedation score (measure of combative, violent, and out of control behavior) at 5, 10, 15, 30 and 60 minutes^b^ | 1 RCT7 (n=202) | High | Unknown, single study | Direct | Imprecise | Insufficient
Aggressive behavior | Change in CGI-A scores^c^ | 1 NRCT8 (n=558) | High | Unknown, single study | Direct | Imprecise | Insufficient
Aggressive behavior | Violent and acute behavioral disturbance, median duration | 1 RCT9 (n=91) | Medium | Unknown, single study | Direct | Imprecise | Insufficient

a A decrease of four or more points on the OAS within 60 minutes of baseline was considered “clinically significant improvement”.5

b Mean reductions in combative, violent, and out of control behavior were measured on a six-point scale, ranging from 6 (combative, violent, out of control) to 1 (deep sleep).7

c Measured with change in percentage of patients with CGI-A scores ≥3 (corresponding to at least a moderate level of aggression).8

CGI-A = Clinical Global Impression Severity of Illness – Aggression; MOAS = Modified Overt Aggression Scale; n or N = number of patients; NR = not reported; NRCT = nonrandomized controlled trial; OAS = Overt Aggression Scale; RCT = randomized controlled trial

Evidence Table D4 KQ 1c – Medication protocols: Primary outcomes

Outcome Category | Outcome | N of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence
Use of seclusion or restraints | Seclusion incident rate (per 1000 admission days) | 1 RCT10 (n=659) | High | Unknown, single study | Direct | Precise | Insufficient
Use of seclusion or restraints | Seclusion hours, total number | 1 RCT10 (n=659) | High | Unknown, single study | Direct | Imprecise | Insufficient
Use of seclusion or restraints | Seclusion, mean duration rate of incidents in hours (per 1000 admission hours) | 1 RCT10 (n=659) | High | Unknown, single study | Direct | Imprecise | Insufficient
Use of seclusion or restraints | Mechanical restraint incident rate (per 1000 admission days) | 1 RCT10 (n=659) | High | Unknown, single study | Direct | Imprecise | Insufficient
Use of seclusion or restraints | Mechanical restraint duration (per 1000 admission days) | 1 retrospective cohort study11 (n=200) | High | Unknown, single study | Direct | Precise | Insufficient
Use of seclusion or restraints | Coercive incident rate (individual or combined) (per 1000 admission days)^a^ | 1 RCT10 (n=659) | High | Unknown, single study | Direct | Imprecise | Insufficient

a “Coercion” refers to a sequence of coercive episodes (seclusion, mechanical restraint, or involuntary medication) for less than 24 hours.10

b Details about the involuntary medications used were NR.

n or N = number of patients; RCT = randomized controlled trial

Evidence Table D5 KQ 2a – Staff training intervention studies: Adverse events or harms

Outcome Category | Outcome | N of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence
Staff distress | Change from baseline in staff resignations and transfers | 1 CRT1 (n=NR^a^) | High | Unknown, single study | Indirect | Imprecise | Insufficient
Staff distress | Change from baseline in staff sick leave | 1 CRT1 (n=NR^a^) | High | Unknown, single study | Indirect | Imprecise | Insufficient
Patient distress | Change from baseline in patients' rights complaints | 1 CRT1 (n=NR^a^) | High | Unknown, single study | Indirect | Imprecise | Insufficient

a Average of 92 patients discharged per month in each unit, meaning about 184 patients were included in the study each month.1

CRT = cluster randomized trial; n or N = number of patients; NR = not reported

Evidence Table D6 KQ 2b – Medication protocols: Adverse events or harms

Outcome Category | Outcome | N of Studies (Subjects) | Risk of Bias | Consistency | Directness | Precision | Overall Strength of Evidence
Staff injuries | Staff injuries | 1 RCT9 (n=91) | Medium | Unknown, single study | Direct | Imprecise | Insufficient
Medication side effects | Overall medication-related side effects (droperidol vs. midazolam vs. combination) | 1 RCT9 (n=91) | Medium | Unknown, single study | Direct | Imprecise | Insufficient
Medication side effects | Abnormal QT interval | 1 RCT9 (n=91) | Medium | Unknown, single study | Direct | Imprecise | Insufficient
Medication side effects | Acute extrapyramidal effects (flunitrazepam vs. haloperidol) | 1 RCT4 (n=28) | Medium | Unknown, single study | Direct | Imprecise | Insufficient
Medication side effects | Acute extrapyramidal symptoms (risperidone vs. olanzapine vs. quetiapine vs. haloperidol) | 1 NRCT6 (n=101) | Medium | Unknown, single study | Direct | Imprecise | Insufficient
Medication side effects | Extrapyramidal side effects (olanzapine vs. risperidone vs. haloperidol) | 1 NRCT 8 (n=558) | High | Unknown, single study | Direct | Imprecise | Insufficient
Medication side effects | Marked sedation | 1 RCT4 (n=28) | Medium | Unknown, single study | Direct | Imprecise | Insufficient
Medication side effects | Overall treatment-emergent adverse events (olanzapine vs. risperidone vs. haloperidol) | 1 NRCT 8 (n=558) | High | Unknown, single study | Direct | Imprecise | Insufficient
Medication side effects | Adverse events considered related to primary antipsychotic medication | 1 NRCT 8 (n=558) | High | Unknown, single study | Direct | Imprecise | Insufficient
Medication side effects | Treatment-related adverse events (haloperidol plus lorazepam vs. lorazepam) | 1 RCT5 (n=20) | Low | Unknown, single study | Direct | Imprecise | Insufficient
Medication side effects | Mean reductions in vital signs (pulse, SBP, respiratory rate, body temperature) | 1 RCT7 (n=202) | High | Unknown, single study | Direct | Imprecise | Insufficient

n or N = number of patients; NRCT = nonrandomized controlled trial; QT = Q and T wave; RCT = randomized controlled trial; SBP = systolic blood pressure; vs. = versus.

## References for Appendix D

1 Smoot SL, Gonzales JL. Cost-effective communication skills training for state hospital employees. Psychiatr Serv. Aug. 1995;46(8):819-22. [pmid: 7583484].
2 van de Sande R, Nijman HL, Noorthoorn EO, et al. Aggression and seclusion on acute psychiatric wards: effect of short-term risk assessment. Br J Psychiatry. Dec. 2011;199(6):473-8. Epub: 2011/10/22. [pmid: 22016437].
3 Abderhalden C, Needham I, Dassen T, et al. Structured risk assessment and violence in acute psychiatric wards: randomised controlled trial. Br J Psychiatry. Jul. 2008;193(1):44-50. Epub: 2008/08/14. [pmid: 18700217].
4 Dorevitch A, Katz N, Zemishlany Z, et al. Intramuscular flunitrazepam versus intramuscular haloperidol in the emergency treatment of aggressive psychotic behavior. Am J Psychiatry. Jan. 1999;156(1):142-4. Epub: 1999/01/19. [pmid: 9892313].
5 Bieniek SA, Ownby RL, Penalver A, et al. A double-blind study of lorazepam versus the combination of haloperidol and lorazepam in managing agitation. Pharmacotherapy. Jan-Feb. 1998;18(1):57-62. [pmid: 9469682].
6 Villari V, Rocca P, Fonzo V, et al. Oral risperidone, olanzapine and quetiapine versus haloperidol in psychotic agitation. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 15. 2008;32(2):405-13. [pmid: 17900775].
7 Richards JR, Derlet RW, Duncan DR. Chemical restraint for the agitated patient in the emergency department: lorazepam versus droperidol. J Emerg Med. Jul-Aug. 1998;16(4):567-73. [pmid: 9696171].
8 Wilhelm S, Schacht A, Wagner T. Use of antipsychotics and benzodiazepines in patients with psychiatric emergencies: results of an observational trial. BMC Psychiatry. 2008;8:61. Epub: 2008/07/24. [pmid: 18647402].
9 Isbister GK, Calver LA, Page CB, et al. Randomized controlled trial of intramuscular droperidol versus midazolam for violence and acute behavioral disturbance: the DORM study. Ann Emerg Med. Oct. 2010;56(4):392-401 e1. Epub: 2010/09/28. [pmid: 20868907].
10 Georgieva I, Mulder CL, Noorthoorn E. Reducing seclusion through involuntary medication: a randomized clinical trial. Psychiatry Res. Jan. 30. 2013;205(1-2):48-53. Epub: 2012/09/07. [pmid: 22951334].
11 Michaud CJ, Thomas WL, McAllen KJ. Early pharmacological treatment of delirium may reduce physical restraint use: a retrospective study. Ann Pharmacother. Mar. 2014;48(3):328-34. Epub: 2013/11/22. [pmid: 24259659].