# Risk of Bias Ratings

We provide our detailed risk of bias (ROB) ratings and the questions used to assign ratings below. ROB rating information for randomized controlled trials is presented in Tables C1 through C4, while ROB rating information for our observational and nonrandomized controlled trials is shown in Tables C5 through C7.

Table C1 Risk of bias assessments for RCTs, part 1

Author, Year Trial Name (if applicable) | Type of Randomization | Eligibility criteria clearly described? | Method of randomization method appropriate? | Allocation concealment adequate? | Patients blind to treatment assignment | Outcome assessors blind to txmt assignment? | Care providers blind to txmt assignment? | Any variation from study protocol? | Groups recruited over same time period?
Abderhalden et al., 2008^1^ | Cluster | Yes | Yes | Yes | Unclear | No | No | No | Yes
Bieniek et al., 1998^2^ | Parallel | Yes | Yes | Yes | Yes | Yes | Yes | NR | Yes
Dorevitch et al., 2008^3^ | Parallel | Yes | No | Unclear | Yes | Yes | Unclear | No | Yes
Georgieva et al., 2013^4^ | Parallel | Yes | Unclear | Unclear | Unclear | Yes | No | No | Yes
Isbister et al., 2010^5^ | Parallel | Yes | Yes | Yes | Yes | Yes | Yes | No | Yes
Richards et al., 1998^6^ | Parallel | Yes | Unclear | Yes | NR | No | No | NR | Unclear
Smoot et al., 1997^7^ | Cluster | Partially (criteria for unit selection NR) | No | NA | NA | NA | No | NR | Yes
van de Sande et al., 2011^8^ | Cluster | Yes | Yes | Yes | Unclear | No | No | No | Yes

NA = not applicable; NR = not reported; txmt = treatment

Table C2 Risk of bias assessments for RCTs, part 2

Author, Year | Baseline chx similar? If not similar, did design or analyses account for this? | Interventions adequately described? | Intervention fidelity adequate? | Cross-overs or contamination raising concern for bias? | KQ 1 Primary Outcomes: Valid and reliable measures consistently used for all participants? | KQ 1 Secondary Outcomes: Valid and reliable measures consistently used for all participants? | KQ 1: Benefits outcome data clearly reported without discrepancies?
Abderhalden et al., 2008^1^ | No, and design/analyses did not account for differences | Yes | No | Unclear | Yes | Yes | Yes
Bieniek et al., 1998^2^ | Yes, similar characteristics | Yes | Yes | No | Yes | No (non-validated VAS) | Yes
Dorevitch et al., 2008^3^ | Unclear | Yes | Yes | No | Yes | NA | Yes
Georgieva et al., 2013^4^ | Yes, similar characteristics | Yes | Unclear | Unclear | Yes | Yes | Yes
Isbister et al., 2010^5^ | No, and design/analyses did not account for differences | Yes | Unclear | No | Yes | Yes | Yes
Richards et al., 1998^6^ | Yes, similar characteristics | Yes | NR | No | Unclear (consistent use) | NA | Yes
Smoot et al., 1997^7^ | Partially (demographic and clinical chx unaccounted for), and No (baseline levels of assaults on staff) | Yes | No | No | Yes | Yes | Yes
van de Sande et al., 2011^8^ | No, but design/analyses accounted for differences | Yes | Unclear | Yes | Yes | Yes | Yes

chx = characteristics; KQ = Key Question; NA = not applicable; NR = not reported; VAS = visual analogue scale.

Table C3 Risk of bias assessments for RCTs, part 3

Author, Year | KQ 2 Harms: Valid and reliable measures consistently used for all participants? | KQ 2: Harms outcome data clearly reported without discrepancies? | Important outcomes pre-specified? If yes, reported? | Overall attrition? | Differential attrition? | Differential (≥15%) or overall high attrition (generally ≥20%) raising concern for bias?
Abderhalden et al., 2008^1^ | NA | NA | Yes | 0% | 0% | No
Bieniek et al., 1998^2^ | NA | NA | Yes | 0% | 0% | No
Dorevitch et al., 2008^3^ | NA | NA | Yes | 0% | 0% | No
Georgieva et al., 2013^4^ | NA | NA | Yes | 0% | 0% | No
Isbister et al., 2010^5^ | Yes | Yes | Yes | 13% | 11.3% (droperidol vs. droperidol plus midazolam); 6.9% (droperidol vs. midazolam); 4.4% (droperidol vs. midazolam) | No
Richards et al., 1998^6^ | Partially (vital signs not consistently measured) | Yes | Partially (adverse events not related to vital signs) | 8.2% (missing or incomplete data) | 1.8% (missing or incomplete data) | No
Smoot et al., 1997^7^ | Yes | Yes | Yes | 9.7% (pre- and post-testing); 46% of experimental group did not complete training | 3.3% (pre- and post-testing) | Yes
van de Sande et al., 2011^8^ | NA | NA | Yes | 0% | 0% | No

KQ = Key Question; NA = not applicable; vs. = versus

Table C4 Risk of bias assessments for RCTs, part 4

Author, Year | Appropriate statistical method for missing data? | If multicenter study, accounted for in analysis? | Potential confounders and modifying variables taken into account in design and/or analysis? | Other potential sources of bias? | ROB | Rationale for ROB Rating
Abderhalden et al., 2008^1^ | Unclear | NA | No | No | Medium | At baseline, rates of aggression were higher in intervention wards; unclear if interventions were implemented because of risk assessment. Because the unit of randomization was the hospital ward, raters were not blinded to treatment allocation across multiple psychiatric hospitals. There were fewer patients with schizophrenia in the preference group but all other characteristics were similar between groups. There was no reporting of attrition or intervention fidelity. Authors did not describe how wards from multiple hospitals were handled in analyses. No control for confounding.
Bieniek et al., 1998^2^ | NA | NA | Yes | No | Low | No missing data, no attrition, and use of adequate randomization and blinding all strengths of the study. Small sample size (N=20) limited the study's statistical power to evaluate between-group differences, possibly explaining the nonsignificant group-by-time interaction for improvement in OAS scores, despite time to improvement clearly favoring haloperidol + lorazepam. Also unclear which timeframe was used for patient enrollment.
Dorevitch et al., 2008^3^ | NA | NA | No | No | Medium | The study was very small (N=28). Unclear whether important sociodemographic variables differed between the two arms (no demographic or other clinical parameters were described); no control of potential confounders between two arms. The authors don't report on treatment fidelity or contamination, but it is unlikely to be a large concern given the study's small size. Authors don't provide info on attrition, but it seems unlikely to be a problem given the population and setting.
Georgieva et al., 2013^4^ | NA | NA | No | No | High | The authors did not provide any details about randomization procedures, and clinicians on unit were not clearly blinded from patient assignments to the intervention arm. Data on the use of restrictive measures were extracted from the hospital database, but it is unclear who did the extracting and if s/he was blind to the randomization. Could not collect reliable data on the number of aggressive incidents in each arm. Authors didn't appear to take into account repeated measures, nor did they report results for only first admission, even though 21% of patients were repeat patients. Unclear whether confounders were controlled for; all presented results are unadjusted. Nearly three-quarters of the patients in Group 1 (first-choice involuntary medication) were also secluded, suggesting contamination.
Isbister et al., 2010^5^ | Unclear | NA | Yes | | Medium | There were potential confounding variables not addressed in the analysis (e.g., gender). The effect of additional sedation (when needed) in the ITT sample vs. the completers sample receiving only their randomized medication was not described. Unclear how the physical restraints required with medication administration affected outcomes of interest. Unclear how missing data were handled.
Richards et al., 1998^6^ | No | NA | Partially (ethanol intoxication evaluated as confounder, but not physician seniority) | Yes | High | Potentially biased assessment of sedation (depending on primary clinician's experience), neither outcome assessors nor care providers blinded to treatment assessment, potential impact of uncontrolled intracorrelation within subjects across timepoints because of choice of statistical test, and small potential increase in ROB because missing data were excluded without ITT analysis or ensuring no impact from those data.
Smoot et al., 1997^7^ | NR | NA | No | Yes | High | Small CRT involving only two units “randomized” and within the units, only 72 employees. No information about randomization besides use of coin flip. Eligibility criteria not described. Baseline similarity of staff demographics, or patient demographics or clinical characteristics also not described. Approximately 10% of staff refused pre- and post-testing; this probably did not affect the primary outcome of interest. However, almost half of the experimental group failed to complete the intervention training (46% overall, with 40% in day shift and 17% in evening shift), which could potentially be a source of bias. Differences in outcomes could have also varied by shift because of difference in noncompletion rates. No description of how missing data from pre- and post-testing were addressed, nor the extent to which pre- and post-testing non-completers in the experimental group completed the training.
van de Sande et al., 2011^8^ | Unclear | NA | Yes | No | Medium | There was a risk of rater bias because same nurses who used Crisis Monitor scale as part of intervention also evaluated aggression and seclusion outcomes. The authors state potential risk of contamination, but they make a case that notification of control ward nurses by intervention ward nurses likely did not impact outcome. Analysis controlled for potentially confounding measures.

CRT = cluster randomized trial; ITT = intent-to-treat; N = number of patients; NA = not applicable; NR = not reported; OAS = Overt Aggression Scale; ROB = risk of bias; vs. = versus

Table C5 Risk of bias assessments for observational studies and nonrandomized controlled trials, part 1

Author, Year Trial Name (if applicable) | Study Design | Eligibility criteria clearly described? | Eligibility criteria measured with valid and reliable measures, consistently across all participants? | Strategy for recruiting participants different across groups? | Sample size sufficient to detect meaningfully significant differences? | Interventions adequately described? | Important outcomes pre-specified? If yes, reported? | Comparison group selection appropriate?^a^ | Any attempt to balance patient allocation between groups? | Impacts from concurrent interventions or unintended exposures that might bias results ruled out?
Michaud et al., 2014^9^ | Cohort (retrospective) | Yes | Unclear | No | Yes | No | Yes | Yes | No | No
Villari et al., 2008^10^ | NRCT | Unclear | Unclear | No | Unclear (powered to detect very small differences, not necessarily clinically meaningful differences) | Yes | Partially (harms not pre-specified) | Yes | Yes | Partially (unclear if other medications taken in addition to what patients were assigned)
Wilhelm et al., 2008^11^ | NRCT | Yes | Partially (NR which clinical diagnoses deemed eligible) | No | Yes | Partially (antipsychotic dosing NR) | Yes | Yes | No | No

a After taking into account feasibility and ethical considerations.

NR = not reported; NRCT = nonrandomized controlled trial.

Table C6 Risk of bias assessments for observational studies and nonrandomized controlled trials, part 2

Author, Year Trial Name (if applicable) | Study Design | Outcome assessors blind to txmt or exposure status? | Interventions/exposures assessed using valid and reliable measures, consistently across all participants? | Follow-up length sufficient to support benefits/harms evaluation? | Overall attrition? | Differential attrition? | Differential (≥15%) or overall high attrition (generally ≥20%) raising concern for bias?
Michaud et al., 2014^9^ | Cohort (retrospective) | No | Unclear | Yes | 0% | 0% | No
Villari et al., 2008^10^ | NRCT | Yes | Partially (dosing distribution NR) | Yes (benefits), and Partially (harms) | 9.9% | 0.8% to 2.8% | No
Wilhelm et al., 2008^11^ | NRCT | NR | Unclear | Yes | 2.9% | 0.2% to 2.2% | No

NR = not reported; NRCT = nonrandomized controlled trial; txmt = treatment

Table C7 Risk of bias assessments for observational studies and nonrandomized controlled trials, part 3

Author, Year Trial Name (if applicable) | Study Design | Confounding and/or effect modifying variables assessed using valid and reliable measures, consistently across all participants? | KQ 1: Appropriate statistical methods used for assessing primary benefit outcomes? | KQ 2: Appropriate statistical methods used for assessing harms outcomes? | Any impt information about primary outcomes missing? | ROB | Rationale for ROB Rating
Michaud et al., 2014^9^ | Cohort (retrospective) | Unclear | Yes | Yes | No | High | Unclear how many patients did not receive screen. Medication dosing is unknown. There was no control for differences in concomitant medication use between arms; no control for confounding in primary analyses. Unclear if/how restraint assessment was consistently applied. Study was powered to detect a 20% difference in primary outcome. There were no major differences between groups except a much higher percentage of hypervigilance documented in the treatment group. More than half of patients with at least 1 positive delirium score were not enrolled (mostly due to lack of mechanical ventilation, some due to missing data), which has the potential to bias the results.
Villari et al., 2008^10^ | NRCT | Partially (unclear to what extent medication dosing varied by treating physician) | Yes | Yes | No | Medium | Baseline characteristics similar despite alternating assignment to medication groups. Authors accounted for several potential confounders, such as prior depot antipsychotic or ECT treatment, but unable to account for other concurrent treatments that patients might have been taking at time of admission. Doses determined by treating physicians, who might have also introduced bias that way. Open-ended collection of KQ 2 harms data possibly affected by bias and might have led to underreporting. Also unclear if time of individual patients' enrollment introduced any ROB.
Wilhelm et al., 2008^11^ | NRCT | Partially (benzodiazepine use measured, but unclear how other potential confounders measured) | Partially (exploratory analyses only, no adjustment for use of multiple centers) | Partially (exploratory analyses only, no adjustment for use of multiple centers) | Partially (differences in monotherapy groups NR) | High | High risk of selection bias into different medication groups based on clinical indication and variables related to the treating physician. Unadjusted confounding by concomitant and prior medication use. No attempts to adjust statistically for between-hospital differences or patients' baseline demographic or clinical chx.

chx = characteristics; ECT = electroconvulsive therapy; impt = important; KQ = Key Question; NR = not reported; NRCT = nonrandomized controlled trial; ROB = risk of bias

## References

1 Abderhalden C, Needham I, Dassen T, et al. Structured risk assessment and violence in acute psychiatric wards: randomised controlled trial. Br J Psychiatry. Jul. 2008;193(1):44-50. Epub: 2008/08/14. [pmid: 18700217].
2 Bieniek SA, Ownby RL, Penalver A, et al. A double-blind study of lorazepam versus the combination of haloperidol and lorazepam in managing agitation. Pharmacotherapy. Jan-Feb. 1998;18(1):57-62. [pmid: 9469682].
3 Dorevitch A, Katz N, Zemishlany Z, et al. Intramuscular flunitrazepam versus intramuscular haloperidol in the emergency treatment of aggressive psychotic behavior. Am J Psychiatry. Jan. 1999;156(1):142-4. Epub: 1999/01/19. [pmid: 9892313].
4 Georgieva I, Mulder CL, Noorthoorn E. Reducing seclusion through involuntary medication: a randomized clinical trial. Psychiatry Res. Jan. 30. 2013;205(1-2):48-53. Epub: 2012/09/07. [pmid: 22951334].
5 Isbister GK, Calver LA, Page CB, et al. Randomized controlled trial of intramuscular droperidol versus midazolam for violence and acute behavioral disturbance: the DORM study. Ann Emerg Med. Oct. 2010;56(4):392-401 e1. Epub: 2010/09/28. [pmid: 20868907].
6 Richards JR, Derlet RW, Duncan DR. Chemical restraint for the agitated patient in the emergency department: lorazepam versus droperidol. J Emerg Med. Jul-Aug. 1998;16(4):567-73. [pmid: 9696171].
7 Smoot SL, Gonzales JL. Cost-effective communication skills training for state hospital employees. Psychiatr Serv. Aug. 1995;46(8):819-22. [pmid: 7583484].
8 van de Sande R, Nijman HL, Noorthoorn EO, et al. Aggression and seclusion on acute psychiatric wards: effect of short-term risk assessment. Br J Psychiatry. Dec. 2011;199(6):473-8. Epub: 2011/10/22. [pmid: 22016437].
9 Michaud CJ, Thomas WL, McAllen KJ. Early pharmacological treatment of delirium may reduce physical restraint use: a retrospective study. Ann Pharmacother. Mar. 2014;48(3):328-34. Epub: 2013/11/22. [pmid: 24259659].
10 Villari V, Rocca P, Fonzo V, et al. Oral risperidone, olanzapine and quetiapine versus haloperidol in psychotic agitation. Prog Neuropsychopharmacol Biol Psychiatry. Feb. 15. 2008;32(2):405-13. [pmid: 17900775].
11 Wilhelm S, Schacht A, Wagner T. Use of antipsychotics and benzodiazepines in patients with psychiatric emergencies: results of an observational trial. BMC Psychiatry. 2008;8:61. Epub: 2008/07/24. [pmid: 18647402].