# Excluded Studies

Exclusion Codes:

X1: | Non-English
X2: | Ineligible publication type
X3: | Ineligible study design
X4: | Ineligible population
X5: | Ineligible or no intervention
X6: | Ineligible or no comparator(s)
X7: | Ineligible or no outcome(s)
X8: | Ineligible timing
X9: | Ineligible clinical setting(s)
X10: | Ineligible geographic setting
X11: | No KQs addressed
X12: | Sample size <100 (nonrandomized studies only)
X13: | Full-text article unretrievable

1 Schizophrenia, violence, clozapine and risperidone: a review. The Special Hospitals Treatment Resistant Schizophrenia Research Group. Br J Psychiatry Suppl. Dec. 1996;(31):21-30. Exclusion Code: X2. [pmid: 8968652].
2 Rapid tranquillisation for agitated patients in emergency psychiatric rooms: a randomised trial of midazolam versus haloperidol plus promethazine. BMJ. Sep. 27. 2003;327(7417):708-13. Exclusion Code: X4. [pmid: 14512476].
3 Taking the first step. Schizophr Bull. Sep. 2010;36(5):895-9. Exclusion Code: X2. [pmid: 20554784].
4 Agid O, Kapur S, Warrington L, et al. Early onset of antipsychotic response in the treatment of acutely agitated patients with psychotic disorders. Schizophr Res. Jul. 2008;102(1-3):241-8. Exclusion Code: X7. [pmid: 18495436].
5 Alexander J, Tharyan P, Adams C, et al. Rapid tranquillisation of violent or agitated patients in a psychiatric emergency setting. Pragmatic randomised trial of intramuscular lorazepam v. haloperidol plus promethazine. Br J Psychiatry. Jul. 2004;185:63-9. Exclusion Code: X7. [pmid: 15231557].
6 Alexander M. Violence in the emergency department: a firsthand account. J Emerg Nurs. Jun. 2001;27(3):279-85. Exclusion Code: X3. [pmid: 11387566].
7 Ali A, Hassiotis A. Managing the violent patient. Br J Hosp Med (Lond). Aug. 2006;67(8):M142-4. Exclusion Code: X2. [pmid: 16918097].
8 Allan ER, Alpert M, Sison CE, et al. Adjunctive nadolol in the treatment of acutely aggressive schizophrenic patients. J Clin Psychiatry. Oct. 1996;57(10):455-9. Exclusion Code: X3. [pmid: 8909331].
9 Allen DE, de Nesnera A, Cummings K, et al. Transforming the culture of caring. J Psychosoc Nurs Ment Health Serv. Jan. 2011;49(1):45-9. Exclusion Code: X4. [pmid: 21175121].
10 Allen MH. The organization of psychiatric emergency services and related differences in restraint practices. Gen Hosp Psychiatry. Nov-Dec. 2007;29(6):467-9. Exclusion Code: X2. [pmid: 18022037].
11 Altenor A. Seclusion and restraints. Psychiatr Serv. Oct. 2000;51(10):1318. Exclusion Code: X2. [pmid: 11013340].
12 Arnetz JE, Arnetz BB. Implementation and evaluation of a practical intervention programme for dealing with violence towards health care workers. J Adv Nurs. Mar. 2000;31(3):668-80. Exclusion Code: X9. [pmid: 10718887].
13 Ashcraft L, Anthony W. Eliminating seclusion and restraint in recovery-oriented crisis services. Psychiatr Serv. Oct. 2008;59(10):1198-202. Exclusion Code: X4. [pmid: 18832507].
14 Baldacara L, Sanches M, Cordeiro DC, et al. Rapid tranquilization for agitated patients in emergency psychiatric rooms: a randomized trial of olanzapine, ziprasidone, haloperidol plus promethazine, haloperidol plus midazolam and haloperidol alone. Rev Bras Psiquiatr. Mar. 2011;33(1):30-9. Exclusion Code: X10. [pmid: 21537720].
15 Barton SA, Johnson MR, Price LV. Achieving restraint-free on an inpatient behavioral health unit. J Psychosoc Nurs Ment Health Serv. Jan. 2009;47(1):34-40. Exclusion Code: X4. [pmid: 19227108].
16 Battaglia J, Lindborg SR, Alaka K, et al. Calming versus sedative effects of intramuscular olanzapine in agitated patients. Am J Emerg Med. May. 2003;21(3):192-8. Exclusion Code: X7. [pmid: 12811711].
17 Battaglia J, Moss S, Rush J, et al. Haloperidol, lorazepam, or both for psychotic agitation? A multicenter, prospective, double-blind, emergency department study. Am J Emerg Med. Jul. 1997;15(4):335-40. Exclusion Code: X7. [pmid: 9217519].
18 Belgamwar RB, Fenton M. Olanzapine IM or velotab for acutely disturbed/agitated people with suspected serious mental illnesses. Cochrane Database of Syst Rev. 2009;(4). Exclusion Code: X6.
19 Bellus SB, Vergo JG, Kost PP, et al. Behavioral rehabilitation and the reduction of aggressive and self-injurious behaviors with cognitively impaired, chronic psychiatric inpatients. Psychiatr Q. Spring. 1999;70(1):27-37. Exclusion Code: X8. [pmid: 9924730].
20 Bergk J, Flammer E, Steinert T. Ratings of coercive interventions by inpatients and staff in Germany. Psychiatr Serv. Oct. 2009;60(10):1401. author reply -2. Exclusion Code: X11. [pmid: 19797389].
21 Bernstein R. Commentary: commentary on the “choice” between seclusion and forced medication. Psychiatr Serv. Feb. 2008;59(2):212. Exclusion Code: X2. [pmid: 18245169].
22 Bhui K, Outhwaite J, Adzinku F, et al. Implementing clinical practice guidelines on the management of imminent violence on two acute psychiatric in-patient units. Journal of Mental Health. 2001/01/01. 2001;10(5):559-69. Exclusion Code: X9.
23 Binder RL, McNiel DE. Emergency psychiatry: contemporary practices in managing acutely violent patients in 20 psychiatric emergency rooms. Psychiatr Serv. Dec. 1999;50(12):1553-4. Exclusion Code: X3. [pmid: 10577870].
24 Bjorkdahl A, Heilig M, Palmstierna T, et al. Changes in the occurrences of coercive interventions and staff injuries on a psychiatric intensive care unit. Arch Psychiatr Nurs. Oct. 2007;21(5):270-7. Exclusion Code: X9. [pmid: 17904484].
25 Borckardt JJ, Grubaugh AL, Pelic CG, et al. Enhancing patient safety in psychiatric settings. J Psychiatr Pract. Nov. 2007;13(6):355-61. Exclusion Code: X7. [pmid: 18032980].
26 Borckardt JJ, Madan A, Grubaugh AL, et al. Systematic investigation of initiatives to reduce seclusion and restraint in a state psychiatric hospital. Psychiatr Serv. May. 2011;62(5):477-83. Exclusion Code: X4. [pmid: 21532072].
27 Borenstein J. Teaching tool to reduce restraint and seclusion. Psychiatr Serv. Apr. 2008;59(4):448. Exclusion Code: X2. [pmid: 18378851].
28 Bostwick JR, Hallman IS. Agitation management strategies: overview of non-pharmacologic and pharmacologic interventions. Medsurg Nurs. Sep-Oct. 2013;22(5):303-7. 18. Exclusion Code: X2. [pmid: 24358571].
29 Bowers L, Stewart D, Papadopoulos C, et al. Inpatient violence and aggression: A literature review. Report from the Conflict and Containment Reduction Research Programme. Section of Mental Health Nursing Health Service and Population Research Institute of Psychiatry Kings College London. Institute of Psychiatry, Kings College London. May. 2011. http://www.kcl.ac.uk/ioppn/depts/hspr/research/ciemh/mhn/projects/litreview/litrevagg.pdf. Exclusion Code: X3.
30 Bowers L, Ross J, Nijman H, et al. The scope for replacing seclusion with time out in acute inpatient psychiatry in England. J Adv Nurs. Apr. 2012;68(4):826-35. Exclusion Code: X5. [pmid: 21749438].
31 Bowers L, Van Der Merwe M, Paterson B, et al. Manual restraint and shows of force: the City-128 study. Int J Ment Health Nurs. Feb. 2012;21(1):30-40. Exclusion Code: X3. [pmid: 21733054].
32 Brakoulias V, Mandali R, Seymour J, et al. Characteristics of admissions to a recently opened Psychiatric Emergency Care Centre. Australas Psychiatry. Aug. 2010;18(4):326-9. Exclusion Code: X5. [pmid: 20645898].
33 Breier A, Meehan K, Birkett M, et al. A double-blind, placebo-controlled dose-response comparison of intramuscular olanzapine and haloperidol in the treatment of acute agitation in schizophrenia. Arch Gen Psychiatry. May. 2002;59(5):441-8. Exclusion Code: X7. [pmid: 11982448].
34 Brooks MO, Sanguineti VR, Schwartz SL. Providing short-term intensive treatment in public psychiatry. Hosp Community Psychiatry. Jan. 1992;43(1):74-6. Exclusion Code: X6. [pmid: 1544655].
35 Buckley P, Bartell J, Donenwirth K, et al. Violence and schizophrenia: clozapine as a specific antiaggressive agent. Bull Am Acad Psychiatry Law. 1995;23(4):607-11. Exclusion Code: X9. [pmid: 8639988].
36 Buckley PF, Ibrahim ZY, Singer B, et al. Aggression and schizophrenia: efficacy of risperidone. J Am Acad Psychiatry Law. 1997;25(2):173-81. Exclusion Code: X12. [pmid: 9213289].
37 Cailhol L, Allen M, Moncany AH, et al. Violent behavior of patients admitted in emergency following drug suicidal attempt: a specific staff educational crisis intervention. Gen Hosp Psychiatry. Jan-Feb. 2007;29(1):42-4. Exclusion Code: X4. [pmid: 17189744].
38 Calver L, Drinkwater V, Gupta R, et al. Droperidol v. haloperidol for sedation of aggressive behaviour in acute mental health: randomised controlled trial. Br J Psychiatry. Mar. 2015;206(3):223-8. Exclusion Code: X4. [pmid: 25395689].
39 Calver L, Drinkwater V, Isbister GK. A prospective study of high dose sedation for rapid tranquilisation of acute behavioural disturbance in an acute mental health unit. BMC Psychiatry. 2013;13:225. Exclusion Code: X4. [pmid: 24044673].
40 Carmel H, Hunter M. Compliance with training in managing assaultive behavior and injuries from inpatient violence. Hosp Community Psychiatry. May. 1990;41(5):558-60. Exclusion Code: X9. [pmid: 2078207].
41 Cashin A. Seclusion: the quest to determine effectiveness. J Psychosoc Nurs Ment Health Serv. Nov. 1996;34(11):17-21. Exclusion Code: X5. [pmid: 8923346].
42 Castle DJ, Udristoiu T, Kim CY, et al. Intramuscular olanzapine versus short-acting typical intramuscular antipsychotics: comparison of real-life effectiveness in the treatment of agitation. World J Biol Psychiatry. 2009;10(1):43-53. Exclusion Code: X7. [pmid: 19137460].
43 Chaichan W. Evaluation of the use of the positive and negative syndrome scale-excited component as a criterion for administration of p.r.n. medication. J Psychiatr Pract. Mar. 2008;14(2):105-13. Exclusion Code: X10. [pmid: 18360196].
44 Champagne T, Sayer E. The effects of the use of the sensory room in psychiatry. 2003. http://www.ot-innovations.com/pdf_files/QI_STUDY_Sensory_Room.pdf. Exclusion Code: X4.
45 Chan HY, Lin AS, Chen KP, et al. An open-label, randomized, controlled trial of zotepine and risperidone for acutely ill, hospitalized, schizophrenic patients with symptoms of agitation. J Clin Psychopharmacol. Dec. 2013;33(6):747-52. Exclusion Code: X3. [pmid: 24100785].
46 Chan HY, Lu RB, Tseng CL, et al. Effectiveness of the anger-control program in reducing anger expression in patients with schizophrenia. Arch Psychiatr Nurs. Apr. 2003;17(2):88-95. Exclusion Code: X7. [pmid: 12701086].
47 Chan KL, Campayo A, Moser DJ, et al. Aggressive behavior in patients with stroke: association with psychopathology and results of antidepressant treatment on aggression. Arch Phys Med Rehabil. Jun. 2006;87(6):793-8. Exclusion Code: X4. [pmid: 16731214].
48 Charatan F. US reconsiders use of seclusion and restraints in psychiatric patients. BMJ. Jul. 10. 1999;319(7202):77. Exclusion Code: X2. [pmid: 10398624].
49 Chen J, Yang X, Song A, et al. Intramuscular ziprasidone versus haloperidol in the treatment of acute agitation in schizophrenia. Shanghai Archives of Psychiatry. 2008;20(6):363-6. Exclusion Code: X1.
50 Chen M, Liu D, Lin J. The comparision study on curing agitation by haloperidol and chlorpromazine venoclysis. Medical Journal of Chinese Civil Administration. 2004;16(10):599-629. Exclusion Code: X1.
51 Chengappa KN, Ebeling T, Kang JS, et al. Clozapine reduces severe self-mutilation and aggression in psychotic patients with borderline personality disorder. J Clin Psychiatry. Jul. 1999;60(7):477-84. Exclusion Code: X12. [pmid: 10453803].
52 Chengappa KN, Levine J, Ulrich R, et al. Impact of risperidone on seclusion and restraint at a state psychiatric hospital. Can J Psychiatry. Nov. 2000;45(9):827-32. Exclusion Code: X8. [pmid: 11143833].
53 Chengappa KN, Vasile J, Levine J, et al. Clozapine: its impact on aggressive behavior among patients in a state psychiatric hospital. Schizophr Res. Jan. 1. 2002;53(1-2):1-6. Exclusion Code: X12. [pmid: 11728832].
54 Chiles JA, Davidson P, McBride D. Effects of clozapine on use of seclusion and restraint at a state hospital. Hosp Community Psychiatry. Mar. 1994;45(3):269-71. Exclusion Code: X9. [pmid: 8188201].
55 Citrome L, Casey DE, Daniel DG, et al. Adjunctive divalproex and hostility among patients with schizophrenia receiving olanzapine or risperidone. Psychiatr Serv. Mar. 2004;55(3):290-4. Exclusion Code: X7. [pmid: 15001730].
56 Citrome L, Volavka J, Czobor P, et al. Efficacy of ziprasidone against hostility in schizophrenia: Post hoc analysis of randomized, open-label study data. J Clin Psychiatry. Apr. 2006;67(4):638-42. Exclusion Code: X3. [pmid: 16669729].
57 Cohen ES, Kruschwitz AL. Restraint reduction: lessons from the asylum. J Ethics Law Aging. Spring-Summer. 1997;3(1):25-43. Exclusion Code: X2. [pmid: 11656712].
58 Cole MG, Primeau FJ, Bailey RF, et al. Systematic intervention for elderly inpatients with delirium: a randomized trial. CMAJ. Oct. 1. 1994;151(7):965-70. Exclusion Code: X7. [pmid: 7922932].
59 Conley J. The NTAC training curriculum for the reduction of seclusion and restraint. Evaluation FastFacts from the Evaluation Center @ HSRI. May. 2004;3(1):1-4. Exclusion Code: X7.
60 Coutinho E, Fenton M, Adams C, et al. Zuclopenthixol acetate in psychiatric emergencies: looking for evidence from clinical trials. Schizophr Res. Dec. 15. 2000;46(2-3):111-8. Exclusion Code: X7. [pmid: 11120423].
61 Cowin L, Davies R, Estall G, et al. De-escalating aggression and violence in the mental health setting. Int J Ment Health Nurs. Mar. 2003;12(1):64-73. Exclusion Code: X7. [pmid: 14685961].
62 Cruz V, Abdul-Hamid M, Heater B. Research-based practice: reducing restraints in an acute care setting--phase I. J Gerontol Nurs. Feb. 1997;23(2):31-40. Exclusion Code: X4. [pmid: 9086979].
63 Currier GW, Allen MH. Emergency psychiatry: physical and chemical restraint in the psychiatric emergency service. Psychiatr Serv. Jun. 2000;51(6):717-9. Exclusion Code: X2. [pmid: 10828101].
64 Currier GW, Chou JC, Feifel D, et al. Acute treatment of psychotic agitation: a randomized comparison of oral treatment with risperidone and lorazepam versus intramuscular treatment with haloperidol and lorazepam. J Clin Psychiatry. Mar. 2004;65(3):386-94. Exclusion Code: X4. [pmid: 15096079].
65 Currier GW, Simpson GM. Risperidone liquid concentrate and oral lorazepam versus intramuscular haloperidol and intramuscular lorazepam for treatment of psychotic agitation. J Clin Psychiatry. Mar. 2001;62(3):153-7. Exclusion Code: X7. [pmid: 11305699].
66 Cutchins CH. Blueprint for restraint-free care. Am J Nurs. Jul. 1991;91(7):36-42. Exclusion Code: X4. [pmid: 1858843].
67 Damsa C, Adam E, Lazignac C, et al. Intramuscular olanzapine in patients with schizophrenia: an observational study in an emergency room. Bull Soc Sci Med Grand Duche Luxemb. 2008;(2):209-16. Exclusion Code: X12. [pmid: 18561597].
68 Damsa C, Ikelheimer D, Adam E, et al. Heisenberg in the ER: observation appears to reduce involuntary intramuscular injections in a psychiatric emergency service. Gen Hosp Psychiatry. Sep-Oct. 2006;28(5):431-3. Exclusion Code: X5. [pmid: 16950380].
69 Deans C. The effectiveness of a training program for emergency department nurses in managing violent situations. Aust J Adv Nurs. Jun-Aug. 2004;21(4):17-22. Exclusion Code: X4. [pmid: 18646649].
70 DeLacy L, Edner B, Hart C, et al. Learning from Each Other: Success Stories and Ideas for Reducing Restraint/Seclusion in Behavioral Health. American Psychiatric Association, American Psychiatric Nurses Association, National Association of Psychiatric Health Systems, and American Hospital Association Section for Psychiatric and Substance Abuse Services. 2003. http://c.ymcdn.com/sites/www.copaa.org/resource/collection/662B1866-952D-41FA-B7F3-D3CF68639918/Learning_from_each_other_-reducing_restraint.pdf. 19 January 2015. Exclusion Code: X3.
71 Delaney KR, Johnson ME. Safety and inpatient psychiatric treatment: moving the science forward. J Am Psychiatr Nurses Assoc. Mar-Apr. 2012;18(2):79-80. Exclusion Code: X2. [pmid: 22548225].
72 Dewey K, Brill C. Decrease in restraint use in a study of a geropsychiatric unit. J Psychosoc Nurs Ment Health Serv. Oct. 2000;38(10):14-8. Exclusion Code: X4. [pmid: 11056890].
73 Dickerson F, Ringel N, Parente F, et al. Seclusion and restraint, assaultiveness, and patient performance in a token economy. Hosp Community Psychiatry. Feb. 1994;45(2):168-70. Exclusion Code: X9. [pmid: 8168799].
74 Dodds P, Bowles N. Dismantling formal observation and refocusing nursing activity in acute inpatient psychiatry: a case study. J Psychiatr Ment Health Nurs. Apr. 2001;8(2):183-8. Exclusion Code: X2. [pmid: 11882126].
75 Donat DC. Impact of a mandatory behavioral consultation on seclusion/restraint utilization in a psychiatric hospital. J Behav Ther Exp Psychiatry. Mar. 1998;29(1):13-9. Exclusion Code: X9. [pmid: 9627821].
76 Donat DC. Impact of improved staffing on seclusion/restraint reliance in a public psychiatric hospital. Psychiatr Rehabil J. Spring. 2002;25(4):413-6. Exclusion Code: X9. [pmid: 12013271].
77 Donat DC. Employing behavioral methods to improve the context of care in a public psychiatric hospital: Reducing hospital reliance on seclusion/restraint and psychotropic PRN medication. Cognitive and Behavioral Practice. Winter. 2002;9(1):28-37. Exclusion Code: X12.
78 Donat DC. An analysis of successful efforts to reduce the use of seclusion and restraint at a public psychiatric hospital. Psychiatr Serv. Aug. 2003;54(8):1119-23. Exclusion Code: X9. [pmid: 12883139].
79 Donat DC, McKeegan GF, Neal B. Training inpatient psychiatric staff in the use of behavioral methods: A program to enhance utilization. Psychosocial Rehabilitation Journal. 1991;15(1):69-74. Exclusion Code: X7.
80 Emde K, Merkle S. Reducing use of restraints in the emergency department: one level III community hospital's experience. J Emerg Nurs. Aug. 2002;28(4):320-2. Exclusion Code: X12. [pmid: 12122405].
81 Fernandes CM, Raboud JM, Christenson JM, et al. The effect of an education program on violence in the emergency department. Ann Emerg Med. Jan. 2002;39(1):47-55. Exclusion Code: X4. [pmid: 11782730].
82 Fisher WA. Restraint and seclusion: a review of the literature. Am J Psychiatry. Nov. 1994;151(11):1584-91. Exclusion Code: X5. [pmid: 7943445].
83 Fisher WA. Elements of successful restraint and seclusion reduction programs and their application in a large, urban, state psychiatric hospital. J Psychiatr Pract. Jan. 2003;9(1):7-15. Exclusion Code: X9. [pmid: 15985912].
84 Fletcher E, Stevenson C. Launching the Tidal Model in an adult mental health programme. Nurs Stand. Aug. 22-28. 2001;15(49):33-6. Exclusion Code: X9. [pmid: 12214392].
85 Foster S, Kessel J, Berman ME, et al. Efficacy of lorazepam and haloperidol for rapid tranquilization in a psychiatric emergency room setting. Int Clin Psychopharmacol. May. 1997;12(3):175-9. Exclusion Code: X7. [pmid: 9248875].
86 Garner B. Effect of Massage Therapy on Aggression in a Psychiatric Inpatient Unit. Melbourne Health. NCT00421070. Melbourne, Victoria, Australia. January. 10. 2007. January 10, 2007. Exclusion Code: X4.
87 Garner B, Phillips LJ, Schmidt HM, et al. Pilot study evaluating the effect of massage therapy on stress, anxiety and aggression in a young adult psychiatric inpatient unit. Aust N Z J Psychiatry. May. 2008;42(5):414-22. Exclusion Code: X4. [pmid: 18478478].
88 Gaskin CJ, Elsom SJ, Happell B. Interventions for reducing the use of seclusion in psychiatric facilities: review of the literature. Br J Psychiatry. Oct. 2007;191:298-303. Exclusion Code: X3. [pmid: 17906239].
89 Gerolamo AM. The conceptualization of physical restraint as a nursing-sensitive adverse outcome in acute care psychiatric treatment settings. Arch Psychiatr Nurs. Aug. 2006;20(4):175-85. Exclusion Code: X3. [pmid: 16846778].
90 Gilbert M, Counsell C. Planned change to implement a restraint reduction program. J Nurs Care Qual. Jun. 1999;13(5):57-64. Exclusion Code: X4. [pmid: 10343480].
91 Gillies D, Beck A, McCloud A, et al. Benzodiazepines for psychosis-induced aggression or agitation. Cochrane Database of Syst Rev. 2009;(4). Exclusion Code: X7.
92 Gillies J, Moriarty H, Short T, et al. An innovative model for restraint use at the Philadelphia Veterans Affairs Medical Center. Nurs Adm Q. Jan-Mar. 2005;29(1):45-56. Exclusion Code: X3. [pmid: 15779705].
93 Goldbloom DL, Mojtabai R, Serby MJ. Weekend prescribing practices and subsequent seclusion and restraint in a psychiatric inpatient setting. Psychiatr Serv. Feb. 2010;61(2):193-5. Exclusion Code: X12. [pmid: 20123827].
94 Gonzalez D, Bienroth M, Curtis V, et al. Consensus statement on the use of intramuscular aripiprazole for the rapid control of agitation in bipolar mania and schizophrenia. Curr Med Res Opin. 2013;29(3):241-50. Exclusion Code: X2. [pmid: 23323879].
95 Goodykoontz L, Herrick CA. Evaluation of an inservice education program regarding aggressive behavior on a psychiatric unit. J Contin Educ Nurs. May-Jun. 1990;21(3):129-33. Exclusion Code: X9. [pmid: 2112174].
96 Gordon W, Morton T, Brooks G. The Tidal Model and the reform of nursing practice. 2004. Exclusion Code: X4.
97 Gordon W, Morton T, Brooks G. Launching the Tidal Model: evaluating the evidence. J Psychiatr Ment Health Nurs. Dec. 2005;12(6):703-12. Exclusion Code: X2. [pmid: 16336595].
98 Griffey RT, Wittels K, Gilboy N, et al. Use of a computerized forcing function improves performance in ordering restraints. Ann Emerg Med. Apr. 2009;53(4):469-76. Exclusion Code: X5. [pmid: 18640744].
99 Grigg M. Eliminating seclusion and restraint in Australia. Int J Ment Health Nurs. Dec. 2006;15(4):224-5. Exclusion Code: X2. [pmid: 17064317].
100 Haddock G, Tarrier N, Morrison AP, et al. A pilot study evaluating the effectiveness of individual inpatient cognitive-behavioural therapy in early psychosis. Soc Psychiatry Psychiatr Epidemiol. May. 1999;34(5):254-8. Exclusion Code: X5. [pmid: 10396167].
101 Halbreich U, Smail N, Tu X, et al. Participation in clinical trials may improve care of acute schizophrenia inpatients in a general hospital. CNS Spectr. Sep. 2008;13(9):757-61. Exclusion Code: X3. [pmid: 18849894].
102 Hatta K, Takebayashi H, Sudo Y, et al. The possibility that requiring high-dose olanzapine cannot be explained by pharmacokinetics in the treatment of acute-phase schizophrenia. Psychiatry Res. Dec. 15. 2013;210(2):396-401. Exclusion Code: X5. [pmid: 23919898].
103 Helmuth R. Nursing staff educational preparation and patient inflicted injuries in a 160 bed psychiatric hospital. Alaska Med. Oct-Dec. 1994;36(4):189-92. 203. Exclusion Code: X3. [pmid: 7847582].
104 Herzog A. Safe and minimal use of seclusion and restraint. Psychiatr Serv. Dec. 2005;56(12):1622. discussion. Exclusion Code: X2. [pmid: 16339636].
105 Holt E. Rest and restraint. Lancet. Sep. 4-10. 2004;364(9437):829-30. Exclusion Code: X2. [pmid: 15359481].
106 Houston RJ, Stanford MS. Characterization of aggressive behavior and phenytoin response. Aggressive Behavior. 2006;32(1):38-43. Exclusion Code: X9.
107 Hovens JE, Dries PJ, Melman CT, et al. Oral risperidone with lorazepam versus oral zuclopenthixol with lorazepam in the treatment of acute psychosis in emergency psychiatry: a prospective, comparative, open-label study. J Psychopharmacol. Jan. 2005;19(1):51-7. Exclusion Code: X12. [pmid: 15671129].
108 Hsu WY, Huang SS, Lee BS, et al. Comparison of intramuscular olanzapine, orally disintegrating olanzapine tablets, oral risperidone solution, and intramuscular haloperidol in the management of acute agitation in an acute care psychiatric ward in Taiwan. J Clin Psychopharmacol. Jun. 2010;30(3):230-4. Exclusion Code: X7. [pmid: 20473056].
109 Huckshorn KA. Reducing seclusion and restraint use in mental health settings: core strategies for prevention. J Psychosoc Nurs Ment Health Serv. 2004;42(9):22-33. Review. Exclusion Code: X2. [pmid: 15493493].
110 Hughes L, Fuller G. Towards evidence based emergency medicine: best BETs from the Manchester Royal Infirmary. BET 3. Rapid tranquilisation in acute psychotic agitation. Emerg Med J. Jan. 2011;28(1):77-8. Exclusion Code: X7. [pmid: 21172918].
111 Istikoglou C, Vlavianou A, Foutsitzis D, et al. Intramuscular aripiprazole versus injectable haloperidol in treatment of acute psychotic agitation. Eur Neuropsychopharmacol. ((Istikoglou C.; Vlavianou A.; Foutsitzis D.; Theodorakopoulos G.; Polonifis C.; Kanellos P.) Konstantopouleion General Hospital of Nea Ionia, Psychiatric, Athens, Greece). 2010;20:S469-S70. Exclusion Code: X7.
112 Jagella E, Tideiksaar R, Mulvihill M, et al. Alarm devices instead of restraints?. J Am Geriatr Soc. Feb. 1992;40(2):191. Exclusion Code: X2. [pmid: 1740608].
113 Jambunathan J, Bellaire K. Evaluating staff use of crisis prevention intervention techniques: a pilot study. Issues Ment Health Nurs. Nov-Dec. 1996;17(6):541-58. Exclusion Code: X4. [pmid: 9052093].
114 Janelli LM, Kanski GW. Music intervention with physically restrained patients. Rehabil Nurs. Jan-Feb. 1997;22(1):14-9. Exclusion Code: X4. [pmid: 9110838].
115 Jayakody K, Gibson RC, Kumar A, et al. Zuclopenthixol acetate for acute schizophrenia and similar serious mental illnesses. Cochrane Database Syst Rev. 2012;4. CD000525. Exclusion Code: X5. [pmid: 22513898].
116 Jin C, Sher L. Restrictive measures in a psychiatric hospital on weekdays versus on weekends or holidays. Can J Psychiatry. Jun. 1999;44(5):505-6. Exclusion Code: X2. [pmid: 10389617].
117 Jungfer HA, Schneeberger AR, Borgwardt S, et al. Reduction of seclusion on a hospital-wide level: successful implementation of a less restrictive policy. J Psychiatr Res. Jul. 2014;54:94-9. Exclusion Code: X9. [pmid: 24726637].
118 Kern RS, Kuehnel TG, Teuber J, et al. Multimodal cognitive-behavior therapy for borderline personality disorder with self-injurious behavior. Psychiatr Serv. Sep. 1997;48(9):1131-3. Exclusion Code: X3. [pmid: 9285971].
119 Kinon BJ, Ahl J, Rotelli MD, et al. Efficacy of accelerated dose titration of olanzapine with adjunctive lorazepam to treat acute agitation in schizophrenia. Am J Emerg Med. May. 2004;22(3):181-6. Exclusion Code: X7. [pmid: 15138953].
120 Kinsella C, Chaloner C, Brosnan C. An alternative to seclusion?. Nurs Times. May. 5-11. 1993;89(18):62-4. Exclusion Code: X2. [pmid: 8516133].
121 Knight M, Adkison L, Kovach JS. A comparison of multisensory and traditional interventions on inpatient psychiatry and geriatric neuropsychiatry units. J Psychosoc Nurs Ment Health Serv. Jan. 2010;48(1):24-31. Exclusion Code: X7. [pmid: 20102130].
122 Knight MM. Quality improvement initiatives to minimize seclusion and restraint. J Healthc Qual. Mar-Apr. 2005;27(2):20-5. Exclusion Code: X5. [pmid: 16190307].
123 Kontio R, Pitkanen A, Joffe G, et al. eLearning course may shorten the duration of mechanical restraint among psychiatric inpatients: a cluster-randomized trial. Nord J Psychiatry. Oct. 2014;68(7):443-9. Exclusion Code: X9. [pmid: 24274836].
124 Kostecka M, Zardecka M. The use of physical restraints in Polish psychiatric hospitals in 1989 and 1996. Psychiatr Serv. Dec. 1999;50(12):1637-8. Exclusion Code: X5. [pmid: 10577888].
125 Krakowski MI, Czobor P. A prospective longitudinal study of cholesterol and aggression in patients randomized to clozapine, olanzapine, and haloperidol. J Clin Psychopharmacol. Apr. 2010;30(2):198-200. Exclusion Code: X2. [pmid: 20520296].
126 Krakowski MI, Czobor P, Citrome L, et al. Atypical antipsychotic agents in the treatment of violent patients with schizophrenia and schizoaffective disorder. Arch Gen Psychiatry. Jun. 2006;63(6):622-9. Exclusion Code: X9. [pmid: 16754835].
127 Krakowski MI, Czobor P, Nolan KA. Atypical antipsychotics, neurocognitive deficits, and aggression in schizophrenic patients. J Clin Psychopharmacol. Oct. 2008;28(5):485-93. Exclusion Code: X9. [pmid: 18794642].
128 Kupas DF, Wydro GC. Patient restraint in emergency medical services systems. Prehosp Emerg Care. Jul-Sep. 2002;6(3):340-5. Exclusion Code: X2. [pmid: 12109581].
129 Lafeuille MH, Grittner AM, Fortier J, et al. Comparison of rehospitalization rates and associated costs among patients with schizophrenia receiving paliperidone palmitate or oral antipsychotics. Am J Health Syst Pharm. Mar. 1. 2015;72(5):378-89. Exclusion Code: X7. [pmid: 25694413].
130 Lafferty S, Davidson R. Putting the person first: The tidal model aims to provide acute inpatient nurses with a framework to guide person-centred care. Ment Health Today. Mar. 2006:31-3. Exclusion Code: X12. [pmid: 16548283].
131 Lamberti JS, Cummings S. Hands-on restraints in the treatment of multiple personality disorder. Hosp Community Psychiatry. Mar. 1992;43(3):283-4. Exclusion Code: X2. [pmid: 1555828].
132 Langenbach M. Assaults on staff. Psychiatr Serv. Jul. 1998;49(7):970-1. Exclusion Code: X2. [pmid: 9661239].
133 Lanza ML, Anderson J, Boisvert CM, et al. Assaultive behavior intervention in the Veterans Administration: psychodynamic group psychotherapy compared to cognitive behavior therapy. Perspect Psychiatr Care. Jul-Sep. 2002;38(3):89-97. Exclusion Code: X9. [pmid: 12385079].
134 LeBel J. First randomised controlled-trial research on seclusion and restraint reduction achieves intent. Evid Based Ment Health. May. 2014;17(2):40-1. Exclusion Code: X2. [pmid: 24648332].
135 Lee HK, Reddy TB, Travin S, et al. A trial of lithium citrate for the management of acute agitation of psychiatric inpatients: a pilot study. J Clin Psychopharmacol. Oct. 1992;12(5):361-2. Exclusion Code: X3. [pmid: 1479057].
136 Lee S, Gray R, Gournay K. Comparing the outcomes of the application of C&amp;R (general service) and SCIP in the management of disturbed behaviour in mental health care. J Ment Health. Jun. 2012;21(3):307-17. Exclusion Code: X9. [pmid: 22574957].
137 Lee SJ, Cox A, Whitecross F, et al. Sensory assessment and therapy to help reduce seclusion use with service users needing psychiatric intensive care. Journal of Psychiatric Intensive Care. 2010;6(02):83-90. Exclusion Code: X12.
138 LePage JP, DelBen K, Pollard S, et al. Reducing assaults on an acute psychiatric unit using a token economy: A 2-year follow-up. Behavioral Interventions. Jul. 2003;18(3):179-90. PMID: WOS:000184212200002. Exclusion Code: X9.
139 Lever JA, Molloy DW, Eagle DJ, et al. Use of physical restraints and their relationship to medication use in patients in four different institutional settings. Humane Med. Jan. 1994;10(1):17-27. Exclusion Code: X5. [pmid: 11659751].
140 Levin-Epstein M. The one-hour rule controversy. Behav Healthc. May. 2007;27(5):38-9. Exclusion Code: X2. [pmid: 17958246].
141 Lewis C, Sierzega G, Haines D. The creation of a behavioral health unit as part of the emergency department: one community hospital's two-year experience. J Emerg Nurs. Dec. 2005;31(6):548-54. Exclusion Code: X7. [pmid: 16308042].
142 Lewis M, Taylor K, Parks J. Crisis prevention management: a program to reduce the use of seclusion and restraint in an inpatient mental health setting. Issues Ment Health Nurs. Mar. 2009;30(3):159-64. Exclusion Code: X9. [pmid: 19291492].
143 Li C, Zhu S, Wang H, et al. Safety and efficacy of clonazepam, haloperidol and haloperidol combined with clonazepam in the treatment of schizophrenia with excitement and agitation. Shanghai Archives of Psychiatry. 2007;19(3):150-2. Exclusion Code: X1.
144 Liberman RP. Elimination of seclusion and restraint: a reasonable goal?. Psychiatr Serv. Apr. 2006;57(4):576. author reply -8. Exclusion Code: X2. [pmid: 16603760].
145 Lim HK, Kim JJ, Pae CU, et al. Comparison of risperidone orodispersible tablet and intramuscular haloperidol in the treatment of acute psychotic agitation: a randomized open, prospective study. Neuropsychobiology. 2010;62(2):81-6. Exclusion Code: X7. [pmid: 20523078].
146 Loucks J, Rutledge DN, Hatch B, et al. Rapid response team for behavioral emergencies. J Am Psychiatr Nurses Assoc. Mar. 2010;16(2):93-100. Exclusion Code: X2. [pmid: 21659266].
147 MacDonald K, Wilson M, Minassian A, et al. A naturalistic study of intramuscular haloperidol versus intramuscular olanzapine for the management of acute agitation. J Clin Psychopharmacol. Jun. 2012;32(3):317-22. Exclusion Code: X7. [pmid: 22544013].
148 MacDonald K, Wilson MP, Minassian A, et al. A retrospective analysis of intramuscular haloperidol and intramuscular olanzapine in the treatment of agitation in drug- and alcohol-using patients. Gen Hosp Psychiatry. Jul-Aug. 2010;32(4):443-5. Exclusion Code: X7. [pmid: 20633750].
149 Madan A, Borckardt JJ, Grubaugh AL, et al. Efforts to reduce seclusion and restraint use in a state psychiatric hospital: a ten-year perspective. Psychiatr Serv. Oct. 2014;65(10):1273-6. Exclusion Code: X4. [pmid: 25022602].
150 Maier GJ, Van Rybroek GJ, Mays DV. A report on staff injuries and ambulatory restraints: dealing with patient aggression. J Psychosoc Nurs Ment Health Serv. Nov. 1994;32(11):23-9. Exclusion Code: X9. [pmid: 7884688].
151 Mallya AR, Roos PD, Roebuck-Colgan K. Restraint, seclusion, and clozapine. J Clin Psychiatry. Nov. 1992;53(11):395-7. Exclusion Code: X9. [pmid: 1459970].
152 Martel M, Sterzinger A, Miner J, et al. Management of acute undifferentiated agitation in the emergency department: a randomized double-blind trial of droperidol, ziprasidone, and midazolam. Acad Emerg Med. Dec. 2005;12(12):1167-72. Exclusion Code: X7. [pmid: 16282517].
153 Martin KH. Improving staff safety through an aggression management program. Arch Psychiatr Nurs. Aug. 1995;9(4):211-5. Exclusion Code: X9. [pmid: 7668888].
154 Mattes JA. Oxcarbazepine in patients with impulsive aggression: a double-blind, placebo-controlled trial. J Clin Psychopharmacol. Dec. 2005;25(6):575-9. Exclusion Code: X9. [pmid: 16282841].
155 Mayor S. Restraint should be last resort for violent behaviour. BMJ. Feb. 26. 2005;330(7489):438. Exclusion Code: X2. [pmid: 15731134].
156 McCue RE, Urcuyo L, Lilu Y, et al. Reducing restraint use in a public psychiatric inpatient service. J Behav Health Serv Res. Apr-Jun. 2004;31(2):217-24. Exclusion Code: X9. [pmid: 15255229].
157 McLoughlin KA, Geller JL. The recovery model and seclusion and restraint. Psychiatr Serv. Jul. 2006;57(7):1045. Exclusion Code: X2. [pmid: 16816295].
158 McMahon M, Fisher L. Achieve ED restraint reduction. Nurs Manage. Jan. 2003;34(1):35-8. Exclusion Code: X2. [pmid: 12544581].
159 Meehan T, Fjeldsoe K, Stedman T, et al. Reducing aggressive behaviour and staff injuries: a multi-strategy approach. Aust Health Rev. May. 2006;30(2):203-10. Exclusion Code: X4. [pmid: 16646769].
160 Melle I, Friis S, Hauff E, et al. The importance of ward atmosphere in inpatient treatment of schizophrenia on short-term units. Psychiatr Serv. Jul. 1996;47(7):721-6. Exclusion Code: X12. [pmid: 8807685].
161 Minarik PA. Alternatives to physical restraints in acute care. Clin Nurse Spec. May. 1994;8(3):136. 62. Exclusion Code: X3. [pmid: 7874640].
162 Mistral W, Hall A, McKee P. Using therapeutic community principles to improve the functioning of a high care psychiatric ward in the UK. Int J Ment Health Nurs. Mar. 2002;11(1):10-7. Exclusion Code: X9. [pmid: 12400102].
163 Modestin J, Dal Pian D, Agarwalla P. Clozapine diminishes suicidal behavior: a retrospective evaluation of clinical records. J Clin Psychiatry. Apr. 2005;66(4):534-8. Exclusion Code: X12. [pmid: 15816798].
164 Möhler R, Richter T, Köpke S, et al. Interventions for preventing and reducing the use of physical restraints in long-term geriatric care. Cochrane Database of Syst Rev. Feb. 16. 2011;(2). CD007546. Exclusion Code: X9. [pmid: 21328295].
165 Morales E, Duphorne PL. Least restrictive measures: alternatives to four-point restraints and seclusion. J Psychosoc Nurs Ment Health Serv. Oct. 1995;33(10):13-6. Exclusion Code: X12. [pmid: 8847668].
166 Morrison EF. An evaluation of four programs for the management of aggression in psychiatric settings. Arch Psychiatr Nurs. Aug. 2003;17(4):146-55. Exclusion Code: X3. [pmid: 14508770].
167 Morrison P, Lehane M. Staffing levels and seclusion use. J Adv Nurs. Dec. 1995;22(6):1193-202. Exclusion Code: X5. [pmid: 8675875].
168 Mortimer AM. Reducing violence on a secure ward. The Psychiatrist. 1995;19(10):605-8. Exclusion Code: X12.
169 Muralidharan S, Fenton M. Containment strategies for people with serious mental illness. Cochrane Database Syst Rev. 2006;(3). CD002084. Exclusion Code: X5. [pmid: 16855984].
170 Murphy S, Irving CB, Adams CE, et al. Crisis intervention for people with severe mental illnesses. Schizophr Bull. Jun. 2012;38(4):676-7. Exclusion Code: X9. [pmid: 22837350].
171 Nadler-Moodie M. Restraint debate. J Psychosoc Nurs Ment Health Serv. Jun. 2009;47(6):15. author reply -6. Exclusion Code: X2. [pmid: 19585797].
172 National Alliance on Mental Illness. Policy Topics: What are restraints and seclusion?. http://www.nami.org/Template.cfm?Section=issue_spotlights&template=/ContentManagement/ContentDisplay.cfm&ContentID=7803. 14 January 2015. Exclusion Code: X2.
173 National Association of State Mental Health Program Directors. Reducing the Use of Seclusion and Restraint: Findings, Strategies, and Recommendations. Alexandria, VA. 1999. Exclusion Code: X2.
174 National Association of State Mental Health Program Directors. Reducing the Use of Seclusion and Restraint PART II: Findings, Principles, and Recommendations for Special Needs Populations. Alexandria, VA. 2001. Exclusion Code: X2.
175 Needham I, Abderhalden C, Halfens RJ, et al. The effect of a training course in aggression management on mental health nurses' perceptions of aggression: a cluster randomised controlled trial. Int J Nurs Stud. Aug. 2005;42(6):649-55. Exclusion Code: X7. [pmid: 15982464].
176 Needham I, Abderhalden C, Meer R, et al. The effectiveness of two interventions in the management of patient violence in acute mental inpatient settings: report on a pilot study. J Psychiatr Ment Health Nurs. Oct. 2004;11(5):595-601. Exclusion Code: X4. [pmid: 15450028].
177 Nelstrop L, Chandler-Oatts J, Bingley W, et al. A systematic review of the safety and effectiveness of restraint and seclusion as interventions for the short-term management of violence in adult psychiatric inpatient settings and emergency departments. Worldviews Evid Based Nurs. 2006;3(1):8-18. Exclusion Code: X3. [pmid: 17040518].
178 New AS, Buchsbaum MS, Hazlett EA, et al. Fluoxetine increases relative metabolic rate in prefrontal cortex in impulsive aggression. Psychopharmacology (Berl). Nov. 2004;176(3-4):451-8. Exclusion Code: X12. [pmid: 15160265].
179 Nijman HL, Merckelbach HL, Allertz WF, et al. Prevention of aggressive incidents on a closed psychiatric ward. Psychiatr Serv. May. 1997;48(5):694-8. Exclusion Code: X9. [pmid: 9144826].
180 Nobay F, Simon BC, Levitt MA, et al. A prospective, double-blind, randomized trial of midazolam versus haloperidol versus lorazepam in the chemical restraint of violent and severely agitated patients. Acad Emerg Med. Jul. 2004;11(7):744-9. Exclusion Code: X7. [pmid: 15231461].
181 Nolan KA, Citrome L. Reducing inpatient aggression: does paying attention pay off?. Psychiatr Q. Jun. 2008;79(2):91-5. Exclusion Code: X9. [pmid: 17952595].
182 Owen C, Tarantello C, Jones M, et al. Violence and aggression in psychiatric units. Psychiatr Serv. Nov. 1998;49(11):1452-7. Exclusion Code: X5. [pmid: 9826247].
183 Palmstierna T, Wistedt B. Changes in the pattern of aggressive behaviour among inpatients with changed ward organization. Acta Psychiatr Scand. Jan. 1995;91(1):32-5. Exclusion Code: X5. [pmid: 7754783].
184 Park JS, Lee K. Modification of severe violent and aggressive behavior among psychiatric inpatients through the use of a short-term token economy. J Korean Acad Nurs. Dec. 2012;42(7):1062-9. Exclusion Code: X12. [pmid: 23377602].
185 Pascual JC, Oller S, Soler J, et al. Ziprasidone in the acute treatment of borderline personality disorder in psychiatric emergency services. J Clin Psychiatry. Sep. 2004;65(9):1281-2. Exclusion Code: X7. [pmid: 15367057].
186 Patel K, Khalid F, Cree A, et al. P.3.14 Specific antipsychotic medications—a treatment for aggressive behaviour in schizophrenia?. Eur Neuropsychopharmacol. 3. Supplement 1. 2008;18:s73-s4. Exclusion Code: X9.
187 Paterson B, Turnbull J, Aitken I. An evaluation of a training course in the short-term management of violence. Nurse Educ Today. Oct. 1992;12(5):368-75. Exclusion Code: X7. [pmid: 1448026].
188 Peek-Asa C, Cubbin L, Hubbell K. Violent events and security programs in California Emergency Departments before and after the 1993 Hospital Security Act. J Emerg Nurs. Oct. 2002;28(5):420-6. Exclusion Code: X4. [pmid: 12386623].
189 Phillips D, Rudestam KE. Effect of nonviolent self-defense training on male psychiatric staff members' aggression and fear. Psychiatr Serv. Feb. 1995;46(2):164-8. Exclusion Code: X4. [pmid: 7712254].
190 Powney MJ, Adams CE, Jones H. Haloperidol for psychosis-induced aggression or agitation (rapid tranquillisation). Cochrane Database Syst Rev. 2012;11. CD009377. Exclusion Code: X2. [pmid: 23152276].
191 Prescott DL, Madden LM, Dennis M, et al. Reducing mechanical restraints in acute psychiatric care settings using rapid response teams. J Behav Health Serv Res. Jan. 2007;34(1):96-105. Exclusion Code: X4. [pmid: 17103042].
192 Preval H, Klotz SG, Southard R, et al. Rapid-acting IM ziprasidone in a psychiatric emergency service: A naturalistic study. Gen Hosp Psychiatry. 2005;27(2):140-4. Exclusion Code: X4. [pmid: 15763126].
193 Putkonen A, Kuivalainen S, Louheranta O, et al. Cluster-randomized controlled trial of reducing seclusion and restraint in secured care of men with schizophrenia. Psychiatr Serv. Sep. 1. 2013;64(9):850-5. Exclusion Code: X9. [pmid: 23771480].
194 Rabinowitz J, Avnon M, Rosenberg V. Effect of clozapine on physical and verbal aggression. Schizophr Res. Dec. 15. 1996;22(3):249-55. Exclusion Code: X12. [pmid: 9000322].
195 Raja M, Azzoni A. Second-generation antipsychotics in the emergency care setting. A prospective naturalistic study. Gen Hosp Psychiatry. Mar-Apr. 2000;22(2):107-14. Exclusion Code: X11. [pmid: 10822097].
196 Rangecroft ME, Tyrer SP, Berney TP. The use of seclusion and emergency medication in a hospital for people with learning disability. Br J Psychiatry. Mar. 1997;170:273-7. Exclusion Code: X12. [pmid: 9229036].
197 Ratey JJ, Sorgi P, O'Driscoll GA, et al. Nadolol to treat aggression and psychiatric symptomatology in chronic psychiatric inpatients: a double-blind, placebo-controlled study. J Clin Psychiatry. Feb. 1992;53(2):41-6. Exclusion Code: X3. [pmid: 1347291].
198 Reynolds JR. The PACT model. Hosp Community Psychiatry. Mar. 1994;45(3):281-2. Exclusion Code: X2. [pmid: 8188207].
199 Rice ME. Controlling violence in adult psychiatric settings. Research Reports of the Penetanguishene (Ontario) Mental Health Centre. 1991;8(3):1-31. Exclusion Code: X13.
200 Rieth KA, Bennett CC. Restraint-free care. Part 1: Legal and regulatory mandates. Part 2: Creating a restraint-free environment. Nurs Manage. May. 1998;29(5):36-9. quiz 40. Exclusion Code: X4. [pmid: 9807412].
201 Sailas E, Wahlbeck K. Restraint and seclusion in psychiatric inpatient wards. Curr Opin Psychiatry. Sep. 2005;18(5):555-9. Exclusion Code: X2. [pmid: 16639118].
202 Salzman C, Solomon D, Miyawaki E, et al. Parenteral lorazepam versus parenteral haloperidol for the control of psychotic disruptive behavior. J Clin Psychiatry. Apr. 1991;52(4):177-80. Exclusion Code: X12. [pmid: 1673123].
203 Sanders K. The Effects of an Action Plan, Staff Training, Management Support and Monitoring on Restraint Use and Costs of Work-Related Injuries. Journal of Applied Research in Intellectual Disabilities. 2009;22(2):216-20. Exclusion Code: X4.
204 Scanlan JN. Interventions to reduce the use of seclusion and restraint in inpatient psychiatric settings: what we know so far a review of the literature. Int J Soc Psychiatry. Jul. 2010;56(4):412-23. Exclusion Code: X2. [pmid: 19617275].
205 Schott-Baer D, Lusis S, Beauregard K. Use of restraints; changes in nurses' attitudes. J Gerontol Nurs. Feb. 1995;21(2):39-44. Exclusion Code: X7. [pmid: 7884166].
206 Sclafani MJ, Humphrey FJ 2nd, Repko S, et al. Reducing patient restraints: a pilot approach using clinical case review. Perspect Psychiatr Care. Jan. 2008;44(1):32-9. Exclusion Code: X9. [pmid: 18177276].
207 Scott JG, Dean A. Tailoring seclusion policies to the patient group. Br J Psychiatry. Mar. 2008;192(3):232. author reply. Exclusion Code: X2. [pmid: 18310587].
208 Sedran RJ, Brubacher JR. The use and abuse of restraints. CMAJ. Nov. 17. 1998;159(10):1239-40. Exclusion Code: X2. [pmid: 9882150].
209 Shafti SS, Shahveisi B. Olanzapine versus haloperidol in the management of borderline personality disorder: a randomized double-blind trial. J Clin Psychopharmacol. Feb. 2010;30(1):44-7. Exclusion Code: X7. [pmid: 20075647].
210 Sharfstein SS. Commentary: reducing restraint and seclusion: a view from the trenches. Psychiatr Serv. Feb. 2008;59(2):197. Exclusion Code: X2. [pmid: 18245164].
211 Sheline Y, Beattie M. Effects of the right to refuse medication in an emergency psychiatric service. Hosp Community Psychiatry. Jun. 1992;43(6):640-2. Exclusion Code: X7. [pmid: 1351029].
212 Silver JM, Yudofsky SC, Slater JA, et al. Propranolol treatment of chronically hospitalized aggressive patients. J Neuropsychiatry Clin Neurosci. Summer. 1999;11(3):328-35. Exclusion Code: X3. [pmid: 10440008].
213 Sivak K. Implementation of comfort rooms to reduce seclusion, restraint use, and acting-out behaviors. J Psychosoc Nurs Ment Health Serv. Feb. 2012;50(2):24-34. Exclusion Code: X9. [pmid: 22439145].
214 Sjostrom N, Eder DN, Malm U, et al. Violence and its prediction at a psychiatric hospital. Eur Psychiatry. Dec. 2001;16(8):459-65. Exclusion Code: X9. [pmid: 11777736].
215 Smith GM, Ashbridge DM, Davis RH, et al. Correlation between reduction of seclusion and restraint and assaults by patients in Pennsylvania's state hospitals. Psychiatr Serv. Mar. 1. 2015;66(3):303-9. Exclusion Code: X9. [pmid: 25727119].
216 Smith GM, Davis RH, Bixler EO, et al. Pennsylvania State Hospital system's seclusion and restraint reduction program. Psychiatr Serv. Sep. 2005;56(9):1115-22. Exclusion Code: X9. [pmid: 16148327].
217 Smith NH, Timms J, Parker VG, et al. The impact of education on the use of physical restraints in the acute care setting. J Contin Educ Nurs. Jan-Feb. 2003;34(1):26-33. quiz 46-7. Exclusion Code: X4. [pmid: 12546131].
218 Smith S, Jones J. Use of a sensory room on an intensive care unit. J Psychosoc Nurs Ment Health Serv. May. 2014;52(5):22-30. Exclusion Code: X12. [pmid: 24305908].
219 Stanley KM, Amabile CM, Simpson KN, et al. Impact of an alcohol withdrawal syndrome practice guideline on surgical patient outcomes. Pharmacotherapy. Jul. 2003;23(7):843-54. Exclusion Code: X4. [pmid: 12885097].
220 Stanley KM, Worrall CL, Lunsford SL, et al. Experience with an adult alcohol withdrawal syndrome practice guideline in internal medicine patients. Pharmacotherapy. Aug. 2005;25(8):1073-83. Exclusion Code: X4. [pmid: 16207098].
221 Steinert T, Eisele F, Goeser U, et al. Successful interventions on an organisational level to reduce violence and coercive interventions in in-patients with adjustment disorders and personality disorders. Clin Pract Epidemiol Ment Health. 2008;4:27. Exclusion Code: X9. [pmid: 19014698].
222 Stevenson C, Barker P, Fletcher E. Judgement days: developing an evaluation for an innovative nursing model. J Psychiatr Ment Health Nurs. Jun. 2002;9(3):271-6. Exclusion Code: X9. [pmid: 12060370].
223 Strumpf NE, Evans LK, Wagner J, et al. Reducing physical restraints: developing an educational program. J Gerontol Nurs. Nov. 1992;18(11):21-7. Exclusion Code: X9. [pmid: 1430893].
224 Stubbs B, Yorston G, Knight C. Physical intervention to manage aggression in older adults: how often is it employed?. Int Psychogeriatr. Aug. 2008;20(4):855-7. Exclusion Code: X3. [pmid: 18366826].
225 Subramaney U, Brook S, Berk M. A prospective randomised double blind controlled study of the efficacy of Lorazepam versus Clothiapine in the control of acutely behaviourally disturbed patients. S Afr Med J. 1998;88(3):307-10. Exclusion Code: X10.
226 Substance Abuse and Mental Health Services Administration. Roadmap to Seclusion and Restraint Free Mental Health Services (CD). Washington, DC. U.S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration. 2006. http://store.samhsa.gov/product/Roadmap-to-Seclusion-and-Restraint-Free-Mental-Health-Services-CD-/SMA06-4055. 19 January 2015. Exclusion Code: X3.
227 Substance Abuse and Mental Health Services Administration. Alternatives to Seclusion and Restraint in Behavioral Health Care. Washington, DC. U.S. Department of Health and Human Services, Substance Abuse and Mental Health Services Administration. 2011. http://www.integration.samhsa.gov/clinical-practice/promoting_alternatives_to_seclusion_and_restraint.pdf. 19 January 2015. Exclusion Code: X3.
228 Sullivan AM, Bezmen J, Barron CT, et al. Reducing restraints: alternatives to restraints on an inpatient psychiatric service--utilizing safe and effective methods to evaluate and treat the violent patient. Psychiatr Q. Spring. 2005;76(1):51-65. Exclusion Code: X9. [pmid: 15757236].
229 Sullivan D, Wallis M, Lloyd C. Effects of patient-focused care on seclusion in a psychiatric intensive care unit. International Journal of Therapy and Rehabilitation. 2004;11(11):503-8. Exclusion Code: X12.
230 Swanson JW, Swartz MS, Van Dorn RA, et al. Comparison of antipsychotic medication effects on reducing violence in people with schizophrenia. Br J Psychiatry. Jul. 2008;193(1):37-43. Exclusion Code: X4. [pmid: 18700216].
231 Taxis JC. Ethics and praxis: alternative strategies to physical restraint and seclusion in a psychiatric setting. Issues Ment Health Nurs. Mar. 2002;23(2):157-70. Exclusion Code: X9. [pmid: 11901660].
232 Tebaldi C. Understanding involuntary hospitalization and use of seclusion and restraint. Nurse Pract. Jun. 10. 2012;37(6):13-6. Exclusion Code: X2. [pmid: 22635259].
233 Thomas B, Jones M, Johns P, et al. P.r.n. medication use in a psychiatric high-dependency unit following the introduction of a nurse-led activity programme. Int J Ment Health Nurs. Dec. 2006;15(4):266-71. Exclusion Code: X7. [pmid: 17064323].
234 Thomas H Jr., Schwartz E, Petrilli R. Droperidol versus haloperidol for chemical restraint of agitated and combative patients. Ann Emerg Med. Apr. 1992;21(4):407-13. Exclusion Code: X7. [pmid: 1554179].
235 Tunde-Ayinmode M, Little J. Use of seclusion in a psychiatric acute inpatient unit. Australas Psychiatry. Dec. 2004;12(4):347-51. Exclusion Code: X5. [pmid: 15715806].
236 van der Schaaf PS, Dusseldorp E, Keuning FM, et al. Impact of the physical environment of psychiatric wards on the use of seclusion. Br J Psychiatry. Feb. 2013;202:142-9. Exclusion Code: X3. [pmid: 23307922].
237 Visalli H, McNasser G. Striving toward a best practice model for a restraint-free environment. J Nurs Care Qual. Aug. 1997;11(6):1-4. Exclusion Code: X7. [pmid: 9267114].
238 Visalli H, McNasser G. Reducing seclusion and restraint: meeting the organizational challenge. J Nurs Care Qual. Jul. 2000;14(4):35-44. Exclusion Code: X2. [pmid: 10881448].
239 Visalli H, McNasser G, Johnstone L, et al. Reducing high-risk interventions for managing aggression in psychiatric settings. J Nurs Care Qual. Feb. 1997;11(3):54-61. Exclusion Code: X2. [pmid: 9029854].
240 Volavka J, Crowner M, Brizer D, et al. Tryptophan treatment of aggressive psychiatric inpatients. Biol Psychiatry. Oct. 15. 1990;28(8):728-32. Exclusion Code: X3. [pmid: 1978689].
241 Volavka J, Czobor P, Citrome L, et al. Effectiveness of antipsychotic drugs against hostility in patients with schizophrenia in the Clinical Antipsychotic Trials of Intervention Effectiveness (CATIE) study. CNS Spectrums. 19(5):374-81. Exclusion Code: X7. [pmid: 24284234].
242 Volavka J, Czobor P, Nolan K, et al. Overt aggression and psychotic symptoms in patients with schizophrenia treated with clozapine, olanzapine, risperidone, or haloperidol. J Clin Psychopharmacol. Apr. 2004;24(2):225-8. Exclusion Code: X9. [pmid: 15206671].
243 Volavka J, Zito JM, Vitrai J, et al. Clozapine effects on hostility and aggression in schizophrenia. J Clin Psychopharmacol. Aug. 1993;13(4):287-9. Exclusion Code: X9. [pmid: 8376618].
244 Vruwink FJ, Mulder CL, Noorthoorn EO, et al. The effects of a nationwide program to reduce seclusion in the Netherlands. BMC Psychiatry. 2012;12:231. Exclusion Code: X5. [pmid: 23249413].
245 Wale JB, Belkin GS, Moon R. Reducing the use of seclusion and restraint in psychiatric emergency and adult inpatient services- improving patient-centered care. Perm J. Spring. 2011;15(2):57-62. Exclusion Code: X3. [pmid: 21841927].
246 Walsh E, Leese M, Byford S, et al. B229. Do violent patients benefit from intensive case management?. Schizophr Res. 2002;53:234. Exclusion Code: X9.
247 Walters H, Kay R. Developing a compassionate control strategy. Aust Nurs J. Oct. 2004 2013-09-06. 2004;12(4):21-3. Exclusion Code: X9.
248 Wang H, Guo X, Shen T. Safety and efficacy of quetiapine and haloperidol in the treatment of schizophrenia with excitement and agitation. Shanghai Archives of Psychiatry. 2005;17(5):271-4. Exclusion Code: X1.
249 Wanich CK, Sullivan-Marx EM, Gottlieb GL, et al. Functional status outcomes of a nursing intervention in hospitalized elderly. Image J Nurs Sch. Fall. 1992;24(3):201-7. Exclusion Code: X4. [pmid: 1521848].
250 Weintraub D, Spurlock M. Change in the rate of restraint use and falls on a psychogeriatric inpatient unit: impact of the health care financing administration's new restraint and seclusion standards for hospitals. J Geriatr Psychiatry Neurol. Summer. 2002;15(2):91-4. Exclusion Code: X4. [pmid: 12083599].
251 Weng YZ, Xiang YQ, Liberman RP. Psychiatric rehabilitation in a Chinese psychiatric hospital. Psychiatr Serv. Apr. 2005;56(4):401-3. Exclusion Code: X7. [pmid: 15812086].
252 Werner P, Cohen-Mansfield J, Koroknay V, et al. Reducing restraints. Impact on staff attitudes. J Gerontol Nurs. Dec. 1994;20(12):19-24. Exclusion Code: X9. [pmid: 7852708].
253 West LJ. The effect of an intervention on the risk of eruptive violence in the emergency department. New Haven, CO. Southern Connecticut State University. 2003. Exclusion Code: X4.
254 Whitecross F, Seeary A, Lee S. Measuring the impacts of seclusion on psychiatry inpatients and the effectiveness of a pilot single-session post-seclusion counselling intervention. Int J Ment Health Nurs. Dec. 2013;22(6):512-21. Exclusion Code: X3. [pmid: 23682907].
255 Whitman GR, Kim Y, Davidson LJ, et al. The impact of staffing on patient outcomes across specialty units. J Nurs Adm. Dec. 2002;32(12):633-9. Exclusion Code: X5. [pmid: 12483084].
256 Wieman DA, Camacho-Gonsalves T, Huckshorn KA, et al. Multisite study of an evidence-based practice to reduce seclusion and restraint in psychiatric inpatient facilities. Psychiatr Serv. Mar. 1. 2014;65(3):345-51. Exclusion Code: X4. [pmid: 24292685].
257 Wilkinson CL RNMSNMPA. An evaluation of an educational program on the management of assaultive behaviors. J Gerontol Nurs. Apr. 1999. 1999;25(4):6-11. 204143830. Exclusion Code: X4. [pmid: 10426029].
258 Wilson MP, MacDonald K, Vilke GM, et al. A comparison of the safety of olanzapine and haloperidol in combination with benzodiazepines in emergency department patients with acute agitation. J Emerg Med. Nov. 2012;43(5):790-7. Exclusion Code: X12. [pmid: 21601409].
259 Wilson MP, Pepper D, Currier GW, et al. The psychopharmacology of agitation: consensus statement of the american association for emergency psychiatry project Beta psychopharmacology workgroup. West J Emerg Med. Feb. 2012;13(1):26-34. Exclusion Code: X2. [pmid: 22461918].
260 Winston PA, Morelli P, Bramble J, et al. Improving patient care through implementation of nurse-driven restraint protocols. J Nurs Care Qual. Aug. 1999;13(6):32-46. Exclusion Code: X3. [pmid: 10476623].
261 Wolfaardt T, AUT University. Faculty of Health and Environmental Sciences. An evaluation of the efficacy of the six core strategies intervention to reduce seclusion and restraint episodes in an acute mental health unit : a dissertation submitted to Auckland University of Technology in the partial fulfilment of the requirements for the degree of Bachelor of Health Science (Honours) in Psychology. 2013. 2013. p. 1 online resource. Exclusion Code: X9.
262 Woo BK, Chan VT, Ghobrial N, et al. Comparison of two models for delivery of services in psychiatric emergencies. Gen Hosp Psychiatry. Nov-Dec. 2007;29(6):489-91. Exclusion Code: X5. [pmid: 18022041].
263 Wyant M, Diamond BI, O'Neal E, et al. The use of midazolam in acutely agitated psychiatric patients. Psychopharmacol Bull. 1990;26(1):126-9. Exclusion Code: X7. [pmid: 2371367].
264 Wystanski M. Assaultive behaviour in psychiatrically hospitalized elderly: a response to psychosocial stimulation and changes in pharmacotherapy. Int J Geriatr Psychiatry. Jul. 2000;15(7):582-5. Exclusion Code: X3. [pmid: 10918337].
265 Yildiz A, Sachs GS, Turgay A. Pharmacological management of agitation in emergency settings. Emerg Med J. Jul. 2003;20(4):339-46. Exclusion Code: X7. [pmid: 12835344].
266 Zook R. Developing a crisis response team. J Nurses Staff Dev. May-Jun. 2001;17(3):125-30. Exclusion Code: X4. [pmid: 11998671].