# Literature Search Strategies and Yields

## Published Literature

Table A1 PubMed Original Search, 7/23/15

Limited to date range of 1/1/1990 – present.

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Substance-Related Disorders”[Mesh] OR (“Mental Disorders”[MeSH] OR “Mood Disorders”[Mesh] OR “Schizophrenia and Disorders with Psychotic Features”[Mesh]OR Depression[Mesh] OR ((“Depressive Disorder, Major”[Mesh]) OR “Anxiety Disorders”[Mesh]) OR “Eating Disorders”[Mesh] OR “Personality Disorders”[Mesh] OR ((severe OR serious OR persistent) mental illness[Text Word]))) | 1050558 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Aggression”[Mesh] OR “Violence”[Mesh] OR (“Psychomotor Agitation”[Mesh]) OR “Hostility”[Mesh] OR “Crisis Intervention”[Mesh] OR “Restraint, Physical”[Mesh] OR “Patient Isolation”[Mesh] | 122256 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Antipsychotic Agents”[MeSH Terms] OR “Antipsychotic Agents”[nm]) OR “Valproic Acid”[Mesh] OR “Droperidol”[Mesh] OR “Promethazine”[Mesh] OR “Trazodone”[Mesh] OR “Amitriptyline”[Mesh] OR “Chlormethiazole”[Mesh] OR “Citalopram”[Mesh]) OR “Chlorpromazine”[Mesh] OR “topiramate” [Supplementary Concept] OR “Diphenhydramine”[Mesh] OR “Carbamazepine”[Mesh] OR “Pindolol”[Mesh] OR “Lithium Carbonate”[Mesh] OR “Hydroxyzine”[Mesh] OR “Nadolol”[Mesh] OR “Sertraline”[Mesh] OR “Diazepam”[Mesh] OR “lurasidone” [Supplementary Concept] OR “Metoprolol”[Mesh] OR “Lorazepam”[Mesh] OR “iloperidone” [Supplementary Concept] | 127794 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#2 OR #3) | 246849 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 AND #4 | 84055 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((“Hospitals, General”[Mesh]) OR “Emergency Service, Hospital”[Mesh] OR (“Hospitals, Psychiatric”[Mesh] OR “Psychiatric Department, Hospital”[Mesh]) OR “Inpatients”[Mesh] OR hospitalization [mesh])) | 250345 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #5 AND #6 | 5805 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((“Comparative Effectiveness Research”[Mesh] OR “Comparative Study” [Publication Type] OR “Pragmatic Clinical Trials as Topic”[Mesh]) OR comparison OR comparator OR comparative)) | 2352489 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #8) | 1121 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #8) Filters: Publication date from 1990/01/01; Humans; English | 844 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Crisis Intervention”[Majr] OR “Restraint, Physical”[Majr] OR “Patient Isolation”[Majr]) | 8503 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #6 AND #13) | 605 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #6 AND #13) Filters: Publication date from 1990/01/01; Humans; English | 363 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #5 AND #6 Filters: Clinical Trial; Randomized Controlled Trial | 714 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 OR #17 OR #19) Filters: Publication date from 1990/01/01; Humans; English | 1452 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Restraint, Physical”[Mesh] OR “Patient Isolation”[Mesh])) Filters:Publication date from 1990/01/01; Humans; English | 4669 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#27 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #25) Filters: Publication date from 1990/01/01; Humans; English | 134 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=27)
#29 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #6 AND #27) Filters: Publication date from 1990/01/01; Humans; English | 40 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#32 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Tranquilizing Agents/administration and dosage”[MAJR]) | 3614 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=32)
#37 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #2 AND #6 AND #32) Filters: Publication date from 1990/01/01; Humans; English | 17 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=37)
#41 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 OR #17 OR #19 OR #29 OR #37)) Filters: Publication date from 1990/01/01; Humans; English | 1471 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=41)

Table A2 PubMed Preliminary Update Search, 12/21/15 (incremental addition to Table A1)

Limited to date range of 1/1/2015 – present.

Search | Query | Items found
#18 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Substance-Related Disorders”[Mesh] OR (“Mental Disorders”[MeSH] OR “Mood Disorders”[Mesh] OR “Schizophrenia and Disorders with Psychotic Features”[Mesh]OR Depression[Mesh] OR ((“Depressive Disorder, Major”[Mesh]) OR “Anxiety Disorders”[Mesh]) OR “Eating Disorders”[Mesh] OR “Personality Disorders”[Mesh] OR ((severe OR serious OR persistent) mental illness[Text Word])))) | 1081546 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=18)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Aggression”[Mesh] OR “Violence”[Mesh] OR (“Psychomotor Agitation”[Mesh]) OR “Hostility”[Mesh] OR “Crisis Intervention”[Mesh] OR “Restraint, Physical”[Mesh] OR “Patient Isolation”[Mesh] | 126109 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#20 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Antipsychotic Agents”[MeSH Terms] OR “Antipsychotic Agents”[nm]) OR “Valproic Acid”[Mesh] OR “Droperidol”[Mesh] OR “Promethazine”[Mesh] OR “Trazodone”[Mesh] OR “Amitriptyline”[Mesh] OR “Chlormethiazole”[Mesh] OR “Citalopram”[Mesh]) OR “Chlorpromazine”[Mesh] OR “topiramate” [Supplementary Concept] OR “Diphenhydramine”[Mesh] OR “Carbamazepine”[Mesh] OR “Pindolol”[Mesh] OR “Lithium Carbonate”[Mesh] OR “Hydroxyzine”[Mesh] OR “Nadolol”[Mesh] OR “Sertraline”[Mesh] OR “Diazepam”[Mesh] OR “lurasidone” [Supplementary Concept] OR “Metoprolol”[Mesh] OR “Lorazepam”[Mesh] OR “iloperidone” [Supplementary Concept] | 132065 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=20)
#21 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#19 OR #20) | 254897 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=21)
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#18 AND #21) | 86302 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((“Hospitals, General”[Mesh]) OR “Emergency Service, Hospital”[Mesh] OR (“Hospitals, Psychiatric”[Mesh] OR “Psychiatric Department, Hospital”[Mesh]) OR “Inpatients”[Mesh] OR hospitalization [mesh])) | 261616 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)
#24 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#22 AND #23) | 5922 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=24)
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((“Comparative Effectiveness Research”[Mesh] OR “Comparative Study” [Publication Type] OR “Pragmatic Clinical Trials as Topic”[Mesh]) OR comparison OR comparator OR comparative)) | 2387120 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)
#26 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#24 AND #25) | 1139 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=26)
#29 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#24 AND #25) Filters: Publication date from 2015/01/01; Humans; English | 11 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=29)
#30 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Crisis Intervention”[Majr] OR “Restraint, Physical”[Majr] OR “Patient Isolation”[Majr]) | 8607 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=30)
#31 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#18 AND #23 AND #30) | 610 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=31)
#34 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#18 AND #23 AND #30) Filters: Publication date from 2015/01/01; Humans; English | 2 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=34)
#37 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search Search (#22 AND #23) Filters: Clinical Trial; Randomized Controlled Trial; Publication date from 2015/01/01; Humans; English | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=37)
#41 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#29 OR #34 OR #37) | 15 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=41)

Table A3 PubMed Final Update Search, 1/16/16 (incremental addition to Tables A2 and A3)

Limited to date range of 6/1/2015 – present.

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Substance-Related Disorders”[Mesh] OR (“Mental Disorders”[MeSH] OR “Mood Disorders”[Mesh] OR “Schizophrenia and Disorders with Psychotic Features”[Mesh]OR Depression[Mesh] OR ((“Depressive Disorder, Major”[Mesh]) OR “Anxiety Disorders”[Mesh]) OR “Eating Disorders”[Mesh] OR “Personality Disorders”[Mesh] OR ((severe OR serious OR persistent) mental illness[Text Word]))) | 1087588 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Aggression”[Mesh] OR “Violence”[Mesh] OR (“Psychomotor Agitation”[Mesh]) OR “Hostility”[Mesh] OR “Crisis Intervention”[Mesh] OR “Restraint, Physical”[Mesh] OR “Patient Isolation”[Mesh] | 126789 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Antipsychotic Agents”[MeSH Terms] OR “Antipsychotic Agents”[nm]) OR “Valproic Acid”[Mesh] OR “Droperidol”[Mesh] OR “Promethazine”[Mesh] OR “Trazodone”[Mesh] OR “Amitriptyline”[Mesh] OR “Chlormethiazole”[Mesh] OR “Citalopram”[Mesh]) OR “Chlorpromazine”[Mesh] OR “topiramate” [Supplementary Concept] OR “Diphenhydramine”[Mesh] OR “Carbamazepine”[Mesh] OR “Pindolol”[Mesh] OR “Lithium Carbonate”[Mesh] OR “Hydroxyzine”[Mesh] OR “Nadolol”[Mesh] OR “Sertraline”[Mesh] OR “Diazepam”[Mesh] OR “lurasidone” [Supplementary Concept] OR “Metoprolol”[Mesh] OR “Lorazepam”[Mesh] OR “iloperidone” [Supplementary Concept] | 132478 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#2 OR #3) | 255973 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #1 AND #4 | 86752 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#6 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((“Hospitals, General”[Mesh]) OR “Emergency Service, Hospital”[Mesh] OR (“Hospitals, Psychiatric”[Mesh] OR “Psychiatric Department, Hospital”[Mesh]) OR “Inpatients”[Mesh] OR hospitalization [mesh])) | 263499 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=6)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search #5 AND #6 | 5953 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((“Comparative Effectiveness Research”[Mesh] OR “Comparative Study” [Publication Type] OR “Pragmatic Clinical Trials as Topic”[Mesh]) OR comparison OR comparator OR comparative)) | 2397046 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 AND #8) Filters: Publication date from 2015/06/01; Humans; English | 4 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Crisis Intervention”[Majr] OR “Restraint, Physical”[Majr] OR “Patient Isolation”[Majr])) | 8636 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #6 AND #15) Filters: Publication date from 2015/06/01; Humans; English | 2 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#22 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#5 AND #6) Filters: Clinical Trial; Randomized Controlled Trial; Publication date from 2015/06/01; Humans; English | 1 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=22)
#25 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#13 OR #19 OR #22) Filters: Publication date from 2015/06/01; Humans; English | 6 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=25)

Table A4 First (of two) corrections to PubMed Update Search, 2/3/16 (expanded search by combining search for “Emergency services, psychiatric” MeSH term with psychiatric condition terms)

Limited to date range of 1/1/1980 – present.

Search | Query | Items found
#1 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search Prog Neuropsychopharmacol Biol Psychiatry[Jour] AND 32[volume] AND 405[page] AND 2008[pdat] | 1 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=1)
#2 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Substance-Related Disorders”[Mesh] OR (“Mental Disorders”[MeSH] OR “Mood Disorders”[Mesh] OR “Schizophrenia and Disorders with Psychotic Features”[Mesh]OR Depression[Mesh] OR ((“Depressive Disorder, Major”[Mesh]) OR “Anxiety Disorders”[Mesh]) OR “Eating Disorders”[Mesh] OR “Personality Disorders”[Mesh] OR ((severe OR serious OR persistent) mental illness[Text Word])))) | 1087914 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=2)
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #2) | 1 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((“Hospitals, General”[Mesh]) OR “Emergency Service, Hospital”[Mesh] OR (“Hospitals, Psychiatric”[Mesh] OR “Psychiatric Department, Hospital”[Mesh]) OR “Inpatients”[Mesh] OR hospitalization [mesh])) | 263598 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#5 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#1 AND #4) | 0 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=5)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search Emergency Services, Psychiatric[mesh] | 2190 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 NOT #4) | 1245 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 NOT #4) Filters: Humans | 1195 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#10 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#7 NOT #4) Filters: Humans; English | 946 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=10)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((“Aggression”[Mesh] OR “Violence”[Mesh] OR (“Psychomotor Agitation”[Mesh]) OR “Hostility”[Mesh] OR “Crisis Intervention”[Mesh] OR “Restraint, Physical”[Mesh] OR “Patient Isolation”[Mesh])) OR (“Antipsychotic Agents”[MeSH Terms] OR “Antipsychotic Agents”[nm]) OR “Valproic Acid”[Mesh] OR “Droperidol”[Mesh] OR “Promethazine”[Mesh] OR “Trazodone”[Mesh] OR “Amitriptyline”[Mesh] OR “Chlormethiazole”[Mesh] OR “Citalopram”[Mesh]) OR “Chlorpromazine”[Mesh] OR “topiramate” [Supplementary Concept] OR “Diphenhydramine”[Mesh] OR “Carbamazepine”[Mesh] OR “Pindolol”[Mesh] OR “Lithium Carbonate”[Mesh] OR “Hydroxyzine”[Mesh] OR “Nadolol”[Mesh] OR “Sertraline”[Mesh] OR “Diazepam”[Mesh] OR “lurasidone” [Supplementary Concept] OR “Metoprolol”[Mesh] OR “Lorazepam”[Mesh] OR “iloperidone” [Supplementary Concept]) Filters: Humans; English | 176883 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Filters: Humans; English | 349 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#2 AND #12) Filters: Humans; English | 272 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((“Comparative Effectiveness Research”[Mesh] OR “Comparative Study” [Publication Type] OR “Pragmatic Clinical Trials as Topic”[Mesh]) OR comparison OR comparator OR comparative)) Filters: Humans; English | 1291760 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#13 AND #14) | 28 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Crisis Intervention”[Majr] OR “Restraint, Physical”[Majr] OR “Patient Isolation”[Majr])) Filters: Humans; English | 5436 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#17 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#2 AND #10 AND #16) Filters: Humans; English | 57 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=17)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#10 AND #11) Filters: Randomized Controlled Trial; Clinical Trial; Humans; English | 18 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)
#23 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#19 OR #17 OR #15) Filters: Publication date from 1980/01/01; Humans; English | 60 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=23)

Table A5 Second (of two) corrections to PubMed Update Search, 2/3/16 (expanded search for records indexed using “Psychiatric Nursing” MeSH term without any psychiatric condition or setting terms)

Limited to date range of 1/1/1980 – present.

Search | Query | Items found
#3 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Psychiatric Nursing”[Mesh] | 15909 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=3)
#4 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (“Aggression”[Mesh] OR “Violence”[Mesh] OR (“Psychomotor Agitation”[Mesh]) OR “Hostility”[Mesh] OR “Crisis Intervention”[Mesh] OR “Restraint, Physical”[Mesh] OR “Patient Isolation”[Mesh] | 126878 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=4)
#7 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search “Antipsychotic Agents”[MeSH Terms] OR “Antipsychotic Agents”[nm]) OR “Valproic Acid”[Mesh] OR “Droperidol”[Mesh] OR “Promethazine”[Mesh] OR “Trazodone”[Mesh] OR “Amitriptyline”[Mesh] OR “Chlormethiazole”[Mesh] OR “Citalopram”[Mesh]) OR “Chlorpromazine”[Mesh] OR “topiramate” [Supplementary Concept] OR “Diphenhydramine”[Mesh] OR “Carbamazepine”[Mesh] OR “Pindolol”[Mesh] OR “Lithium Carbonate”[Mesh] OR “Hydroxyzine”[Mesh] OR “Nadolol”[Mesh] OR “Sertraline”[Mesh] OR “Diazepam”[Mesh] OR “lurasidone” [Supplementary Concept] OR “Metoprolol”[Mesh] OR “Lorazepam”[Mesh] OR “iloperidone” [Supplementary Concept] | 132533 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=7)
#8 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#4 OR #7) | 256116 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=8)
#9 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#3 AND #8) | 1458 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=9)
#11 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((“Substance-Related Disorders”[Mesh] OR (“Mental Disorders”[MeSH] OR “Mood Disorders”[Mesh] OR “Schizophrenia and Disorders with Psychotic Features”[Mesh] OR Depression[Mesh] OR ((“Depressive Disorder, Major”[Mesh]) OR “Anxiety Disorders”[Mesh]) OR “Eating Disorders”[Mesh] OR “Personality Disorders”[Mesh] OR ((severe OR serious OR persistent) mental illness[Text Word])))) | 1088471 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=11)
#12 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#9 NOT #11) | 848 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=12)
#13 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search ((((“Hospitals, General”[Mesh]) OR “Emergency Service, Hospital”[Mesh] OR (“Hospitals, Psychiatric”[Mesh] OR “Psychiatric Department, Hospital”[Mesh]) OR “Inpatients”[Mesh] OR hospitalization [mesh])) | 263822 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=13)
#14 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#12 NOT #13) | 683 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=14)
#15 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (((“Comparative Effectiveness Research”[Mesh] OR “Comparative Study” [Publication Type] OR “Pragmatic Clinical Trials as Topic”[Mesh]) OR comparison OR comparator OR comparative)) | 2398633 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=15)
#16 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 AND #15) | 23 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=16)
#19 (http://www.ncbi.nlm.nih.gov/pubmed/advanced) | Search (#14 AND #15) Filters: Publication date from 1980/01/01; Humans; English | 20 (http://www.ncbi.nlm.nih.gov/pubmed/?cmd=HistorySearch&querykey=19)

Table A6 Cochrane Original Library Search for Reviews, 7/23/15

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 18

Table A7 Cochrane Update Library Search for Reviews, 1/16/16

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 2

Table A8 Cochrane Original Library Search for Clinical Trials, 7/23/15

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 8

Table A9 Cochrane Update Library Search for Clinical Trials, 1/16/16

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 0

Table A10 CINAHL Original Search, 7/23/15

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 5

Table A11 CINAHL Update Search, 1/16/16

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 4

Table A12 PsycINFO Original Search, 7/23/15

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 21

Table A13 PsycINFO Update Search, 1/16/16

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 7

Table A14 EMBASE Original Search, 7/23/15

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 88

Table A15 EMBASE Update Search, 1/16/16

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 7

## Gray Literature

Table A16 Academic Search™ Premier, Original Search, 7/23/15

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 30

Table A17 Academic Search™ Premier, Update Search, 1/16/16

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 6

Table A18 ClinicalTrials.gov, Original Search, 7/23/15

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 1

Table A19 ClinicalTrials.gov, Update Search, 1/16/16

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 3

Table A20 NIH RePORTer, Original Search, 7/23/15

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 1

Table A21 NIH RePORTer, Update Search, 1/16/16

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 1

Table A22 WHOLIS, Original Search, 7/23/15

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 0

Table A23 WHOLIS, Update Search, 1/16/16

No limits based on publication date.

ID | Search | Hits
#1 | [(serious OR severe OR persistent) mental illness] AND [“crisis intervention” OR violence OR aggression OR agitation OR hostility OR “physical restraint” OR “isolation” OR “antipsychotic”] AND [comparative OR comparison] AND [hospitalization OR hospital OR “emergency department”] | 0