# Summary and Discussion

A succinct summary of evidence on comparative long-term benefits and harms of ACE inhibitors and/or ARBs in patients with preserved left ventricular function who have stable ischemic heart disease or heart disease risk equivalents is presented in Table 15. More elaborate discussions are provided at the end of the results for each Key Question. More detailed assessments of strength of evidence for major clinical outcomes and harms are summarized in a EPC grading table of evidence (Appendix Tables 41–47). Major clinical outcomes are those explicitly stated in Key Questions 1–3 and 7 and harms in Key Questions 4–6. Members of the TEP identified these outcomes as important because they are most relevant to patients, clinicians, and policymakers; and have adequate data from studies meeting eligibility criteria for the comparative effectiveness review. Clinical outcomes included total mortality, cardiovascular mortality, nonfatal myocardial infarction, stroke, a composite of cardiovascular mortality, nonfatal myocardial infarction and stroke, atrial fibrillation, symptom reporting, total hospitalizations, hospitalization for angina, hospitalization for heart failure, revascularization and quality of life. Harms included withdrawals due to adverse events, hypotension, syncope, cough, angioedema, hyperkalemia, rash, and blood dyscrasias.

Table 15 Outcomes, strength of evidence, and conclusions

Key Question | Strength of evidence | Conclusions
KQ1. In patients with stable ischemic heart disease or ischemic heart disease risk equivalents who have preserved left ventricular systolic function, what is the comparative effectiveness of ACE inhibitors or ARBs added to standard medical therapy when compared to standard medical therapy alone in terms of total mortality, cardiovascular mortality, nonfatal myocardial infarction, stroke, the composite endpoint of latter three items, and atrial fibrillation? What is the evidence of benefit on other outcomes such as symptom reporting, hospitalization, revascularization, and quality of life measures?
KQ1a. Total mortality | High High Moderate | - ACE inhibitor or ARB therapy is better than placebo in patients with stable ischemic heart disease; - ACE inhibitors (enalapril, perindopril, ramipril, trandolapril) are better than placebo in patients with stable ischemic heart disease.; - ARB therapy (telmisartan) is similar to placebo in patients with stable ischemic heart disease.
KQ1a. Total mortality | Moderate Moderate Insufficient | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to calcium channel blockers in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, imidapril, lisinopril^*^) are similar to calcium channel blockers (amlodipine, nifedipine) in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. calcium channel blockers in patients with stable ischemic heart disease.
KQ1a. Total mortality | Low Low Insufficient | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to placebo in patients with stable ischemic heart disease risk equivalents.; - ACE inhibitors (fosinopril) are similar to placebo in patients with stable ischemic heart disease risk equivalents.; - ARB therapy was not evaluated vs. placebo in patients with stable ischemic heart disease risk equivalents.
KQ1b. Cardiovascular mortality | Moderate Moderate Moderate | - ACE inhibitor or ARB therapy is similar to placebo in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, perindopril, ramipril, trandolapril) are better than placebo in patients with stable ischemic heart disease.; - ARB therapy (telmisartan) is similar to placebo in patients with stable ischemic heart disease.
KQ1b. Cardiovascular mortality | Moderate Moderate Insufficient | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to calcium channel blockers in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, imidapril, lisinopril^*^) are similar to calcium channel blockers (amlodipine, nifedipine) in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. calcium channel blockers in patients with stable ischemic heart disease.
KQ1b. Cardiovascular mortality | Moderate Moderate Insufficient | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to placebo in patients with ischemic heart disease risk equivalents.; - ACE inhibitors (fosinopril) are similar to placebo in patients with stable ischemic heart disease risk equivalents.; - ARB therapy was not evaluated vs. placebo in patients with stable ischemic heart disease risk equivalents.
KQ1c. Nonfatal myocardial infarction | High High Insufficient | - ACE inhibitor or ARB therapy (ARB not evaluated) is better than placebo in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, perindopril, ramipril, trandolapril) are better than placebo in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. placebo in patients with stable ischemic heart disease.
KQ1c. Nonfatal myocardial infarction | Moderate Moderate Insufficient | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to calcium channel blockers in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril) are similar to calcium channel blockers (amlodipine) in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. calcium channel blockers in patients with stable ischemic heart disease.
KQ1c. Nonfatal myocardial infarction | Low Low Insufficient | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to placebo in patients with ischemic heart disease risk equivalents.; - ACE inhibitors (fosinopril) are similar to placebo in patients with stable ischemic heart disease risk equivalents.; - ARB therapy was not evaluated vs. placebo in patients with stable ischemic heart disease risk equivalents.
KQ1d. Stroke | Moderate Moderate Moderate | - ACE inhibitor or ARB therapy is better than placebo in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, perindopril, ramipril, trandolapril) are better than placebo in patients with stable ischemic heart disease.; - ARB therapy (telmisartan) is similar to placebo in patients with stable ischemic heart disease.
KQ1d. Stroke | Moderate Moderate Insufficient | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to calcium channel blockers in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, imidapril, lisinopril^*^) are similar to calcium channel blockers (amlodipine, nifedipine) in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. calcium channel blockers in patients with stable ischemic heart disease.
KQ1d. Stroke | Low Low Insufficient | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to placebo in patients with ischemic heart disease risk equivalents.; - ACE inhibitors (fosinopril) are similar to placebo in patients with stable ischemic heart disease risk equivalents.; - ARB therapy was not evaluated vs. placebo in patients with stable ischemic heart disease risk equivalents.
KQ1e. Composite of cardiovascular mortality, nonfatal myocardial infarction, or stroke | High Moderate Moderate | - ACE inhibitor or ARB therapy is better than placebo in patients with stable ischemic heart disease.; - ACE inhibitors (ramipril, trandolapril) are similar placebo in patients with stable ischemic heart disease.; - ARB therapy (telmisartan) is better than placebo in patients with stable ischemic heart disease.
KQ1e. Composite of cardiovascular mortality, nonfatal myocardial infarction, or stroke | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to calcium channel blockers in patients with stable ischemic heart disease.
KQ1e. Composite of cardiovascular mortality, nonfatal myocardial infarction, or stroke | Low Low Insufficient | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to placebo in patients with ischemic heart disease risk equivalents.; - ACE inhibitors (fosinopril) are similar to placebo in patients with stable ischemic heart disease risk equivalents.; - ARB therapy was not evaluated vs. placebo in patients with stable ischemic heart disease risk equivalents.
KQ1f. Atrial fibrillation | High | - ACE inhibitor (ramipril) or ARB (telmisartan) therapy is similar to placebo in patients with stable ischemic heart disease.
KQ1f. Atrial fibrillation | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to calcium channel blockers in patients with stable ischemic heart disease.
KQ1f. Atrial fibrillation | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo in patients with ischemic heart disease risk equivalents.
KQ1g. Symptom reporting | Moderate | - ACE inhibitor (zofenopril) therapy increases the time to onset of ischemic symptoms via treadmill exercise test versus placebo in patients with stable ischemic heart disease.
KQ1g. Symptom reporting | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to calcium channel blockers in patients with stable ischemic heart disease.
KQ1g. Symptom reporting | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo in patients with ischemic heart disease risk equivalents.
KQ1h. Total hospitalization | Moderate | - ACE inhibitor (ramipril) or ARB therapy (telmisartan) is similar to placebo in patients with stable ischemic heart disease.
KQ1h. Total hospitalization | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to calcium channel blockers in patients with stable ischemic heart disease.
KQ1h. Total hospitalization | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo in patients with ischemic heart disease risk equivalents.
KQ1i. Hospitalization for angina | High | - ACE inhibitor (enalapril, ramipril) or ARB (telmisartan) therapy is similar to placebo in patients with stable ischemic heart disease.
KQ1i. Hospitalization for angina | Moderate | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to calcium channel blockers in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, imidapril, lisinopril^*^) are similar to calcium channel blockers (amlodipine, nifedipine) in patients with stable ischemic heart disease; - ARB therapy was not evaluated vs. calcium channel blockers in patients with stable ischemic heart disease.
KQ1i. Hospitalization for angina | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo in patients with ischemic heart disease risk equivalents.
KQ1j. Hospitalization for heart failure | High High Moderate | - ACE inhibitor or ARB therapy is better than placebo in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, perindopril, ramipril, trandolapril) are better than placebo in patients with stable ischemic heart disease.; - ARB therapy (telmisartan) is similar to placebo in patients with stable ischemic heart disease.
KQ1j. Hospitalization for heart failure | Moderate Moderate Insufficient | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to calcium channel blockers in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, imidapril, lisinopril^*^) are similar to calcium channel blockers (amlodipine, nifedipine) in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. calcium channel blockers in patients with stable ischemic heart disease.
KQ1j. Hospitalization for heart failure | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo in patients with ischemic heart disease risk equivalents.
KQ1k. Revascularization | High High Moderate | - ACE inhibitor or ARB therapy is better than placebo in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, perindopril, ramipril) are better than placebo in patients with stable ischemic heart disease.; - ARB therapy (telmisartan) is similar to placebo in patients with stable ischemic heart disease.
KQ1k. Revascularization | Moderate Moderate Insufficient | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to calcium channel blockers in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, imidapril, lisinopril^*^) are similar to calcium channel blockers (amlodipine, nifedipine) in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. calcium channel blockers in patients with stable ischemic heart disease.
KQ1k. Revascularization | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo in patients with ischemic heart disease risk equivalents.
KQ1l. Quality of life | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to either placebo or calcium channel blockers in patients with ischemic heart disease or ischemic heart disease risk equivalents.
KQ1 Discussion: Patients with stable ischemic heart disease and preserved left ventricular function benefit from receiving ACE inhibitors, and perhaps ARBs as well, in addition to standard medical therapy, but may not benefit more than using calcium channel blockers in addition to standard medical therapy. Future research is needed to determine if ACE inhibitors or ARBs offer additional benefits over other vasoactive drugs. The TRANSCEND trial was the only placebo controlled trial available to evaluate major efficacy outcomes for ARB therapy. ARB therapy was associated with similar reductions in the composite endpoint of cardiovascular mortality, nonfatal myocardial infarction, and stroke as the pooled results from the HOPE and PEACE trials comparing ACE inhibitors versus placebo. While major ACE inhibitor trials utilized a run-in period to ensure that subjects tolerated ACE inhibitor therapy, subjects in TRANSCEND were intolerant of ACE inhibitors and may represent a distinct population. This reduces confidence indirect comparisons and direct evidence comparing ACE inhibitors and ARBs (evaluated in KQ2) should be considered.
KQ2. In patients with stable ischemic heart disease or ischemic heart disease risk equivalents who have preserved left ventricular systolic function and are receiving standard medical therapy, what is the comparative effectiveness of combining ACE inhibitors and ARBs vs. either an ACE inhibitor or ARB alone in terms of total mortality, cardiovascular mortality, nonfatal myocardial infarction, stroke, the composite endpoint of the latter three items, and atrial fibrillation? What is the evidence of benefit on other outcomes such as symptom reporting, hospitalization, revascularization, and quality of life measures?
KQ2a. Total mortality | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) is similar to ACE inhibitor (ramipril) alone in patients with stable ischemic heart disease.
KQ2b. Cardiovascular mortality | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) is similar to ACE inhibitor (ramipril) alone in patients with stable ischemic heart disease.
KQ2c. Fatal + nonfatal myocardial infarction | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) is similar to ACE inhibitor (ramipril) alone in patients with stable ischemic heart disease.
KQ2d. Fatal + nonfatal stroke | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) is similar to ACE inhibitor (ramipril) alone in patients with stable ischemic heart disease.
KQ2e. Composite of cardiovascular mortality, fatal + nonfatal myocardial infarction, and fatal + nonfatal stroke | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) is similar to ACE inhibitor (ramipril) alone in patients with stable ischemic heart disease.
KQ2f. New atrial fibrillation | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) is similar to ACE inhibitor (ramipril) alone in patients with stable ischemic heart disease.
KQ2g. Worsening or new angina | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) is similar to ACE inhibitor (ramipril) alone in patients with stable ischemic heart disease.
KQ2h. Total hospitalization | Insufficient | - No data is available comparing the combination of ACE inhibitor + ARB therapy vs. ACE inhibitor therapy alone in patients with stable ischemic heart disease.
KQ2i. Hospitalization for angina | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) is similar to ACE inhibitor (ramipril) alone in patients with stable ischemic heart disease.
KQ2j. Hospitalization for heart failure | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) is similar to ACE inhibitor (ramipril) alone in patients with stable ischemic heart disease.
KQ2k. Revascularization | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) is similar to ACE inhibitor (ramipril) alone in patients with stable ischemic heart disease.
KQ2l. Quality of life | Insufficient | - No data is available comparing the combination of ACE inhibitor + ARB therapy vs. ACE inhibitor therapy alone in patients with stable ischemic heart disease.
KQ2 Discussion. There is direct comparative evidence from the ONTARGET trial that ACE inhibitors and ARBs provide similar benefits in major outcomes of interest in this population. Since ONTARGET directly compared the same drugs as was evaluated in the placebo controlled HOPE and TRANSCEND trials (ramipril and telmisartan), the direct evidence of similar benefit is more compelling than indirect evidence of possible differences from KQ1.
KQ3. In patients with ischemic heart disease and preserved left ventricular function who had to have recently undergone, or are set to undergo, a coronary revascularization procedure, what is the comparative effectiveness of ACE inhibitors or ARBs added to standard medical therapy when compared to standard medical therapy alone in terms of total mortality, cardiovascular mortality, nonfatal myocardial infarction, stroke, the composite endpoint of the latter three items, and atrial fibrillation? What is the evidence of benefit on other outcomes such as symptom reporting, hospitalization, revascularization, and quality of life measures?
KQ3a. Total mortality | Moderate | - ACE inhibitor (cilazapril, quinapril, ramipril) or ARB (candesartan) therapy is similar to placebo.
KQ3b. Cardiovascular mortality | Low | - ACE inhibitor (quinapril, ramipril) or ARB (candesartan) therapy is similar to placebo.
KQ3c. Nonfatal myocardial infarction | Low | - ACE inhibitor (cilazapril, quinapril) or ARB (candesartan) therapy is similar to placebo.
KQ3d. Stroke | Low | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to placebo.; - ACE inhibitors (quinapril, ramipril) are similar to placebo.; - ARB therapy was not evaluated vs. placebo.
KQ3e. Composite of cardiovascular mortality, nonfatal myocardial infarction, and stroke | Moderate | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to placebo.; - ACE inhibitors (quinapril) are similar to placebo.; - ARB therapy was not evaluated vs. placebo.
KQ3f. Atrial fibrillation | Moderate | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to placebo.; - ACE inhibitors (quinapril) are similar to placebo.; - ARB therapy was not evaluated vs. placebo.
KQ3g. Symptom reporting | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo.
KQ3h. Total hospitalization | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo.
KQ3i. Hospitalization for angina | Moderate | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to placebo.; - ACE inhibitors (quinapril, ramipril) are similar to placebo.; - ARB therapy was not evaluated vs. placebo.
KQ3j. Hospitalization for heart failure | Low | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to placebo.; - ACE inhibitors (quinapril, ramipril) are similar to placebo.; - ARB therapy was not evaluated vs. placebo.
KQ3k. Revascularization | High | - ACE inhibitor or ARB therapy is worse than placebo.; - ACE inhibitors (cilazapril, quinapril) are worse than placebo.; - ARB (candesartan) therapy is similar to placebo.
KQ3l. Quality of life | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo.
KQ3 Discussion. Trials compared the addition of ACE inhibitors or ARBs to standard medical therapy versus standard medical therapy alone (with or without a placebo). For our base case analysis, we limited the trials to randomized, double-blinded comparisons of ACE inhibitors or ARBs to placebo. ACE inhibitors or ARBs did not significantly impact any of the endpoints evaluated. However, with the exception of the “need for subsequent revascularization” endpoint, the incidence rates for the endpoints were low. Overall, the evidence from Key Question 3 suggests that initiation of ACE inhibitors or ARBs in close proximity to a revascularization procedure does not confer significant clinical benefit. However, Key Question 1 suggested that patients with established ischemic heart disease do derive significant clinical benefits from ACE inhibitor or ARB therapy in addition to standard medical therapy. Thus the question becomes, at what point following a cardiac revascularization procedure a patient with ischemic heart disease derives benefits from these agents? A majority of the trials included in Key Question 1, including HOPE, PEACE, and EUROPA, included patients that were at least 3 to 6 months removed from undergoing a coronary procedure. Thus it seems plausible that this period of time should be given following a revascularization procedure before ACE inhibitors or ARBs are initiated in these populations. However, no studies have prospectively investigated the optimal time to begin therapy and thus more concrete interpretations cannot be made until this evidence becomes available
KQ4. In patients with stable ischemic heart disease or ischemic heart disease risk equivalents who have preserved left ventricular systolic function, what are the comparative harms of adding ACE inhibitors or ARBs to standard medical therapy when compared to standard medical therapy alone?
KQ4a. Withdrawals due to adverse events | Low | - The risk of withdrawing from a trial was greater with ACE inhibitor or ARB therapy (ARB not evaluated) vs. placebo in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, ramipril, trandolapril) are worse than placebo in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. placebo in patients with stable ischemic heart disease.
KQ4a. Withdrawals due to adverse events | Low | - ACE inhibitor or ARB therapy (ARB not evaluated) is similar to calcium channel blockers in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, imidapril, lisinopril^*^) are similar to calcium channel blockers (amlodipine, nifedipine) in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. calcium channel blockers in patients with stable ischemic heart disease.
KQ4a. Withdrawals due to adverse events | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo in patients with ischemic heart disease risk equivalents.
KQ4b. Hypotension | Low | - The risk of hypotension was similar with ACE inhibitor or ARB therapy (ARB not evaluated) vs. placebo in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, ramipril, zofenopril) are similar to placebo in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. placebo in patients with stable ischemic heart disease.
KQ4b. Hypotension | Low | - The risk of hypotension with ACE inhibitor or ARB therapy (ARB not evaluated) is greater than calcium channel blockers in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril) are worse than calcium channel blockers (amlodipine) in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. calcium channel blockers in patients with stable ischemic heart disease.
KQ4b. Hypotension | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo in patients with ischemic heart disease risk equivalents.
KQ4c. Syncope | Low | - The risk of syncope with ACE inhibitor or ARB therapy (ARB not evaluated) was greater than placebo in patients with stable ischemic heart disease.; - ACE inhibitors (ramipril, trandolapril) are worse than placebo in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. placebo in patients with stable ischemic heart disease.
KQ4c. Syncope | Insufficient | - No data is available comparing ACE inhibitors or ARBs to calcium channel blockers in patients with ischemic heart disease.
KQ4c. Syncope | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo in patients with ischemic heart disease risk equivalents.
KQ4d. Cough | Low | - The risk of cough with ACE inhibitor or ARB therapy (ARB not evaluated) was greater than placebo in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril, ramipril, trandolapril) are worse than placebo in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. placebo in patients with stable ischemic heart disease.
KQ4d. Cough | Low | - The risk of cough with ACE inhibitor or ARB therapy (ARB not evaluated) is greater than calcium channel blockers in patients with stable ischemic heart disease.; - ACE inhibitors (enalapril) are worse than calcium channel blockers (amlodipine) in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. calcium channel blockers in patients with stable ischemic heart disease.
KQ4d. Cough | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo in patients with ischemic heart disease risk equivalents.
KQ4e. Angioedema | Low | - The risk of angioedema was similar with ACE inhibitor or ARB therapy (ARB not evaluated) vs. placebo in patients with stable ischemic heart disease.; - ACE inhibitors (ramipril, trandolapril) are similar to placebo in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. placebo in patients with stable ischemic heart disease.
KQ4e. Angioedema | Insufficient | - No data is available comparing ACE inhibitors or ARBs to calcium channel blockers in patients with ischemic heart disease.
KQ4e. Angioedema | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo in patients with ischemic heart disease risk equivalents.
KQ4f. Hyperkalemia | Low | - The risk hyperkalemia with ACE inhibitor (ramipril) or ARB (telmisartan) therapy is greater than placebo therapy in patients with stable ischemic heart disease.
KQ4f. Hyperkalemia | Insufficient | - No data is available comparing ACE inhibitors or ARBs to calcium channel blockers in patients with ischemic heart disease.
KQ4f. Hyperkalemia | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo in patients with ischemic heart disease risk equivalents.
KQ4g. Rash | Insufficient | - No data is available comparing ACE inhibitors or ARBs to placebo in patients with stable ischemic heart disease.
KQ4g. Rash | Insufficient | - No data is available comparing ACE inhibitors or ARBs to calcium channel blockers in patients with ischemic heart disease.
KQ4g. Rash | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo in patients with ischemic heart disease risk equivalents.
KQ4h. Blood dyscrasias | Insufficient | - No data is available comparing ACE inhibitors or ARBs to placebo in patients with stable ischemic heart disease.
KQ4h. Blood dyscrasias | Insufficient | - No data is available comparing ACE inhibitors or ARBs to calcium channel blockers in patients with ischemic heart disease.
KQ4h. Blood dyscrasias | Insufficient | - No data is available comparing ACE inhibitor or ARB therapy to placebo in patients with ischemic heart disease risk equivalents.
KQ4 Discussion. ACE inhibitors or ARBs significantly increase the risk of withdrawing due to adverse events, syncope, cough and hyperkalemia as compared with placebo. ACE inhibitors or ARBs significantly increased the risk of cough and hypotension as compared with CCBs. A number of the included trials included run-in periods in their study design. Thus, the true incidence of harms with these therapies in environments outside of clinical trials may be higher than those reported here. The unique design of the TRANSCEND trial, which compared telmisartan to placebo, deserves special discussion. All of the patients included in TRANSCEND were intolerant to ACE inhibitors at baseline. Following a median followup of 56 months, the ARB telmisartan was relatively well tolerated with only a statistically higher risk of hypotension symptoms as compared with placebo (p=0.049). Thus it appears that in patients with stable ischemic heart disease who cannot tolerate ACE inhibitors or are at an increased risk for harms, that ARBs may be a relatively safe alternative. Given the benefits seen in Key Question 1, the balance of benefits to harms for the use of ACE inhibitors or ARBs in patients with stable ischemic heart disease seems favorable.
KQ5. In patients with stable ischemic heart disease who have preserved left ventricular systolic function and are receiving standard medical therapy, what is the evidence of comparative harms of combination ACE inhibitor and ARB therapy vs. use with either an ACE inhibitor or ARB alone?
KQ5a. Study withdrawal | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) had more discontinuations than ACE inhibitor (ramipril) alone.
KQ5b. Hypotension withdrawal | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) had more discontinuations due to hypotension than ACE inhibitor (ramipril) alone.
KQ5c. Syncope withdrawal | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) had more discontinuations due to syncope than ACE inhibitor (ramipril) alone.
KQ5d. Cough withdrawal | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) had a similar number of discontinuations due to cough as ACE inhibitor (ramipril) alone.
KQ5e. Angioedema withdrawal | Low | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) had a similar number of discontinuations due to angioedema as ACE inhibitor (ramipril) alone.
KQ5f. Renal impairment withdrawal | Moderate | - Combination of ACE inhibitor + ARB (ramipril + telmisartan) had more discontinuations due to renal impairment than ACE inhibitor (ramipril) alone.
KQ5g. Rash | Insufficient | - No data is available comparing the combination of ACE inhibitor + ARB therapy vs. ACE inhibitor therapy alone in patients with stable ischemic heart disease.
KQ5h. Blood dyscrasias | Insufficient | - No data is available comparing the combination of ACE inhibitor + ARB therapy vs. ACE inhibitor therapy alone in patients with stable ischemic heart disease.
KQ5 Discussion. The results of Key Questions 2 and 5 are evaluated together to discern the comparative balance of benefits and harms. ACE inhibitor therapy, represented by ramipril, provides similar efficacy as the combination of an ACE inhibitor plus an ARB, represented by ramipril and telmisartan, with a lower risk of patient harm. As such, current evidence does not support the use of combination therapy at this time. The ACE inhibitor ramipril and the ARB telmisartan have similar efficacy, similar risks of harms, and therefore a similar balance of benefits to harms.
KQ6. In patients with ischemic heart disease and preserved left ventricular systolic function who had to have recently undergone, or are set to undergo, a coronary revascularization procedure, what are the comparative harms of ACE inhibitors or ARBs added to standard medical therapy when compared to standard medical therapy alone?
KQ6a. Study withdrawal | Low | - The risk of withdrawals was greater with ACE inhibitor or ARB therapy (ARB not evaluated) vs. placebo in patients with stable ischemic heart disease.; - ACE inhibitors (quinapril, ramipril) are worse than placebo in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. placebo in patients with stable ischemic heart disease.
KQ6b. Hypotension | Moderate | - The risk of hypotension was greater with ACE inhibitor or ARB therapy (ARB not evaluated) vs. placebo in patients with stable ischemic heart disease.; - ACE inhibitors (quinapril) are worse than placebo in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. placebo in patients with stable ischemic heart disease.
KQ6c. Syncope | Insufficient | - No data is available evaluating ACE inhibitors or ARBs in patients with stable ischemic heart disease.
KQ6d. Cough | Low | - The risk of cough with ACE inhibitor or ARB therapy (ARB not evaluated) was similar to placebo in patients with stable ischemic heart disease.; - ACE inhibitors (quinapril) are similar to placebo in patients with stable ischemic heart disease.; - ARB therapy was not evaluated vs. placebo in patients with stable ischemic heart disease.
KQ6e. Angioedema | Insufficient | - No data is available evaluating ACE inhibitors or ARBs in patients with stable ischemic heart disease.
KQ6f. Renal impairment or hyperkalemia | Insufficient | - No data is available evaluating ACE inhibitors or ARBs in patients with stable ischemic heart disease.
KQ6g. Rash | Insufficient | - No data is available evaluating ACE inhibitors or ARBs in patients with stable ischemic heart disease.
KQ6h. Blood dyscrasias | Insufficient | - No data is available evaluating ACE inhibitors or ARBs in patients with stable ischemic heart disease.
KQ6 Discussion. The constituent trials did not utilize a lengthy run-in period. Only the APRES trial used a run-in period and this was a single test dose. Since the only trial evaluating an ARB did not report adverse event results, our results cannot be applied to ARBs. The use of ACE inhibitors was associated with hypotension. While ACE inhibitors nonsignificantly increased the risk of cough, only three trials provided information, they all agreed on the direction of effect, and two of the three trials individually found ACE inhibitors to increase cough versus placebo. Given the lack of significant benefits found in Key Question 3, the balance of benefits to harms for the initiation of an ACE inhibitor or ARB in close proximity to a revascularization procedure is not favorable.
KQ7. What is the evidence that benefits or harms differ by subpopulations, including: demographics [sex, age, ethnicity, left ventricular ejection fraction (LVEF)], clinical course (previous treatment with a stent or coronary artery bypass surgery, degree and location of lesion, presence and pattern of symptoms), dose of the ACE inhibitor or ARB used, co-morbidities (diabetes, renal dysfunction, hypertension), and other medications (vitamins, lipid lowering drugs, beta-blockers, anti-platelet agents)?
KQ7a. Sex | Moderate | - ACE inhibitors (perindopril, ramipril) reduce composite efficacy endpoints (cardiovascular death, nonfatal myocardial infarction, or of one of the following depending on the trial: stroke or nonfatal cardiac arrest) similarly in males and females.
KQ7a. Sex | Low | - ARB therapy (telmisartan) may not reduce the composite efficacy endpoint of cardiovascular death, nonfatal myocardial infarction, stroke, or heart failure in females as much as in males (p- value for interaction = 0.08).
KQ7a. Sex | Low | - When ACE inhibitor (ramipril) and ARB (telmisartan) therapy are directly compared, there is a nonsignificant indication that ACE inhibitor therapy may provide greater efficacy (composite endpoint of cardiovascular death, nonfatal myocardial infarction, stroke, or heart failure) in females than ARB therapy with similar efficacy between treatments in males.
KQ7a. Sex | Low | - When ACE inhibitor therapy (ramipril) was compared with combination therapy with ACE inhibitors and ARBs (ramipril + telmisartan), there is a nonsignificant indication that combination therapy may provide greater efficacy (composite endpoint of cardiovascular death, nonfatal myocardial infarction, stroke, or heart failure) in females than ACE inhibitor therapy with similar efficacy between treatments in males.
KQ7a. Sex | Low | - ACE inhibitors (enalapril, imidapril, lisinopril) appear to be similar to calcium channel blockers (nifedipine) in efficacy in either males or females with stable ischemic heart disease and preserved left ventricular function.
KQ7a. Sex | Insufficient | - The impact of ACE inhibitors, ARBs and their combination on harms in males and females cannot be determined at this time.
KQ7b. Age | Low | - ACE inhibitors (perindopril, ramipril) reduce composite efficacy endpoints (cardiovascular death, nonfatal myocardial infarction, or of one of the following depending on the trial: stroke or nonfatal cardiac arrest) versus placebo in both younger and older subjects.
KQ7b. Age | Low | - ARB therapy (telmisartan) impacted the composite efficacy endpoint of cardiovascular death, nonfatal myocardial infarction, stroke, or heart failure similarly versus placebo in those under 65 years, 65 to 74 years, and greater than 74 years of age (p-value for interaction = 0.895). No significant benefits were seen with ARB therapy in any of the age subgroups versus placebo.
KQ7b. Age | Low | - When ACE inhibitor therapy (ramipril) was compared to ARB therapy (telmisartan) or to the combination of ACE inhibitor plus an ARB (ramipril + telmisartan), results were similar in the different age subgroups for the composite efficacy endpoint (cardiovascular death, nonfatal myocardial infarction, stroke, or heart failure).
KQ7b. Age | Low | - ACE inhibitors (enalapril, imidapril, lisinopril^*^) appear to be similar to calcium channel blockers (nifedipine) in efficacy in either younger or older subjects with stable ischemic heart disease and preserved left ventricular function.
KQ7b. Age | Insufficient | - The impact of ACE inhibitors, ARBs, and their combination on harms in subjects of differing ages cannot be determined at this time.
KQ7c. Ethnicity/genetic polymorphisms | Insufficient | - The impact of ACE inhibitors, ARBs, and their combination in subjects of differing ethnicity or genetic polymorphisms cannot be determined at this time.
KQ7d. Left ventricular ejection fraction | Insufficient | - The impact of ACE inhibitors, ARBs, and their combination in subjects with varying degrees of preserved left ventricular function cannot be determined at this time.
KQ7e. Degree and location of lesion | Insufficient | - The impact of ACE inhibitors, ARBs, and their combination in subjects with differing extents and locations of atherosclerotic lesions cannot be determined at this time.
KQ7f. Presence and pattern of symptoms | Insufficient | - The impact of the ACE inhibitors, ARBs, and their combination in subjects of different presence and pattern of angina symptoms cannot be determined at this time.
KQ7g. Dose of ACE inhibitor or ARB used | Insufficient | - The impact of ACE inhibitors, ARBs, and their combination on efficacy or harms depending on the dose employed cannot be determined at this time.
KQ7h. Diabetes mellitus | Moderate | - ACE inhibitors (perindopril, ramipril) reduce composite efficacy endpoints (cardiovascular death, nonfatal myocardial infarction, or of one of the following depending on the trial: stroke or nonfatal cardiac arrest) similarly in patients with and without diabetes mellitus.
KQ7h. Diabetes mellitus | Low | - ARB therapy (telmisartan) impacted the composite efficacy endpoint of cardiovascular death, nonfatal myocardial infarction, stroke, or heart failure similarly versus placebo in those with or without diabetes mellitus (p-value for interaction = 0.311). No significant benefits were seen with ARB therapy in either subgroup versus placebo.
KQ7h. Diabetes mellitus | Low | - ACE inhibitor therapy (ramipril) provides similar efficacy (composite endpoint of cardiovascular death, nonfatal myocardial infarction, stroke, or heart failure) to ARB therapy (telmisartan) in those with or without diabetes mellitus.
KQ7h. Diabetes mellitus | Low | - When ACE inhibitor therapy (ramipril) was compared to combination therapy with ACE inhibitors and ARBs (ramipril + telmisartan), there is a nonsignificant indication that combination therapy may provide greater efficacy (composite endpoint of cardiovascular death, nonfatal myocardial infarction, stroke, or heart failure) in those with diabetes mellitus than ACE inhibitor therapy but similar efficacy occurs between treatments in those without diabetes mellitus (p-value for interaction = 0.15).
KQ7h. Diabetes mellitus | Low | - ACE inhibitor therapy (enalapril, imidapril, lisinopril^*^) provided similar efficacy as calcium channel blocker (nifedipine) therapy in those with diabetes mellitus.
KQ7h. Diabetes mellitus | Insufficient | - The impact of ACE inhibitors, ARBs, and their combination on harms in patients with or without diabetes mellitus cannot be determined at this time.
KQ7i. Renal dysfunction | Low | - ACE inhibitor therapy (perindopril, ramipril, trandolapril) may prevent cardiovascular events and total mortality better in those with mild to moderate renal dysfunction than those without it.
KQ7i. Renal dysfunction | Insufficient | - The impact of ARB therapy on cardiovascular events and total mortality in those with and without renal dysfunction cannot be determined at this time.
KQ7i. Renal dysfunction | Insufficient | - The impact of ACE inhibitors, ARBs and their combination on harms in patients with or without renal dysfunction cannot be determined at this time.
KQ7j. Hypertension | Moderate | - ACE inhibitor therapy (perindopril, ramipril) reduce composite efficacy endpoints (cardiovascular death, nonfatal myocardial infarction, or of one of the following depending on the trial: stroke or nonfatal cardiac arrest) similarly in those with or without hypertension.
KQ7j. Hypertension | Low | - ARB therapy (telmisartan) impacted the composite efficacy endpoint of cardiovascular death, nonfatal myocardial infarction, stroke, or heart failure similarly versus placebo in those with systolic blood pressures of <135mmHg, 135–149mmHg, or >149mmHg (p-value for interaction = 0.796).
KQ7j. Hypertension | Low | - When ACE inhibitor (ramipril) and ARB (telmisartan) therapy are directly compared, there is a nonsignificant indication that ACE inhibitor therapy may provide greater efficacy (composite endpoint of cardiovascular death, nonfatal myocardial infarction, stroke, or heart failure) in those with baseline systolic blood pressures above 134mmHg while ARBs might provide greater efficacy in those with baseline systolic blood pressures of 134mmHg or below (p-value for interaction = 0.10).
KQ7j. Hypertension | Low | - When ACE inhibitor therapy (ramipril) was compared to combination therapy with ACE inhibitors and ARBs (ramipril + telmisartan), there is a nonsignificant indication that combination therapy may provide greater efficacy (composite endpoint of cardiovascular death, nonfatal myocardial infarction, stroke, or heart failure) in those with baseline systolic blood pressures of 134mmHg of less and those with a baseline systolic blood pressure of 150mmHg or more. ACE inhibitor therapy alone tended to provide greater efficacy in the middle blood pressure range (p-value for interaction = 0.15).
KQ7j. Hypertension | Insufficient | - The impact of ACE inhibitors, ARBs and their combination on harms in patients with or without hypertension cannot be determined at this time.
KQ7k. Baseline Risk | Low | - ACE inhibitors (perindopril, ramipril) reduce composite efficacy endpoints (cardiovascular death, nonfatal myocardial infarction, or of one of the following depending on the trial: stroke or nonfatal cardiac arrest) in low, medium, and high baseline risk categories versus placebo. As the baseline risk is increased, the benefits from ACE inhibitor therapy might be accentuated.
KQ7k. Baseline Risk | Low | - ARB therapy (telmisartan) might provide greater efficacy versus placebo in low baseline risk patients than those with medium or high risk for the composite endpoint of cardiovascular death, nonfatal myocardial infarction, stroke, or heart failure (p-value for interaction = 0.462).
KQ7k. Baseline Risk | Low | - ACE inhibitor therapy (ramipril) may provide greater efficacy (composite endpoint of cardiovascular death, nonfatal myocardial infarction, stroke, or heart failure) in those at medium to high baseline risk while ARB therapy (telmisartan) may provide more efficacy in those at lower baseline risk (p-value for interaction = 0.21).
KQ7k. Baseline Risk | Low | - Combination therapy with an ACE inhibitor plus an ARB (ramipril + telmisartan) provides similar efficacy as an ACE inhibitor alone regardless of baseline risk (p-value for interaction = 0.97).
KQ7k. Baseline Risk | Insufficient | - The impact of ACE inhibitors, ARBs and their combination on harms in patients with different baseline risk cannot be determined at this time.
KQ7l. Antiplatelet therapy | Moderate | - ACE inhibitor therapy (perindopril, ramipril) is significantly better at reducing the composite endpoint of cardiovascular death, nonfatal myocardial infarction and stroke than placebo in patients without antiplatelet therapy versus those with antiplatelet therapy (p-value for interaction < 0.003).
KQ7l. Antiplatelet therapy | Insufficient | - The impact of ACE inhibitors, ARBs and their combination on harms in patients with antiplatelet therapy cannot be determined at this time.
KQ7m. History of revascularization | Moderate | - ACE inhibitor therapy (perindopril, ramipril) is likely better at reducing the composite endpoint of cardiovascular death, nonfatal myocardial infarction and stroke than placebo in patients without a history of revascularization versus those with such as history (p-value for interaction = 0.078).
KQ7m. History of revascularization | Insufficient | - The impact of ACE inhibitors, ARBs and their combination on harms in patients with or without a history of revascularization cannot be determined at this time.
KQ7n. Beta-blockers | Moderate | - ACE inhibitors (perindopril, ramipril) provided similar ability to reduce the composite endpoint of cardiovascular death, nonfatal myocardial infarction and stroke versus placebo in patients with or without beta-blockers (p-value for interaction = 0.134)
KQ7n. Beta-blockers | Insufficient | - The impact of ACE inhibitors, ARBs and their combination on harms in patients with or without beta-blockers cannot be determined at this time.
KQ7o. Lipid lowering therapy | Moderate | - ACE inhibitors (perindopril, ramipril) provided a similar ability to reduce the composite endpoint of cardiovascular death, nonfatal myocardial infarction and stroke versus placebo in patients with or without lipid lowering therapy (p-value for interaction = 0.651)
KQ7o. Lipid lowering therapy | Insufficient | - The impact of ACE inhibitors, ARBs and their combination on harms in patients with or without lipid lowering therapy cannot be determined at this time.
KQ7p. Vitamin E therapy | Low | - ACE inhibitors (ramipril) provided similar ability to reduce the composite endpoint of cardiovascular death, nonfatal myocardial infarction and stroke versus placebo in patients with or without vitamin E therapy
KQ7p. Vitamin E therapy | Insufficient | - The impact of ACE inhibitors, ARBs and their combination on harms in patients with or without vitamin E therapy cannot be determined at this time.
KQ7 Discussion. This KQ provides important information regarding the applicability of the benefits data. Since there were no subgroup comparisons based on harms, the balance of benefits to harms in these subgroups is not known. While we cannot state with certainty that ARBs do not work as well in females as in males, the subgroup analyses of the TRANSCEND and ONTARGET trials support the need for more research in this area. Patients with renal dysfunction have at least as robust relative reductions in the risk of cardiovascular events when ACE inhibitors are given. Even in the PEACE trial where the overall benefits associated with ACE inhibitor therapy was not as robust, a strong trend towards benefits were seen in the subgroup with renal dysfunction receiving ACE inhibitors versus those receiving placebo. When we evaluated the impact of baseline risk on efficacy, there was a suggestion that ARBs might work better in lower risk patients while ACE inhibitors work better in higher risk patients. Perhaps, the lowest risk group was least likely to receive aspirin therapy that may subsequently attenuate the benefits of ACE inhibitors. Lipid lowering therapy does not seem to negatively impact the benefits of ACE inhibitor or ARB therapy. This is important since patients with stable ischemic heart disease are receiving higher intensity lipid lowering therapy than they did previously. Patients without a prior revascularization procedure may benefit more from ACE inhibitors than those with revascularization. More work is needed to evaluate the impact of different modalities of revascularization (bare metal stents, drug eluting stents, coronary artery bypass grafting, atherectomy) on the benefits associated with ACE inhibitors and ARBs. The balance of benefits to harms derived from initiating ACE inhibitor or ARB therapy along with a revascularization procedure is not favorable.

* Legend: The JMIC-B trial compared the calcium channel blocker nifedipine to one of three ACE inhibitors (enalapril, imidapril, or lisinopril) while the CAMELOT trial compared calcium channel blocker amlodipine to the ACE inhibitor enalapril.