# References

1 Minino AM, Heron MP, Smith BL. Preliminary Data for 2004 National Vital Statistics Reports. National Center for Health Statistics. 2006;54.
2 Gibbons RJ, Abrams J, Chatterjee K, et al. ACC/AHA 2002 guideline update for the management of patients with chronic stable angina. J Am Coll Cardiol. 2002;41:159-68. [pmid: 12570960].
3 Fraker TD, Fihn SD. 2007 chronic angina focused update of the ACC/AHA 2002 guidelines for the management of patients with chronic stable angina. J Am Coll Cardiol. 2007;50:2264-74. [pmid: 18061078].
4 Survival of Myocardial Infarction Long-Term Evaluation (SMILE) Study Investigators. The effect of the angiotensin-converting enzyme inhibitor zofenopril on mortality and morbidity after anterior myocardial infarction. N Engl J Med. 1995;332:80-5. [pmid: 7990904].
5 TRAndolapril Cardiac Evaluation (TRACE) Study Group. A clinical trial of the angiotensin-converting-enzyme inhibitor trandolapril in patients with left ventricular dysfunction after myocardial infarction. N Engl J Med. 1995;333:1670-6. [pmid: 7477219].
6 Collaborative Group on ACE Inhibitor Trials. Overview of randomized trials of angiotensin-converting enzyme inhibitors on mortality and morbidity in patients with heart failure. JAMA. 1995;273:1450-6. [pmid: 7654275].
7 Pitt B, Poole-Wilson PA, Segal R, et al. Effect of losartan compared with captopril on mortality in patients with symptomatic heart failure: randomized trial: the Losartan Heart Failure Survival Study (ELITE II). Lancet. 2000;355:1582-7. [pmid: 10821361].
8 Cohn JN, Tognoni G. for the Valsartan Heart Failure Trial Investigators. A Randomized trial of the angiotensin-receptor blocker valsartan in chronic heart failure. N Engl J Med. 2001;345:1667-75. [pmid: 11759645].
9 Pfeffer MA, Swedberg K, Granger CB. for the CHARM Investigators. Effects of candesartan on mortality and morbidity in patients with chronic heart failure: the CHARM-Overall programme. Lancet. 2003;362:759-66. [pmid: 13678868].
10 McMurray JJ, Ostergren J, Swedberg K. for the CHARM Investigators. Effects of candesartan in patients with chronic heart failure and reduced left-ventricular systolic function taking angiotensin-converting-enzyme inhibitors: the CHARM-Added trial. Lancet. 2003;362:767-71. [pmid: 13678869].
11 Pfeffer MA, McMurray JJ, Velazquez EJ. for the Valsartan in Acute Myocardial infarction Trial Investigators. Valsartan, captopril, or both in myocardial infarction complicated by heart failure, left ventricular dysfunction, or both. N Engl J Med. 2003;149:1893-906. [pmid: 14610160].
12 Matchar DB, McCrory DC, Orlando LA, et al. Systematic review: comparative effectiveness of angiotensin converting enzyme inhibitors or angiotensin II receptor blockers for treating essential hypertension. Ann Intern Med. 2008;148(81):16-29. [pmid: 17984484].
13 Hunt SA, Abraham WT, Chin MH, et al. ACC/AHA 2005 guideline update for the diagnosis and management of chronic heart failure in the adult: a report of the American College of Cardiology/American heart Association Task Force on Practice Guidelines (writing committee to update the 2001 guidelines for the evaluation and management of heart failure). Circulation. 2005;112:e154-e235. [pmid: 16160202].
14 Smith SC, Allen J, Blair SN, et al. AHA/ACC guidelines for secondary prevention for patients with coronary and other atherosclerotic vascular disease: 2006 update. Circulation. 2006;113:2363-72. [pmid: 16702489].
15 Schmidt-Ott KM, Kagiyama S, Philips I. The multiple actions of angiotensin II in atherosclerosis. Regul Pept. 2000;93(1–3):65-77. [pmid: 11033054].
16 Faxon DP, Fuster V, Libby P, et al. Atherosclerotic vascular disease conference. Writing group III: pathophysiology. Circulation. 2004;109(21):2617-25. [pmid: 15173044].
17 Ceconi C, Fox KM, Remme WJ, et al. on behalf of the EUROPA Investigators. ACE inhibition with perindopril and endothelial function. Results of a substudy of the EUROPA study: PERTINENT. Cardiovasc Res. 2007;73(1):237-46. [pmid: 17140552].
18 Song JC, White CM. Clinical pharmacokinetics and selective pharmacodynamics of new angiotensin converting enzyme inhibitors: an update. Clin Pharmacokinet. 2002;41:207-24. [pmid: 11929321].
19 Song JS, White CM. Pharmacologic, pharmacokinetic, and therapeutic differences among angiotensin II receptor blockers. Pharmacother. 2000;20:130-9.
20 Grundy SM, Cleeman JI, Bairey-Merz N, et al. Implications of recent clinical trials for the National Cholesterol Education Program Adult Treatment Panel III Guidelines. Circulation. 2004;110:227-39. [pmid: 15249516].
21 National Kidney Foundation Task Force on Cardiovascular Disease. K/DOQI Clinical practice guidelines for managing dyslipidemias in chronic kidney disease. Available at www.kidney.org/professionals/Kdoqi/guidelines_lipids/i.htm. Accessed June 2, 2008.
22 Rosendorff C, Black HR, Cannon CP, et al. Treatment of hypertension in the prevention and management of ischemic heart disease. Circulation. 2007;115:2761-88. [pmid: 17502569].
23 Physician’s Desk Reference. 61st ed. Montvale, NJ. Thompson PDR. 2007.
24 Monopril [package insert]. Princeton, NJ. Bristol-Myers Squibb Company. 2008.
25 Accupril [package insert]. New York, NY. Pfizer. 2006.
26 Meredith PA, Elliott HL, Reid JL, Francis RJ. The pharmacokinetics and angiotensin converting enzyme inhibition dynamics of cilazapril in essential hypertension. Br J Clin Pharmac. 1989;24:263S-266S.
27 Borghi C, Ambrosioni E. Zofenopril. A review of the evidence of its benefits in hypertension and acute myocardial infarction. Clin Drug Invest. 2000;20:371-84.
28 Higgins JPT, Green S, editors. Cochrane Handbook for Systematic Reviews of Interventions Version 5.0.1 [updated September 2008]. The Cochrane Collaboration. 2008. Available at www.cochrane-handbook.org. Accessed December 4, 2008.
29 Wong SSL, Wilczynski NL, Haynes RB. Comparison of top-performing search strategies for detecting clinically sound treatment studies and systematic reviews in MEDLINE and EMBASE. J Med Libr Assoc. 2006;94(4):451-5. [pmid: 17082841].
30 Scottish Intercollegiate Guidelines Network. Available at www.sign.ac.uk/methodology/filters.html. Accessed December 4, 2008.
31 Shea BJ, Grimshaw JM, Wells GA, Boers M, Andersson N, Hamel C, et al. Development of AMSTAR: a measurement tool to assess the methodological quality of systematic reviews. BMC Med Res Methodol. 2007;7:10. [pmid: 17302989].
32 Schunemann H, Brozek J, Oxman A, editors. GRADE handbook for grading quality of evidence and strength of recommendation. Version 3.2 (updated March 2008). The GRADE Working Group. 2008. Available at http://www.cc-ims.net/gradepro.
33 Dersimonian R, Laird N. Meta-analysis in clinical trials. Control Clin Trials. 1986;7:177-88. [pmid: 3802833].
34 Bax L, Yu LM, Ikeda N, et al. Development and validation of MIX: comprehensive free software for meta-analysis of causal research data. BMC Medical Research Methodology. 2006;6(50).
35 Higgins JP, Thompson SG, Deeks JJ, et al. Measuring inconsistency in meta-analyses. BMJ. 2003;327:557-60. [pmid: 12958120].
36 Egger M, Davey Smith G, Schneider M, et al. Bias in meta-analysis detected by a simple, graphical test. BMJ. 1997;315:629-34. [pmid: 9310563].
37 Duval S, Tweedie R. Trim and fill: A simple funnel-plot-based method of testing and adjusting for publication bias in meta-analysis. Biometrics. 2000;56:455-63. [pmid: 10877304].
38 The Heart Outcomes Prevention Evaluation Study Investigators. Effects of an angiotensin-converting enzyme inhibitor, ramipril, on cardiovascular events in high-risk patients. N Engl J Med. 2000;342(3):145-53. [pmid: 10639539].
39 Dagenais GR, Yusuf S, Mourassa MG, et al. Effects of ramipril on coronary events in high-risk persons: results of the Heart Outcomes Prevention Evaluation study. Circulation. 2001;104(5):522-6. [pmid: 11479247].
40 Salehian O, Healey J, Stambler B, et al. Impact of ramipril on the incidence of atrial fibrillation: results of the Heart Outcomes Prevention Evaluation study. Am Heart J. 2007;154(3):448-53. [pmid: 17719288].
41 MacMahon S, Sharpe N, Gamble G, et al. Randomized, placebo-controlled trial of the angiotensin-converting enzyme inhibitor, ramipril, in patients with coronary or other occlusive arterial disease. J Am Coll Cardiol. 2000;36(2):438-43. [pmid: 10933355].
42 Teo KK, Burton JR, Buller CE, et al. Long-term effects of cholesterol lowering and angiotensin-converting enzyme inhibition on coronary atherosclerosis: the Simvastatin/enalapril Coronary Atherosclerosis Trial (SCAT). Circulation. 2000;102(15):1748-54. [pmid: 11023927].
43 The EURopean trial On reduction of cardiac events with Perindopril in stable coronary Artery disease Investigators. Efficacy of perindopril in reduction of cardiovascular events among patients with stable coronary artery disease: randomized, double-blind, placebo-controlled, multicenter trial (the EUROPA study). Lancet. 2003;362(9386):782-8. [pmid: 13678872].
44 Kondo J, Sone T, Tsuboi H, et al. Effects of low-dose angiotensin II receptor blocker Candesartan on cardiovascular events in patients with coronary artery disease. Am Heart J. 2003;146(6):e20. [pmid: 14661009].
45 Nissen SE, Tuzcu EM, Libby P, et al. Effect of antihypertensive agents on cardiovascular events in patients with coronary disease and normal blood pressure. The CAMELOT study: a randomized controlled trial. JAMA. 2004;292(18):2217-26. [pmid: 15536108].
46 You U, Sumiyoshi T, Kodama K, et al. Comparison of nifedipine retard with angiotensin converting enzyme inhibitors in Japanese hypertensive patients with coronary artery disease: The Japan Multicenter Investigation for Cardiovascular diseases-B (JMIC-B) randomized trial. Hypertens Res. 2004;27(3):181-91. [pmid: 15080377].
47 The PEACE Trial Investigators. Angiotensin-converting-enzyme inhibition in stable coronary artery disease. N Engl J Med. 2004;351(20):2058-68. [pmid: 15531767].
48 Zonnad F, Kessler M, Lehert P, et al. for the FOSIDIAL Investigators. Prevention of cardiovascular events in end-stage renal disease: results of a randomized trial of Fosinopril and implications for future studies. Kidney Int. 2006;70(7):1318-24. [pmid: 16871247].
49 Takahashi A, Takase H, Toriyama T, et al. Candesartan, an angiotensin II type-1 receptor blocker, reduces cardiovascular events in patients on chronic haemodialysis – a randomized study. Nephrol Dial Transplant. 2006;21(9):2507-12. [pmid: 16766543].
50 Borhi C, Ambrosioni E. on behalf of the Survival of Myocardial Infarction Long-term Evaluation (SMILE) Study Group. Effects of zofenopril on myocardial ischemia in post-myocardial infarction patients with preserved left ventricular function: the Survival of Myocardial Infarction Long-term Evaluation (SMILE)-ISCHEMIA study. Am Heart J. 2007;153(3):e7-14. [pmid: 17307427].
51 The Telmisartan Randomized AssessmeNt Study in ACE iNtolerant subjects with cardiovascular Disease (TRANCEND) Investigators. Effects of angiotensin-receptor blocker telmisartan on cardiovascular events in high-risk patients intolerant to angiotensin-converting enzyme inhibitors: a randomized controlled trial. Lancet. 2008;372(9644):1174-83. [pmid: 18757085].
52 The ONTARGET Investigators. Telmisartan, ramipril, or both in patients at high risk for vascular events. N Engl J Med. 2008;358(15):1547-59. [pmid: 18378520].
53 Faxon DP. on behalf of the Multicenter American Research trial with Cilazapril after Angioplasty to prevent Transluminal coronary Obstruction and Restenosis (MARCATOR) Study Group. Effect of high dose angiotensin-converting enzyme inhibition on restenosis: final results of the MARCATOR study, a multicenter, double-blind, placebo-controlled trial of Cilazapril. J Am Coll Cardiol. 1995;25(2):362-9. [pmid: 7829789].
54 Kjoller-Hansen L, Steffensen R, Grande P. The Angiotensin-converting enzyme inhibitor Post REvascularization Study (APRES). J Am Coll Cardiol. 2000;35(4):881-8. [pmid: 10732883].
55 Kondo J, Sone T, Tsuboi H, et al. Effect of quinapril on intimal hyperplasia after coronary stenting as assessed by intravascular ultrasound. Am J Cardiol. 2001;87(4):443-5. [pmid: 11179530].
56 Meurice T, Bauters C, Hermant X, et al. Effect of ACE inhibitors on angiographic restenosis after coronary stenting (PARIS): a randomized, double-blind, placebo-controlled trial. Lancet. 2001;357(9265):1321-4. [pmid: 11343737].
57 Pitt B, O’Neill B, Feldman R, et al. The Quinapril Ischemic Event Trial (QUIET): evaluation of chronic ACE inhibitor therapy in patients with ischemic heart disease and preserved left ventricular function. Am J Cardiol. 2001;87(9):1058-63. [pmid: 11348602].
58 Radke PW, Figulla HR, Drexler H, et al. for the AACHEN Trial Investigators. A double-blind, randomized, placebo-controlled multicenter clinical trial to evaluate the effects of the angiotensin II receptor blocker Candesartan cilexetil on intimal hyperplasia after coronary stent implantation. Am Heart J. 2006;152(4):e1-e6. [pmid: 16996855].
59 Fouleau JL, Warnica WJ, Baillot R, et al. for the IMAGINE (Ischemia Management with Accupril post-bypass Graft via Inhibition of the coNverting Enzyme) Investigators. Effects of angiotensin-converting enzyme inhibition in low-risk patients early after coronary artery bypass surgery. Circulation. 2008;117(1):24-31. [pmid: 18071079].
60 The HOPE Study Investigators. The HOPE (Heart Outcomes Prevention Evaluation) Study: the design of a large, simple randomized trial of an angiotensin-converting enzyme inhibitor (ramipril) and vitamin E in patients at high risk of cardiovascular events. Can J Cardiol. 1996;12(2):127-37. [pmid: 8605634].
61 Pfeffer MA, Domanski M, Rosenberg Y, et al. Prevention of Events with Angiotensin-Converting Enzyme inhibition (the PEACE study design). Am J Cardiol. 1998;82(3A):25H-30H.
62 Zannad F, Kessler M, Grunfeld MP, et al. ROSIDIAL: a randomized placebo controlled trial of the effects of fosinopril on cardiovascular morbidity and mortality in haemodialysis patients. Study design and patients’ baseline characteristics. Fund Clin Pharmacol. 2002;16(5):353-60.
63 Teo KK, Burton JR, Buller C, et al. on behalf of the SCAT Investigators. Rationale and design features of a clinical trial examining the effects of cholesterol lowering and angiotensin-converting enzyme inhibition on coronary atherosclerosis Simvastatin/enalapril Coronary Atherosclerosis Trial (SCAT). Can J Cardiol. 1997;13(6):591-9. [pmid: 9215232].
64 Topouchian J, El Feghali R, Pannier B, et al. Arterial stiffness and pharmacological interventions – The Transcend Arterial stiffness Substudy (TRANS study). Vasc Health Risk Manag. 2007;3(4):381-8. [pmid: 17969367].
65 Fox KM, Henderson JR, Bertrand ME, et al. the European trial on reduction of cardiac events with perindopril in stable coronary artery disease (EUROPA). Eur Heart J. 1998;19(Suppl J):J52-J55. [pmid: 9796841].
66 Gomma AH, Fox KM. on behalf of the EUROPA Investigators. The EUROPA Trial: design, baseline demography and status of the substudies. Cardiovasc Drugs Ther. 2001;15(2):169-79. [pmid: 11669411].
67 Simoons ML, Vos J, de Feyter PJ, et al. EUROPA substudies, confirmation of pathophysiological concepts. Eur Heart J. 1998;19(Suppl J):J56-J60. [pmid: 9796842].
68 Kjoller-Hansen L, Steffensen R, Grande P. Effects of ramipril in patients with reduced left ventricular function. Rationale, design, methods, baseline characteristics and first-year experience. Scand Cardiovasc J. 1998;32(4):225-32. [pmid: 9802141].
69 Lees RS, Pitt B, Chan RC, et al. for the QUIET Investigators. Baseline clinical and angiographic data in the Quinapril Ischemic Event Trial (QUIET). Am J Cardiol. 1996;78(9):1011-6. [pmid: 8916480].
70 Texter M, Lees RS, Pitt B, et al. The Quinapril Ischemic Event Trial (QUIET) design and methods: evaluation of chronic ACE inhibitor therapy after coronary artery intervention. Cardiovasc Drugs Ther. 1993;7(2):273-82. [pmid: 8357782].
71 Warnica JW, van Gilst W, Baillot R, et al. on behalf of the IMAGINE Investigators. Ischemia Management with Accupril post bypass Graft via Inhibition of angiotensin coNverting Enzyme (IMAGINE): a multicenter randomized trial – design and rationale. Can J Cardiol. 2002;18(11):1191-1200. [pmid: 12464983].
72 The ONTARGET-TRANSCENT Investigators. Rationale, design, and baseline characteristics of 2 large, simple, randomized trials evaluating telmisartan, ramipril, and their combination in high-risk patients: the Ongoing Telmisartan Alone and in Combination with Ramipril Global Endpoint Trial/Telmisartan Randomized Assessment Study in ACE Intolerant Subjects with Cardiovascular Disease (ONTARGET/TRANSCEND) trials. Am Heart J. 2004;148(1):52-61. [pmid: 15215792].
73 Unger T. The Ongoing Telmisartan Alone and in Combination with Ramipril Global Endpoint Trial program. Am J Cardiol. 2003;91(suppl):28G-34G.
74 Mangia G. Cardiac and vascular protection: the Potential of ONTARGET. Medscape J Med. 2008;10(Suppl):S7. [pmid: 18449380].
75 Heart Outcomes Prevention Evaluation (HOPE) Study Investigators. Effects of ramipril on cardiovascular and microvascular outcomes in people with diabetes mellitus: results of the HOPE study and MICRO-HOPE substudy. Lancet. 2000;355(9200):253-9. [pmid: 10675071].
76 Daly CA, Fox KM, Remme WJ, et al. on behalf of the EUROPA Investigators. The effect of perindopril on cardiovascular morbidity and mortality in patients with diabetes in the EUROPA study: results from the PERSUADE substudy. Eur Heart J. 2005;26(14):1369-78. [pmid: 15860521].
77 Yui Y, Sumiyoshi T, Kodama K, et al. Nifedipine retard was as effective as angiotensin converting enzyme inhibitors in preventing cardiac events in high-risk hypertensive patients with diabetes and coronary artery disease: the Japan Multicenter Investigation for Cardiovascular diseases-B (JMIC-B) subgroup analysis. Hypertens Res. 2004;27(7):449-56. [pmid: 15302980].
78 Solomon SD, Rice MM, Jablonski KA, et al. Renal function and effectiveness of angiotensin-converting enzyme inhibitor therapy in patients with chronic stable coronary disease in the Prevention of Events with ACE inhibition (PEACE) trial. Circulation. 2006;114(1):26-31. [pmid: 16801465].
79 Brugts JJ, Boersma E, Chonchol M, et al. on behalf of the EUROPA Investigators. The cardioprotective effects of the angiotensin-converting enzyme inhibitor perindopril in patients with stable coronary artery disease are not modified by mild to moderate renal insufficiency. J Am Coll Cardiol. 2007;50(22):2148-55. [pmid: 18036453].
80 Mann JFE, Gerstein HC, Pogue J, et al. for the HOPE Investigators. Renal insufficiency as a predictor of cardiovascular outcomes and the impact of ramipril: the HOPE randomized trial. Ann Intern Med. 2001;134(8):629-36. [pmid: 11304102].
81 Yui Y, Shinoda E, Kodama K, et al. Nifedipine retard prevents hospitalization for angina pectoris better than angiotensin-converting enzyme inhibitors in hypertensive Japanese patients with previous myocardial infarction (JMIC-B substudy). J Hypertens. 2007;25(10):2019-26. [pmid: 17885543].
82 Bertrand ME, Remme WJ, Fox KM, et al. on behalf of the EUROPA Investigators. Effects of perindopril on long-term clinical outcome of patients with coronary artery disease and preserved left ventricular function. Int J Cardiol. 2007;121(1):57-61. [pmid: 17270296].
83 Gianni M, Bosch J, Pogue J, et al. Effect of long-term ACE-inhibitor therapy in elderly vascular disease patients. Eur Heart J. 2007;28(11):1382-8. [pmid: 17395677].
84 Deckers JW, Goedhart DM, Boersma E, et al. Treatment benefit by perindopril in patients with stable coronary artery disease at different levels of risk. Eur Heart J. 2006;27(7):796-801. [pmid: 16497685].
85 Fox KM, Bertrand ME, Remme WJ, et al. on behalf of the EUROPA Investigators. Efficacy of perindopril in reducing risk of cardiac events in patients with revascularized coronary artery disease. Am Heart J. 2007;153(4):629-35. [pmid: 17383303].
86 Kjoller-Hansen L, Steffensen R, Grande P. Beneficial effects of ramipril on left ventricular end-diastolic and end-systolic volume indexes after uncompensated invasive revascularization are associated with a reduction in cardiac events in patients with moderately impaired left ventricular function and no clinical heart failure. J Am Coll Cardiol. 2001;37(5):1214-20. [pmid: 11300425].
87 Kjoller-Hansen L, Steffensen R, Grande P. Extended follow-up of patients randomly assigned in the Angiotensin-converting enzyme inhibition Post-Revascularization Study (APRES). Am Heart J. 2004;148(3):175-80.
88 Kjoller-Hansen L, Steffensen R. Effect of ramipril on postrevascularization prevalence of angina and quality of life. Int J Cardiol. 2004;95(2–3):159-65. [pmid: 15193814].
89 Mann JFE, Yi QL, Sleight P, et al. on behalf of the HOPE Investigators. Serum potassium, cardiovascular risk, and effects of an ACE inhibitor: results of the HOPE study. Clin Nephrol. 2005;63(3):181-7. [pmid: 15786818].
90 Gerstein HC, Bosch J, Pogue J, et al. Rationale and design of a large study to evaluate the renal and cardiovascular effects of an ACE inhibitor and vitamin E in high-risk patients with diabetes. The MICRO-HOPE study. Diab Care. 1996;19(11):1225-8.
91 HOPE/HOPE-TOO Study Investigators. Long-term effects of ramipril on cardiovascular events and on diabetes. Results of the HOPE study extension. Circulation. 2005;112(9):1339-46. [pmid: 16129815].
92 Al-Mallah MH, Tleyjeh IM, Abdel-Latif AA, et al. Angiotensin-converting enzyme inhibitors in coronary artery disease and preserved left ventricular systolic function. A systematic review and meta-analysis of randomized controlled trials. J Am Coll Cardiol. 2006;47(8):1576-83. [pmid: 16630993].
93 Dagenais GR, Pogue J, Fox K, et al. Angiotensin-converting-enzyme inhibitors in stable vascular disease without left ventricular systolic dysfunction or heart failure: a combined analysis of three trials. Lancet. 2006;368(9535):581-8. [pmid: 16905022].
94 Danchin N, Cucherat M, Thullez C, et al. Angiotensin-converting enzyme inhibitors in patients with coronary artery disease and absence of heart failure or left ventricular systolic dysfunction. An overview of long-term randomized controlled trials. Arch Intern Med. 2006;166(7):787-96. [pmid: 16606817].
95 Saha SA, Molnar J, Arora RR. Tissue ACE inhibitors for secondary prevention of cardiovascular disease in patients with preserved left ventricular function: a pooled meta-analysis of randomized placebo-controlled trials. J Cardiovasc Pharmacol Ther. 2007;12(3):192-204. [pmid: 17875946].
96 Lang CD, Arora RR, Saha SA, et al. Bayesian meta-analysis of tissue angiotensin-converting enzyme inhibitors for reduction of adverse cardiovascular events in patients with diabetes mellitus and preserved ventricular function. J Cardiometab Syndr. 2008;3(1):45-52. [pmid: 18326970].
97 Saha SA, Molnar J, Arora RR. Tissue angiotensin-converting enzyme inhibitors for the prevention of cardiovascular disease in patients with diabetes mellitus without left ventricular systolic dysfunction or clinical evidence of heart failure: a pooled meta-analysis of randomized placebo-controlled clinical trials. Diabetes Obes Metab. 2008;10(1):41-52. [pmid: 18095949].
98 Anand K, Mooss AN, Hee TT, et al. Meta-analysis: inhibition of renin-angiotensin system prevents new-onset atrial fibrillation. Am Heart J. 2006;152(2):217-22. [pmid: 16875900].
99 Neutel J, Smith DH. Evaluation of angiotensin II receptor blockers for 24-hour blood pressure control. Meta-analysis of a clinical database. J Clin Hypertens (Greenwich). 2003;5(1):58-63. [pmid: 12556655].
100 Baguet JP, Lagallicier B, Anquier P, et al. Updated meta-analytical approach to the efficacy of antihypertensive drugs in reducing blood pressure. Clin Drug Invest. 2007;27(11):735-53.
101 Xi GL, Cheng JW, Lu GC. Meta-analysis of randomized controlled trials comparing telmisartan with losartan in the treatment of patients with hypertension. Am J Hypertens. 2008;21(5):546-52. [pmid: 18437146].
102 Cicardi M, Zingale LC, Bergamashini L, et al. Angioedema associated with angiotensin-converting enzyme inhibitor use: outcome after switching to a different treatment. Arch Intern Med. 2004;164(8):910-3. [pmid: 15111379].
103 Flather MD, Yusuf S, Pfeffer M, et al. for the ACE-Inhibitor Myocardial Infarction Collaborative Group. Long-term ACE-inhibitor therapy in patients with heart failure or left-ventricular dysfunction: a systematic overview of data from individual trials. Lancet. 2000;355(9215):1575-81. [pmid: 10821360].
104 Pfeffer MA, Braunwald E, Moye L, et al. Effect of Captopril on mortality and morbidity in patients with left ventricular dysfunction after myocardial infarction: results of the survival and ventricular enlargement trial. N Engl J Med. 1992;327(10):669-77. [pmid: 1386652].
105 Acute Infarction Ramipril Efficacy (AIRE) Study Investigators. Effect of ramipril on mortality and morbidity of survivors of acute myocardial infarction with clinical evidence of heart failure. Lancet. 1993;342(8875):821-8. [pmid: 8104270].
106 Kober L, Torp-Pederson C, Carlsen JE, et al. A clinical trial of the angiotensin-converting-enzyme inhibitor Trandolapril in patients with left ventricular dysfunction after myocardial infarction. N Engl J Med. 1995;333(25):1670-6. [pmid: 7477219].
107 The Heart Outcomes Prevention Evaluation Study Investigators. Vitamin E supplementation and cardiovascular events in high risk patients. N Engl J Med. 2000;342(3):154-60. [pmid: 10639540].
108 Exner DV, Dries DL, Domanski MJ, et al. Lesser response to angiotensin-converting-enzyme-inhibitor therapy in black as compared to white patients with left ventricular dysfunction. N Engl J Med. 2001;344(18):1351-7. [pmid: 11333991].
109 Douglas JG, Bakris GL, Epstein M, et al. Management of high blood pressure in African Americans: consensus statement of the hypertension in African Americans Working Group of the International Society on Hypertension in Blacks. Arch Intern Med. 2003;163(5):525-41. [pmid: 12622600].
110 McDowell SE, Coleman JJ, Ferner RE. Systematic review and meta-analysis of ethnic differences in risks of adverse reactions to drugs used in cardiovascular medicine. BMJ. 2006;332(7551):1177-81. [pmid: 16679330].
111 ACE Inhibitor Myocardial Infarction Collaborative Group. Indications for ACE inhibitors in the early treatment of acute myocardial infarction: systematic overview of individual data from 100,000 patients in randomized trials. Circulation. 1998;97(22):2202-12. [pmid: 9631869].
112 Coyle JD, Gardner SF, White CM. The renal protective effects of angiotensin II receptor blockers in type 2 diabetes mellitus. Ann Pharmacother. 2004;38(10):1731-8. [pmid: 15353571].
113 Jacobsen P, Anderson S, Jensen BR, Parving HH. Additive effect of ACE inhibition and angiotensin II receptor blockade in type I diabetic patients with diabetic nephropathy. J Am Soc Nephrol. 2003;14(4):992-9. [pmid: 12660333].
114 Jacobsen P, Anderson S, Rossing K, Parving HH. Dual blockade of the renin-angiotensin system versus maximal recommended dose of ACE inhibition in diabetic nephropathy. Kidney Int. 2003;63(5):1874-80. [pmid: 12675866].
115 Ingelfinger JR. Aliskiren and dual therapy in type 2 diabetes mellitus. N Engl J Med. 2008;358(23):2503-5. [pmid: 18525047].
116 Viberto G, Wheeldon NM. Microalbuminuria reduction with valsartan in patients with type II diabetes mellitus: a blood pressure-independent effect. Circulation. 2002;106(6):672-8. [pmid: 12163426].
117 Lewis EJ, Hunsicker LG, Clarke WR, et al. Renoprotective effect of the angiotensin-receptor antagonist irbesartan in patients with nephropathy due to type 2 diabetes. N Engl J Med. 2001;345(12):851-60. [pmid: 11565517].
118 Danser AH, Schalekamp MA, Bax WA, et al. Angiotensin-converting enzyme in the human heart. Effect of the deletion/insertion polymorphism. Circulation. 1995;92(6):1387-8. [pmid: 7664416].
119 Ueda S, Meredith PA, Morton JJ, et al. ACE (I/D) genotype as a predictor of the magnitude and duration of the response to an ACE inhibitor drug (enalaprilat) in humans. Circulation. 1998;98(20):2148-53. [pmid: 9815869].
120 Pfohl M, Athanasiadis A, Koch A, et al. Insertion/deletion polymorphism of the angiotensin I-converting enzyme gene is associated with coronary artery plaque calcification as assessed by intravascular ultrasound. J Am Coll Cardiol. 1998;31(5):987-91. [pmid: 9561998].
121 Materson BJ. Variability in response to antihypertensive drugs. Am J Med. 2007;120(4 Suppl 1):S10-S20. [pmid: 17403377].
122 Brunner-La Rocca HP. Interaction of angiotensin-converting enzyme inhibition and aspirin in congestive heart failure: Long controversy finally resolved?. Chest. 2003;124(4):1192-4. [pmid: 14555544].
123 Townsend JN, Doran J, Lote CJ, et al. Peripheral haemodynamic effects of inhibition of prostaglandin synthesis in congestive heart failure and interactions with captopril. Br Heart J. 1995;73(5):434-41. [pmid: 7786658].
124 Spaulding C, Charbonnier B, Cohen-Solal A, et al. Acute hemodynamic interaction of aspirin and ticlopidine with enalapril. Results of a double-blind, randomized comparative trial. Circulation. 1998;98(8):757-65. [pmid: 9727545].
125 Morgan TO, Anderson A, Bertram D. Effect of indomethacin on blood pressure in elderly people with essential hypertension well controlled on amlodipine or enalapril. Am J Hypertens. 2000;13(11):1161-7. [pmid: 11078175].
126 Pavlicevic I, Kuzmanic M, Rumboldt M, et al. Interaction between antihypertensives and NSAIDs in primary care: A controlled trial. Can J Clin Pharmacol. 2008;15(3):e372-82. [pmid: 18953082].