# Methods

## Topic Development

The topic for this report was nominated in a public process. With input from technical experts, the Scientific Resource Center (SRC) for the AHRQ Effective Health Care Program drafted the initial key questions and, after approval from AHRQ, posted them to a public Web site. The public was invited to comment on these questions. After reviewing the public commentary, the SRC drafted final key questions and submitted them to AHRQ for approval.

This comparative effectiveness review (CER) of ACE inhibitors or ARBs for stable ischemic heart disease is based on a systematic review of the literature. The University of Connecticut/Hartford Hospital EPC received input from a Technical Expert Panel (TEP) formed for this project as well as the task order officer (TOO). The TEP as well as the TOO served in an advisory capacity for this report, helping to refine key questions, identifying important issues, reviewing our proposed methods, and defining parameters for the review of evidence. The TEP included cardiologists, a cardiovascular pharmacist/pharmacologist, and a health policy pharmacist. All of the methods described below were determined a priori.

The methods for this CER follows the methods suggested in the Methods Reference Guide for Effectiveness and Comparative Effectiveness Reviews, Version 1.0 published by AHRQ (available at http://effectivehealthcare.ahrq.gov/repFiles/2007_10DraftMethodsGuide.pdf). See Abbreviations for a list of abbreviations used for the entire document.

## Search Strategy

For primary studies, two independent investigators conducted systematic literature searches of MEDLINE (1966 to February 2009) using the Cochrane Highly Sensitive and Specific Search Strategy (Sensitivity and Precision Maximizing Version 2008),28 Embase (1974 to February 2009) using the McMaster Health Information Research Unit (HiRU) strategy for minimizing differences between sensitivity and specificity,29 and the Cochrane Central Register of Controlled Trials (1966 to February 2009). Separate searches for ‘clinical outcomes’ (key questions 1, 2, 3, 7; RCTs only) and ‘harm’ (key question 4, 5, 6; observational studies to supplement RCT search) data were conducted. For systematic reviews, two independent investigators conducted systematic literature searches of MEDLINE (1966 to February 2009) using the McMaster Health Information Research Unit (HiRU) strategy to minimize differences between sensitivity and specificity) and the Cochrane Database of Systematic Reviews (1st Quarter 2009). No language restrictions were imposed. A manual search of references from reports of clinical trials or review articles and major cardiology meeting (American Heart Association, American College of Cardiology, European Society of Cardiology) abstract books from June 2006–February 2009 was performed to identify relevant trials. Clinical trial registry Web sites (including www.clinicaltrials.gov) were used to identify ongoing or soon to be published clinical trials of interest.

When applicable, we contacted investigators for clarification and additional data. Our exact search terms for each database are included in Appendix 1.

## Study Selection

The results of our searches were imported into RefWorks^®^ version 16 (CSA, Bethesda, MD). We scanned for duplicate citations, identified the number of duplicates and then eliminated them. We imported the remaining citations into a custom designed Microsoft Access^®^ database version 9.0.6926 SP -3 (Microsoft Corporation, Washington, DC) for title and abstract review. Two independent reviewers conducted this review in a parallel fashion. Citations at this stage could be excluded, in a hierarchical order, for the following reasons: not a study of human subjects, not a randomized controlled or observational trial, not a comparison of ACE inhibitor, ARB or their combination versus control therapy (studies directly comparing two different ACE inhibitors, or two ARBs were not included), not conducted in patients with stable ischemic heart disease or a risk equivalent [including diabetes mellitus or chronic kidney disease, or mixed vascular atherosclerotic disorders (coronary disease, peripheral artery disease, carotid atherosclerosis)], did not enroll at least 75 patients for a randomized controlled trial (RCT) or 1000 (observational study) patients, or was not at least 6 months duration. For a citation to be eliminated both reviewers had to indicate that it was ineligible for the same reason. A query report was generated identifying citations where discrepancies in the determinations of the two reviewers occurred and were reconciled via consensus adjudication or upon a subsequent determination by a third reviewer if consensus could not be reached. Given the robust RCT data known to exist on the subject, we felt that excluding smaller RCTs with less than 75 patients was justified. We also felt that, for harms specifically, only observational studies of greater than 1000 patients would provide reliable data. These search restrictions were discussed and approved by the TOO prior to the search being performed.

Full text articles for all citations progressed through the title/abstract review phase were assessed, in parallel, by two independent reviewers. Articles could be excluded at this stage, in hierarchical order, for the following reasons: not a study of human subjects, not a randomized controlled or observational trial, not a comparison of ACE inhibitor, ARB or their combination versus control therapy, not conducted in patients with stable ischemic heart disease or a risk equivalent, did not include patients with preserved ventricular function, did not enroll at least 75 patients (RCT) or 1000 patients (observational study), was not at least 6 months duration, or did not provide potentially usable efficacy data on the pre-specified clinical/humanistic outcomes. For an article to be eliminated, both reviewers had to indicate that it was ineligible for the same reason. A query report was generated identifying articles where discrepancies in the determinations of the two reviewers occurred and were reconciled via consensus adjudication or upon a subsequent determination by a third reviewer if consensus could not be reached.

Articles making it through the full text article review were included in the ‘clinical outcomes’ search evaluation if they were 1) randomized, controlled trials of ACE inhibitor or ARB therapy versus control therapy (placebo, open label, active control) or combination ACE inhibitor and ARB therapy versus either agent alone, 2) conducted in patients with stable ischemic heart disease, diabetes mellitus or chronic kidney disease, or mixed vascular atherosclerotic disorders (coronary disease, peripheral artery disease, carotid atherosclerosis), 3) enrolled patients who had preserved left ventricular function (an average LVEF in experimental groups >40 percent or no systematic evaluation of LVEF but exclusion of patients with signs or symptoms of heart failure), 4) included at least 75 patients, 5) studies that followed patients for a minimum of 6 months, and 6) reported efficacy data on pre-specified clinical or humanistic outcomes (Figure 2.1). Articles making it through the full text article review were included in the ‘harms’ evaluation if they were 1) randomized, controlled or observational trials of ACE inhibitor or ARB therapy versus control therapy or combination ACE inhibitor and ARB therapy versus either agent alone, 2) conducted in patients with stable ischemic heart disease, diabetes mellitus or chronic kidney disease, or mixed vascular atherosclerotic disorders (coronary disease, peripheral artery disease, carotid atherosclerosis), 3) enrolled patients who had preserved ventricular function (an average LVEF in experimental groups >40 percent or no systematic evaluation of LVEF but exclusion of patients with signs or symptoms of heart failure), 4) included at least 75 patients for RCTs or observational studies of at least 1000 patients, and 5) reported data on pre-specified harms (hyperkalemia, cough, angioedema, hypotension, rash, blood dyscrasias, syncope).

## Data Extraction

Through use of a standardized data abstraction tool, two reviewers independently collected data, with disagreement resolved through discussion. The following information was obtained from each trial: author identification, year of publication, source of study funding, study design characteristics and below-mentioned methodological quality criteria, study population (including study inclusion and exclusion criteria, run-in period, study withdrawals, ACE inhibitor, ARB or combination utilized, dose utilized, length of study, and duration of patient followup), patient baseline characteristics (sex, age, ethnicity, LVEF), co-morbidities (coronary disease history, myocardial infarction, stable angina, unstable angina, stroke or transient ischemic attack, peripheral vascular disease, diabetes mellitus, renal insufficiency, hypertension, left ventricular hypertrophy, microalbuminuria, smoking), revascularization procedures recently conducted or scheduled as an entry criteria, baseline cardiac health assessment values [systolic and diastolic blood pressure, body mass index, cholesterol levels (total LDL, HDL, triglycerides)], blood glucose, serum creatinine, serum potassium, coronary lesion location (left main, left anterior descending, left circumflex, right coronary artery), and use of concurrent standard medical therapies (beta-blockers, calcium channel blockers, anti-platelet agents including aspirin and clopidogrel/ticlopidine, diuretics, nitrates, lipid-lowering therapies including statins, digitalis). Clinical outcome endpoints include: total mortality, cardiovascular mortality, nonfatal myocardial infarction, stroke, composite endpoint (cardiovascular death, nonfatal-myocardial infarction, stroke), total myocardial infarction, fatal myocardial infarction, atrial fibrillation, symptom reporting, hospitalization rates (including total hospitalization, hospitalization for angina, and hospitalization for heart failure), revascularization, and quality of life measures. Harms endpoints include: (hyperkalemia, cough, angioedema, hypotension, rash, blood dyscrasias, syncope, and study withdrawal due to adverse events).

## Individual Study and Systematic Review Validity Assessment

As they are inherent controls of bias, the use of randomization, double-blinding, use of an intention-to-treat methodology, and other study methodologies for reducing bias (such as prospective study conduction, propensity score matching or adjustment, multivariate analysis) were used to assess the methodological quality of included studies.

The eleven-item “Assess the Methodological quality of SysteMAtic Review” (AMSTAR) checklist was used to assess methodological quality of systematic reviews. Two independent reviewers evaluated each systematic review with discrepancies resolved through discussion. Quality criteria set by AMSTAR include ‘a priori’ study design, duplication of study selection and data extraction, comprehensive literature search of at least two databases, inclusion of grey literature, list of both excluded and included studies, study characteristics, quality assessment, quality discussion, appropriate combining of data, publication bias assessment, and statement of conflicts of interest.31

## Applicability

Throughout this report, we discuss the applicability by following the population, intervention, comparator, outcomes, timing of outcomes measurement, and setting (PICOTS) format. Additionally, we report on differences in study design including run-in periods and durations of followup, as well as use subgroup and sensitivity analyses to identify potential differences in results based on PICOTS criteria. Key Question 7 is also used to discuss the applicability of study results to various patient populations.

## Rating the Strength of a Body of Evidence

We used the EPC methodology for grading, which is based on the criteria and methods of GRADE (Grading of Recommendations Assessment, DEvelopment), to assess the strength of evidence. This system uses four required domains – risk of bias, consistency, directness, and precision.32 Additional domains were not utilized because they were deemed not relevant to this review. All assessments were made by two investigators (with disagreements resolved through discussion). The evidence pertaining to each key question was classified into three broad categories: (1) “high”, (2) “moderate”, or (3) “low” grade (see Table 2). Below we describe in more detail the features that determined the strength of evidence for the different outcomes evaluated in this report.

Table 2 Definitions for grading the strength of evidence

Grade | Definition
High | There is high confidence that the evidence reflects the true effect. Further research is very unlikely to change our confidence in the estimate of effect.
Moderate | Moderate confidence that the evidence reflects the true effect. Further research may change our confidence in the estimate of effect and may change the estimate.
Low | Low confidence that the evidence reflects the true effect. Further research is likely to change our confidence in the estimate of effect and is likely to change the estimate.
Insufficient | Evidence either is unavailable or does not permit estimation of an effect.

### Risk of Bias

Risk of bias is the degree to which the included studies for any given outcome or comparison have a high likelihood of adequate protection against bias. This can be assessed through the evaluation of both design and study limitations. The study design for each trial was recorded as either a randomized controlled trial or an observational study. Studies were also ranked as no limitations, serious limitations, or very serious limitations. Because all of the included studies were randomized controlled trials with few limitations, they were considered to have a low risk of bias.

### Consistency

Consistency refers to the degree of similarity in the direction of the effect sizes from included studies within an evidence base. This was assessed in two main ways: (1) the effect sizes had the same sign, in that they were on the same side of unity; (2) the range of effect sizes was narrow. We ranked this domain as no inconsistency, serious inconsistency, and very serious inconsistency. For outcomes whereby only a single study was included, consistency would not be judged. We also considered measures of heterogeneity from out meta-analyses in evaluating consistency.

### Directness

Directness refers to whether the evidence links the compared interventions directly with health outcomes, and compares two or more interventions in head-to-head trials. Indirectness implies that more than one body of evidence is required to link interventions to the most important health outcomes. We ranked this domain as no indirectness, serious indirectness, and very serious indirectness.

### Precision

Precision refers to the degree of certainty surrounding an effect estimate with respect to a given outcome. For example, when a meta-analysis was performed, we evaluated the confidence interval around the summary effect size. A precise estimate is an estimate that would allow a clinically useful conclusion. An imprecise estimate is one for which the confidence interval is wide enough to include clinically distinct conclusions (e.g. both clinically important superiority and inferiority), a circumstance that will preclude a conclusion.

## Data Synthesis

For the purposes of the following analyses, a class effect for all ACE inhibitors and ARBs was made. In order to quantitatively evaluate the comparative effectiveness between ACE inhibitors and/or ARBs versus control (standard medical therapy), meta-analysis was performed when sufficient data existed (two or more studies). As an analytical tool, trials evaluating either an ACE inhibitor or an ARB versus control were pooled together in the base-case analyses. ACE inhibitor and ARB trials were then evaluated separately to determine the individual impact of each class of drugs. Although trials that evaluated patients both with established stable ischemic heart disease, as well as heart disease risk equivalents [including diabetes mellitus or chronic kidney disease, or mixed vascular atherosclerotic disorders (coronary disease, peripheral artery disease, carotid atherosclerosis)] were included, they were not statistically pooled together. Although the risk of some future cardiovascular sequella might be similar between those with ischemic heart disease and ischemic heart disease risk equivalents, we do not have confidence that the risks of many of the outcomes in interest are similar. Similarly, we analyzed placebo controlled trials separately from active controlled trials because of the potential benefits that could be derived from other cardiovascular therapy. We believed that pooling all of these disparate types of trials together would unnecessarily increase the statistical heterogeneity of our analyses. Thus, where applicable, four separate base-case analyses could be run for clinical outcomes: randomized, double-blind, controlled trials in ischemic heart disease comparing ACE inhibitor and/or ARB versus (1) placebo and (2) active-controls; and randomized controlled trials in heart disease risk equivalents [including diabetes mellitus or chronic kidney disease, or mixed vascular atherosclerotic disorders (coronary disease, peripheral artery disease, carotid atherosclerosis)] comparing ACE inhibitor and/or ARB versus (3) placebo and (4) active -controls.

For dichotomous endpoints, data were reported as pooled relative risks (RRs) with associated 95 percent confidence intervals (CIs). As heterogeneity between included studies was expected, a DerSimonian and Laird random-effects model was used which utilizes a variation of the inverse variance method.33 A random-effects model assumes that the variation of effect from study-to-study is related not just to random error (chance) but also to other real differences (including clinical or methodological differences). It also assumes that there is a normal distribution of effect sizes (a bell shaped curve) among constituent studies for which the pooled effect is in the center of the distribution. The result is a more conservative estimate of the confidence interval around the point estimate of effect size. When pooling continuous endpoints, a weighted mean difference (WMD) was calculated, again using a DerSimonian and Laird random-effects model. Statistics were performed using StatsDirect statistical software, version 2.4.6 (StatsDirect Ltd, Cheshire, England) and MIX statistical software,34 version 1.7 (Kitasato Clinical Research Center, Sagamihara, Kanagawa, Japan, freely accessible at www.mix-for-meta-analysis.info). A p-value of <0.05 was considered statistically significant for all analyses, except where otherwise specified.

Statistical heterogeneity was assessed using the Q Statistic (a p-value <0.10 was considered representative of significant statistical heterogeneity) and the I^2^ (which assesses the degree of inconsistency across studies and ranges from 0–100 percent with the higher percentage representing a higher likelihood of the existence of heterogeneity).35 While categorization of values for I^2^ may not be appropriate in all situations, I 2 values of 25–49 percent, 50–74 percent and greater than 75 percent have been regarded as representative of low, medium and high statistical heterogeneity, respectively. In order to evaluate the impact of statistical, clinical or methodological heterogeneity (when present), we conducted various subgroup and sensitivity analyses differing by key question. For Key Questions 1, 2, 4, and 5, we meta-analyzed trials that evaluated ACE inhibitors and ARBs separately. Methodological quality of the included studies was assessed via sensitivity analysis whereby both double-blind as well as open-label trials were pooled, in addition to separately assessing studies that reported using intention-to-treat (ITT) methodologies.

For Key Questions 3 and 6, we also conducted subgroup analysis analyzing ACE inhibitors and ARBs separately. Similar to above, methodological quality of the included studies was assessed via sensitivity analysis whereby both double-blind as well as open-label trials were pooled, in addition to separately assessing studies that reported using ITT methodologies. In addition, we performed subgroup analysis whereby trials conducted in patients undergoing coronary artery bypass graft surgery and percutaneous procedures were analyzed separately.

Visual inspection of funnel plots and Egger’s weighted regression statistics were used to assess for the presence of publication bias.36 In order to assess the potential effect of any publication bias on the meta-analysis results, the Trim and Fill method was used.37 The Trim and Fill method uses funnel plot symmetry to estimate the number of “missing” studies and the magnitudes of their effects. It re-estimates the overall effect size after imputing potentially “missing” studies into the meta-analysis to determine if the results of the original analysis were replicated.

For some key questions, or portions of some key questions, studies that can provide insight into the answers to key questions could not be pooled with others. In this case the studies were described qualitatively.

## Peer Review and Public Commentary

A draft of this Evidence Report was sent to peer reviewers, the representatives of the AHRQ and the SRC at Oregon Health and Science University. Based on comments from AHRQ, revisions were made to the draft report and posted to a website for public comment. In response to the comments of the peer reviewers and the public, revisions were made to the Evidence Report, and a summary of the comments and their disposition was submitted to AHRQ.