# Introduction

## Background

This is an evidence report prepared by the University of Connecticut/Hartford Hospital Evidence-based Practice Center (EPC) concerning the benefits and harms associated with using angiotensin converting enzyme (ACE) inhibitors and angiotensin receptor blockers (ARBs), either alone or in combination, in people with stable ischemic heart disease or ischemic heart disease risk equivalents and intact left ventricular systolic function.

While the role of ACE inhibitors and ARBs in patients with post-myocardial infarction left ventricular dysfunction or chronic heart failure is well established, the role for these modalities in patients with stable ischemic heart disease or ischemic heart disease risk equivalents and preserved left ventricular systolic function is not as clear. The aim of this report is to acquire, assess, and summarize the current evidence about the benefits and harms associated with the use of ACE inhibitors and ARBs, either alone or in combination, in this patient population. The information is intended to inform clinicians, payors, and the public, while helping to define avenues for future research.

### Health Impact of Cardiovascular Disease in the United States

Nearly 2,400 Americans die of cardiovascular disease each day, an average of one death every 36 seconds. Cardiovascular disease claims more lives each year than cancer, chronic lower respiratory diseases, accidents and diabetes mellitus combined.1 An estimated 79,400,000 American adults (one in three) have one or more types of cardiovascular disease, of whom 37,500,000 are estimated to be age 65 or older; approximately 8,900,000 adults suffer from angina. In every year since 1900, except 1918, cardiovasculardisease accounted for more deaths than any other single cause or group of causes of death in the United States.1

### Stable Ischemic Heart Disease With Preserved Left Ventricular Function

People with stable ischemic heart disease have advanced atherosclerosis reducing the maximal ability of the coronary arteries to supply blood to the myocardium.2 Stable ischemic heart disease can run the gamut from those with asymptomatic ischemic episodes to those with severely debilitating symptoms and from focused large vessel disease to those with diffuse microvascular disease.2 People with stable ischemic heart disease may or may not have had an acute coronary syndrome in the past but are at increased risk of such an event in the future.2

In people without a previous acute coronary syndrome but with stable ischemic heart disease, antiplatelet therapy with a single agent (aspirin or clopidogrel) and statin therapy (if the low density lipoprotein and non-high density lipoprotein concentrations are above 100mg/dL and 130mg/dL, respectively) can reduce the risk of cardiovascular events.2,3 Other drugs such as fast acting nitrates (nitroglycerin tablets or spray), negative chronotropic agents (beta-blockers, non-dihydropyridine calcium channel blockers), and vasodilators (calcium channel blockers, long acting nitrates) are for symptomatic relief but do not impact the risk of cardiovascular events. In people with a myocardial infarction but with preserved left ventricular function, dual antiplatelet therapy, statin therapy (if the low density lipoprotein and non-high density lipoprotein concentrations are above 70–100mg/dL and 130mg/dL, respectively), and beta-blockers can reduce the risk of subsequent cardiovascular events. The aforementioned symptomatic relief agents can similarly be used in this population as well.2,3 As such, it is important to evaluate new therapeutic modalities that may impact cardiovascular events in ischemic heart disease patients in addition to standard medical therapy.

### ACE Inhibitors and Angiotensin Receptor Blockers

ACE inhibitors have been shown to reduce the risk of morbidity and mortality amongst patients who have chronic heart failure or those after a myocardial infarction with left ventricular dysfunction.4–6 In patients with either chronic heart failure or post-myocardial infarction with left ventricular dysfunction, ARBs have been shown to be a reasonable substitute for ACE inhibitors for patients with these indications as well.7–11 In fact, in the Losartan Heart Failure Survival Study (ELITE II), patients with class II-IV heart failure and ejection fractions of <40 percent showed no difference between the ACE inhibitor captopril or the ARB losartan in terms of all cause mortality or sudden death.8 Additionally, a recent systematic review reported no significant differences in either blood pressure lowering ability or clinical outcomes in patients with essential hypertension between ACE inhibitors and ARBs.12 American College of Cardiology and American Heart Association practice guidelines support the use of ACE inhibitors in patients who have chronic heart failure or those with myocardial infarction and left ventricular dysfunction while ARBs are reserved for those who cannot tolerate ACE inhibitors.13,14 Combined ACE inhibitor and ARB therapy has been shown to provide additional benefits (17 percent reduction in mortality and 17 percent reduction in heart failure hospitalization) over that of an ACE inhibitor alone among patients with heart failure in the Candesartan in Heart failure Assessment of Reduction in Mortality (CHARM)-added trial.11 However, in the Valsartan in Acute Myocardial infarction (VALIANT) trial the combined use of an ACE inhibitor and ARB in post-myocardial infarction patients with left ventricular dysfunction or heart failure was no better than captopril alone for mortality or the composite endpoint (death from cardiac causes, reinfarction, or hospitalization for heart failure) with an increased risk of harms (adverse events resulting in dose reduction, 34.8 percent vs. 28.4 percent).12 As such, the aforementioned practice guidelines recommend the adjuvant use of ARBs in patients with heart failure who are still symptomatic on ACE inhibitors and beta-blockers but not in patients after a myocardial infarction with left ventricular dysfunction.13,14

Studies have been conducted that evaluate the use of ACE inhibitors and ARBs, either alone or in combination, in patients who have ischemic heart disease or an ischemic heart disease risk equivalent but without heart failure or left ventricular dysfunction. From this body of evidence, the benefits and harms associated with use of these therapies in this population of patients may be discerned. This is the focus of our current report.

### Pharmacology and Analytic Framework

Through the stimulation of angiotensin II type-1 receptors, angiotensin II increases systemic vascular resistance (afterload) elevating blood pressure and causing left ventricular hypertrophy. Angiotensin II promotes pathogenic remodeling (atherosclerosis and fibrosis) through the production of free radicals and subsequent promotion of inflammatory mediator release. These mediators participate in the recruitment of lymphocytes, the accumulation of macrophages with subsequent conversion to foam cells, and the propagation of atherosclerosis.15,16 Angiotensin II causes the release of aldosterone promoting pathogenic remodeling and also activates the sodium-potassium pump in the distal convoluted tubule promoting hypokalemia and fluid retention. Angiotensin II may increase the production of endogenous inhibitors of fibrinolysis. Finally, through production of free radicals, angiotensin II also decreases the availability of nitric oxide, inducing a state of endothelial dysfunction that may impact endothelial wall integrity and lead to ischemia.15,17

ACE inhibitors inhibit ACE, blocking the conversion of angiotensin I to angiotensin II, while preserving bradykinin (Figure 1).18 ARBs block the angiotensin II type-1 receptor and reduce the pharmacologic effects of angiotensin II regardless of whether angiotensin II is created by ACE or non-ACE pathways (Figure 1).19 As such, ACE inhibitors and ARBs can provide several pharmacological effects, over and above that of blood pressure reduction alone, which may impact cardiovascular events.

Figure 1 Pharmacologic effects of antagonists of the renin-angiotens in system18,19

PVR = peripheral vascular resistance

To guide our assessment of studies examining the association between ACE inhibitors, ARBs, or the combination of agents from the two classes on benefits and harms in our target population, we developed an analytic framework mapping specific linkages from comparisons to subpopulations of interest, mechanisms of benefit, and outcomes of interest (Figure 2). It is a logic chain that supports the link from the intervention to the outcomes of interest.

Figure 2 Analytic framework for the use of angiotens in-converting enzyme inhibitors and angiotens in receptor blockers in patients with s table is chemic heart disease and preserved systolic function

## Scope and Key Questions

This comparative effectiveness review was commissioned by the Agency for Healthcare Research and Quality (AHRQ) to focus on a population with stable ischemic heart disease or ischemic heart disease risk equivalents20–22 who have preserved left ventricular systolic function.

The key questions center around the comparative effectiveness of ACE inhibitors or ARBs added to standard medical therapy versus standard medical therapy alone; or center around the combined use of ACE inhibitors and ARBs added to standard medical therapy versus either an ACE inhibitor or ARB alone added to standard medical therapy. Amongst the total number of studies in this general category, some studies have been conducted where recent coronary revascularization procedures were a prerequisite for enrollment. These studies were evaluated separately from those where this was not a prerequisite.

Key Question 1. In patients with stable ischemic heart disease orischemic heart disease risk equivalents who have preserved left ventricular systolic function, what is the comparative effectiveness of ACE inhibitors or ARBs added to standard medical therapy when compared to standard medical therapy alone in terms of total mortality, cardiovascular mortality, nonfatal myocardial infarction, stroke, the composite endpoint of the latter three items, and atrial fibrillation? What is the evidence of benefit on other outcomes such as symptom reporting, hospitalization, revascularization, and quality of life measures?

Key Question 2. In patients with stable ischemic heart disease or ischemic heart disease risk equivalents who have preserved left ventricular systolic function and are receiving standard medical therapy, what is the comparative effectiveness of combination ACE inhibitors and ARBs versus either an ACE inhibitor or ARB alone in terms of total mortality, cardiovascular mortality, nonfatal myocardial infarction, stroke, the composite endpoint of the latter three items, and atrial fibrillation? What is the evidence of benefit on other outcomes such as symptom reporting, hospitalization, revascularization, and quality of life measures?

Key Question 3. In patients with ischemic heart disease and preserved left ventricular function who had to have recently undergone, or are set to undergo, a coronary revascularization procedure, what is the comparative effectiveness of ACE inhibitors or ARBs added to standard medical therapy when compared to standard medical therapy alone in terms of total mortality, cardiovascular mortality, nonfatal myocardial infarction, stroke, the composite endpoint of the latter three items, and atrial fibrillation? What is the evidence of benefit on other outcomes such as symptom reporting, hospitalization, revascularization, and quality of life measures?

Key Question 4. In patients with stable ischemic heart disease or ischemic heart disease risk equivalents who have preserved left ventricular systolic function, what are the comparative harms of adding ACE inhibitors or ARBs to standard medical therapy when compared to standard medical therapy alone?

Key Question 5. In patients with stable ischemic heart disease who have preserved left ventricular systolic function and are receiving standard medical therapy, what is the evidence of comparative harms of combination ACE inhibitor and ARB therapy versus use with either an ACE inhibitor or ARB alone?

Key Question 6. In patients with ischemic heart disease and preserved left ventricular systolic function who had to have recently undergone, or are set to undergo, a coronary revascularization procedure, what are the comparative harms of ACE inhibitors or ARBs added to standard medical therapy when compared to standard medical therapy alone?

Key Question 7. What is the evidence that benefits or harms differ by subpopulations, including: demographics [sex, age, ethnicity, left ventricular ejection fraction (LVEF)], clinical course (previous treatment with a stent or coronary artery bypass surgery, degree and location of lesion, presence and pattern of symptoms), dose of the ACE inhibitor or ARB used, co-morbidities (diabetes, renal dysfunction, hypertension), and other medications (vitamins, lipid lowering drugs, beta-blockers, anti-platelet agents)?

Table 1 Characteristics and current indications of ACE inhibitors and ARBs evaluated in this review23–27

Drug | Trade name(s) | Half-life or other relevant pharmacokinetic feature | Labeled indications | Dosing | Dose adjustments for special populations
ACE Inhibitors
Captopril | Capoten | T_1/2_ = 2 hours | HTN, HF, LVD post MI, diabetic nephropathy | 6.25–100 mg three times daily | Use lower initial doses in patients with renal impairment; titrate slowly
Cilazopril | Various | T_1/2_ = 32–45 hours | Not FDA approved | 1–5 mg daily | Start with 0.5 mg if CrCl 10–40 mL/min or if HF
Enalapril | Vasotec | T_1/2_ = 11 hours | HTN, HF, asymptomatic LVD | 5–40 mg divided once or twice daily | Start with 2.5 mg daily in patients with CrCl ≤ 30 mL/min, HF, or hyponatremia
Fosinopril | Monopril | T_1/2_ = 11.5–14 hours | HTN, HF as adjunctive therapy | 10–80 mg divided once or twice daily | Use close medical supervision in patients with HF; consider 5mg if renal impairment also present or if diuresed
Perindopril | Aceon | T_1/2_ = 3–10 hours (active metabolite) | Stable CAD, HTN | 4–8 mg daily; max 16 mg daily if normal renal function | Start with 2 mg daily if > 70 years old or renal insufficiency, 2 mg–4 mg if on diuretic; Not studied in CrCl < 30 mL/min
Quinapril | Accupril | T_1/2_ = 3 hours (active metabolite) | HTN, HF as adjunctive therapy | 10–80 mg divided once or twice daily | Start with 2.5 mg if CrCl 10–30 mL/min or 5 mg if CrCl 30–60 mL/min
Ramipril | Altace | T_1/2_ = 13–17 hours (active metabolite) | Reduce risk of MI, stroke, and death from CV causes, HTN, HF post MI | 2.5–20 mg divided once or twice daily | Start with 1.25 mg in patients with renal impairment; only 25% of normal doses may be needed if CrCl < 40mL/min
Trandolapril | Mavik | T_1/2_ = 6 hours (parent drug); 10 hours (active metabolite) | HTN, HF or LVSD post MI | 1–4 mg daily up to 4 mg twice daily | Start with 0.5 mg if concomitant diuretic, CrCl < 30 mL/min, or cirrhosis
Zofenopril | Various | T_1/2_ = 5 hours | Not FDA approved | 7.5–60 mg daily | Titrate slowly in HF
ARBs
Candesartan | Atacand | T_1/2_ = 9 hours | HTN, HF in patients with LVD | 2–32 mg daily | Start at lower doses if moderate hepatic impairment or volume depleted
Telmisartan | Micardis | T_1/2_ = 24 hours | HTN | 20–80 mg daily | Use under close medical supervision if volume depleted or hepatic or biliary disorders

Abbreviations: CrCl=creatinine clearance; FDA=Food and Drug Administration; HF=heart failure; HTN=hypertension; LVSD=left ventricular systolic dysfunction; mg=milligram; MI=myocardial infarction; mL/min=milliliters per minute; T_1/2_=half-life