# Acknowledgments

The Evidence-based Practice Center thanks Olivia J. Phung, Pharm.D., for her assistance with this project. We are indebted to the following investigators who provided us additional information or clarification on their clinical trials or individual patient meta-analyses: Claudio Borghi, M.D.; Gilles R. Dagenais, M.D.; Richard D. Rohde, M.D.; Yoshiki Yui, M.D.; Salim Yusuf, D.Phil., FRCPC, FRSC; Gerrit-Anne van Es, Ph.D., M.Sc.; Faiez Zannad, M.D., Ph.D., FESC. We appreciate their willingness to provide us with the information we needed.

## Technical Expert Panel

- JoAnne Foody, M.D.
- Director, Cardiovascular Wellness Program
- Brigham & Women’s/Faulkner Hospitals
- Harvard Medical School
- Jamaica Plain, MA

- Mark Rubino, R.Ph., M.H.A.
- Chief Pharmacy Officer
- Aetna, INC
- Hartford, CT 06156

- Stuart Genser, M.D.
- Internist
- Hartford Healthcare System
- Hartford, CT

- Paul D. Thompson, M.D.
- Director of Cardiology
- Hartford Hospital
- Professor of Medicine
- University of Connecticut
- Hartford, CT

- James P. Tsikouris, Pharm.D.
- Associate Professor
- University of Pittsburgh
- School of Pharmacy
- Pittsburgh, PA

- Michael Rossi, M.D.
- Cardiologist
- Hartford Healthcare System
- Hartford, CT

## AHRQ Contacts

- Beth Collins-Sharp, Ph.D., R.N.
- Director
- Evidence-Based Practice Center Program
- Agency for Healthcare Research and Quality
- Rockville, MD

- Carmen Y. Kelly, Pharm.D., R.Ph.
- Task Order Officer
- Evidence-Based Practice Center Program
- Agency for Healthcare Research and Quality