# Appendixes

Appendix A Search Strategies

Appendix B List of Excluded Studies

Appendix C Additional Evidence Tables and Analyses

Appendix D Peer Reviewers

Appendix E Abstraction Forms