# Abstraction Forms

Stable Ischemic Heart Disease Comparative Effectiveness Review

Baseline Characteristics

| Intervention 1 | Intervention 2 | Total
Males/Females:
Average Age (years):
White
Hispanic
African American
Asian
Other
Average LVEF (%)
Co-Morbidities
Hx/o Angiographically Documented CAD
Hx/o Myocardial Infarction
Previous Revascularization
CABG
PTCA/PCI
CABG or PTCA/PCI
Hx/o Stable Angina
Hx/o Unstable Angina
Hx/o Stroke/TIA
Hx/o Peripheral Vascular Disease
Hx/o Diabetes
Hx/o Renal Insufficiency
Hx/o Hypertension
Hx/o Left Ventricular Hypertrophy
Hx/o Microalbuminuria
Hx/o Smoking
Systolic Blood Pressure (mmHg)
Diastolic Blood Pressure (mmHg)
Body Mass Index
Total Cholesterol (mg/dl)
LDL Cholesterol (mg/dL)
HDL Cholesterol (mg/dL)
Triglycerides (mg/dL)
Glucose (mg/dl)
Creatine (mg/dL)
Potassium (mmol/L)
Left Main
Left Anterior Descending
Left Circumflex
Right Coronary Artery
Baseline Medical Therapies
Beta-Blockers
Calcium Channel Blockers
Aspirin
Clopidogrel/Ticlopidine
Antiplatelet
Diuretics
Nitrates
Statin
Lipid-Lowering
Digitalis

Efficacy Outcomes (Dichotomous)

| Intervention 1 | | Intervention 2
| Number at risk | Number of events | Number at risk | Number of events
Primary Endpoint (list components)
Total Mortality
Cardiovascular Death
Total Myocardial Infarction
Fatal Myocardial Infarction
Nan-Fatal Myocardial Infarction
Stroke
Composite (CV death, non-fatal Ml, stroke)
Other Composite (list Components)
Other Composite (list Components)
Atrial Fibrillation
Hospitalization
No. of Ischemic Events

Efficacy Outcomes (Continuous)

(n, mean+/−SD) | Intervention 1 | | Intervention 2
(n, mean+/−SD) | Baseline | Follow-up | Baseline | Follow-up
Exercise Time Before Ischemia
Quality of Life (Scale used:)

Safety Outcomes (Dichotomous)

| Intervention 1 | | Intervention 2
| Number at risk | Number of events | Number at risk | Number of events
Hyperkalemia
Cough
Angioedema
Syncope
Withdrawals Due to Adverse Events
Hypotension
Rash
Blood Dyscrasia’s