# Peer Reviewers

We gratefully acknowledge the following individuals who reviewed the initial draft of this report and provided us with constructive feedback. Acknowledgments are made with the explicit statement that this does not constitute endorsement of the report by the peer reviewers.

- Benjamin Powers, M.D., MHS
- Division of General Internal Medicine
- Duke University and Durham VAMC
- Durham, North Carolina

- Mouaz Al-Mallah, M.D.
- Division of Cardiology
- Henry Ford Hospital
- Detroit, MI

- Jessica C. Song, MA, Pharm.D.
- Department of Pharmacy
- Santa Clara Valley Medical Center
- San Jose, California

- L. Veronica Lee, M.D., FACC
- Division of Cardiology
- Yale University
- Yale-New Haven Hospital
- New Haven, Connecticut