# Additional Evidence Tables and Analyses

Abbreviations for Appendix C
ACE: Angiotensin Converting Enzyme
ACEI: Angiotensin Converting Enzyme Inhibitor
ADE: Adverse Drug Event
AHR: Adjusted Hazard Ratio
AMSTAR: Assess the Methodological quality of SysteMAtic Review
APRES: Angiotensin-converting Enzyme inhibition Post Revascularization Study
ARB: Angiotensin Receptor Blocker
CABG: Coronary Artery Bypass Grafting
CAD: Coronary Artery Disease
CAMELOT: Comparison of Amlodipine vs Enalapril to Limit Occurrences of Thrombosis
CCB: Calcium Channel Blocker
CHF: Congestive Heart Failure
CI: Confidence Interval
CV: Cardiovascular
DM: Diabetes Mellitus
EKG: Electrocardiogram
EUROPA: EURopean trial On reduction of cardiac events with Perindopril in stable coronary Artery disease
FOSIDIAL: FOSInopril in DIALysis
F/U: Follow-Up
GRADE: Grading of Recommendations Assessment, DEvelopment
HF: Heart Failure
HOPE: Heart Outcomes Prevention Evaluation
HR: Hazard Ratio
HTN: Hypertension
IC: Intermittent Claudication
IHD: Ischemic Heart Disease
IMAGINE: Ischemia Management with Accupril post-bypass Graft via Inhibition of the coNverting Enzyme
JMIC-B: Japan Multicenter Investigation for Cardiovascular Diseases-B
LVEF: Left Ventricular Ejection Fraction
LVH: Left Ventricular Hypertrophy
MARCATOR: Multicenter American Research trial with Cilazapril After angioplasty to prevent Transluminal coronary Obstruction and Restenosis
MI: Myocardial Infarction
N/A: Not Applicable
NR: Not Reported
ONTARGET: ONgoing Telmisartan Alone in combination with Ramipril Global Endpoint Trial
OR: Odds Ratio
PARIS: Effect of ACE inhibitors on angiographic restenosis after coronary stenting
PART-2: Prevention of Atherosclerosis with Ramipril Trial-2
PCI: Percutaneous Coronary Intervention
PEACE: Prevention of Events with Angiotensin Converting Enzyme Inhibition
PTCA: Percutaneous Transluminal Coronary Angioplasy
PVD: Peripheral Vascular Disease
QUIET: Quinapril Ischemic Event Trial
RCT: Randomized Controlled Trial
RR: Relative Risk
SB: Single Blind
SCAT: Simvastatin/enalapril Coronary Atherosclerosis Trial
SMILE-ISCHEMIA: Survival of Myocardial Infarcton Long-term Evaluation-ISCHEMIA
SMT: Standard Medical Therapy
TIA: Transient Ischemic Attack
TRANSCEND: Telmisartan Ransomized AssessmeNt Study in ACE iNtolerant subjects with cardiovascular Disease
SCR: Scientific Resource Center

Appendix Table 1 Pertinent systematic reviews

Reference | Inclusion Criteria | Total Studies Included | Total Pts Included | AMSTAR rating
Al-Mallah 2006^92^ | All randomized, placebo controlled trials of ACEIs use in patients with CAD and preserved LV function (LVEF≥40%) | 6 | 33,500 | 7/11
Dagenais 2006^93^ | HOPE, EUROPA and PEACE (the three main large trials of ACEIs in patients with atherosclerosis, but without heart failure or LSVD) | 3 | 29,805 | 2/11
Danchin 2006^94^ | All placebo-controlled randomized trials with a follow-up of 2 years or longer performed in patients who had stable CAD and either no signs or symptoms of heart failure or no documented LV dysfunction (no LVEF<35%) | 7 | 33,960 | 9/11
Saha 2007^95^ | All randomized, placebo controlled clinical trials with mean study duration of at least 12 months, a use of a tissue-selective ACEI (ramipril, perindopril, quinapril, or trandolapril), and strict inclusion of patients with cardiovascular disease who either had documented EKG evidence of normal left ventricular function (LVEF>40%) or had no clinical symptoms of CHF at the time of randomization | 4 | 31,555 | 7/11
Lang 2008^96^ | All randomized, placebo controlled clinical trials with mean study duration of at least 12 months, a use of a tissue-selective ACEI (ramipril, perindopril, quinapril, or trandolapril), patients with documented DM with evidence of normal left ventricular systolic function or who had no symptoms of congestive heart failure at the onset of the study, and risk factors in addition to DM, according to the Framingham classification | 4 | 10,328 | 6/11
Saha 2008^97^ | All RCTs with mean follow-up period of at least 12 months, and that compared effects of tissue-selective ACEI (ramipril, perindopril, quinapril, or trandolapril), with placebo, in patients with known DM who either had documented evidence of normal left ventricular systolic function or had no clinical symptoms of congestive heart failure at the start of the study | 4 | 10,328 | 6/11

Appendix Table 2 KQ1 Total mortality—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | Death from any cause | Ramipril 10mg/d Placebo | 482/4645 569/4652 | RR 0.84 (0.75 to 0.95)
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | All clinical events resulting in death | Ramipril 5–10mg/d Placebo | 16/308 25/309 | RR 0.64 (0.34 to 1.20)
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | Death | Enalapril 20mg/d Placebo | 8/229 11/231 | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. Or >70% coronary artery narrowing) without HF | Total mortality | Perindopril 8mg/d Placebo | 375/6110 420/6108 | 1-RR 11% (−2% to 23%)
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | Cardiovascular + non-cardiovascular deaths | Candesartan 4mg/d Control | 4/194 11/203 | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | All cause mortality | Enalapril 20mg/d Amlodipine 10mg/d Placebo | 8/673 7/663 6/655 | HR 1.26 (0.44 to 3.65)^†^ HR 0.92 (0.33 to 2.53)^¶^ HR 1.14 (0.38 to 3.40)^‡^
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | Total mortality | ACEI∝ Nifedipine 10–20mg/d | 15/822 12/828 | RR 0.76 (0.35 to 1.63)∂
PEACE, 2004^47^ | RCT | Documented CAD | Death from any cause | Trandolapril 4mg/d Placebo | 299/4158 334/4132 | HR 0.89 (0.76 to 1.04)
FOSIDIAL, 2006^*,48^ | RCT | Hemodialysis and LVH | All cause death | Fosinopril 20mg/d Placebo | 53/196 50/201 | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | Mortality | Candesartan 4–8mg/d Control | 0/43 7/37 | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | Total mortality | Telmisartan 80mg/d Placebo | 364/2954 349/2972 | AHR 1.05 (0.91 to 1.22)

† = Enalapril vs placebo;

¶ = Amlodipine vs enalapril;

‡ = Amlodipine vs placebo;

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d;

* = Clinical outcome data provided by FOSIDIAL corresponding author;

∂ = Nifidepine vs ACEI

Appendix Table 3 KQ1 Cardiovascular mortality—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | Death from cardiovascular causes | Ramipril 10mg/d Placebo | 282/4645 377/4652 | RR 0.74 (0.64 to 0.87)
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | Death from cardiovascular disease | Ramipril 5–10mg/d Placebo | 8/308 18/309 | RR 0.45 (0.19 to 1.03)
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | Cardiac death | Enalapril 20mg/d Placebo | 4/229 7/231 | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or >70% coronary artery narrowing) without HF | Cardiovascular mortality | Perindopril 8mg/d Placebo | 215/6110 249/6108 | 1-RR 14% (−3 to 28)
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mof/o angiography | Cardiovascular death | Candesartan 4mg/d Control | 2/194 9/203 | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | Cardiovascular death | Enalapril 20mg/d Amlodipine 10mg/d Placebo | 5/673 5/663 2/655 | HR 2.33 (0.45 to 12.1)^†^ HR 1.07 (0.31 to 3.70)^¶^ HR 2.46 (0.48 to 12.7)^‡^
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | Cardiac death or sudden death | ACEI∝ Nifedipine 10–20mg/d | 6/822 6/828 | RR 0.96 (0.31 to 3.04)∂
PEACE, 2004^47^ | RCT | Documented CAD | Death from cardiovascular causes | Trandolapril 4mg/d Placebo | 146/4158 152/4132 | HR 0.95 (0.76 to 1.19)
FOSIDIAL, 2006^*,48^ | RCT | Hemodialysis and LVH | Cardiovascular death | Fosinopril 20mg/d Placebo | 32/196 31/201 | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + endorgan damage | Cardiovascular death | Telmisartan 80mg/d Placebo | 227/2954 223/2972 | AHR 1.03 (0.85 to 1.24)

† = Enalapril vs placebo;

¶ = Amlodipine vs enalapril;

‡ = Amlodipine vs placebo;

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d;

* = Clinical outcome data provided by FOSIDIAL corresponding author;

∂ = Nifedipine vs ACEI

Appendix Table 4 KQ1 Nonfatal myocardial infarction—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | Acute MI not resulting in death | Ramipril 10mg/d Placebo | 260/4645 333/4652 | 1-RR 23% (9 to 34)
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | Nonfatal MI requiring hospital admission | Ramipril 5–10mg/d Placebo | 18/308 19/309 | RR 0.94 (0.49 to 1.80)
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | Nonfatal MI | Enalapril 20mg/d Placebo | 7/229 12/231 | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or >70% coronary artery narrowing) without HF | Nonfatal MI (see total MI for definition) | Perindopril 8mg/d Placebo | 295/6110 378/6108 | 1-RR 22% (10 to 33)
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | Nonfatal MI | Candesartan 4mg/d Control | 2/194 1/203 | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | Nonfatal MI | Enalapril 20mg/d Amlodipine 10mg/d Placebo | 11/673 14/663 19/655 | HR 0.55 (0.26 to 1.15)^†^ HR 1.32 (0.60 to 2.90)^¶^ HR 0.73 (0.37 to 1.46)^‡^
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | NR | ACEI∝ Nifedipine 10–20mg/d | NR | NR
PEACE, 2004^47^ | RCT | Documented CAD | Nonfatal MI | Trandolapril 4mg/d Placebo | 222/4158 220/4132 | HR 1.00 (0.83 to 1.20)
FOSIDIAL, 2006^*,48^ | RCT | Hemodialysis and LVH | Nonfatal MI | Fosinopril 20mg/d Placebo | 9/196 7/201 | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | NR | Telmisartan 80mg/d Placebo | NR | NR

† = Enalapril vs placebo

‡ = Amlodipine vs placebo

¶ = Amlodipine vs enalapril

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d

* = Clinical outcome data provided by FOSIDIAL corresponding author

Appendix Table 5 KQ1 Stroke—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | Stroke | Ramipril 10mg/d Placebo | 156/4645 226/4652 | RR 0.68 (0.56 to 0.84)
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | Nonfatal stroke requiring hospital admission | Ramipril 5–10mg/d Placebo | 7/308 4/309 | RR 1.67 (0.48 to 5.75)
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, ↑ chol | Stroke | Enalapril 20mg/d Placebo | 2/229 9/231 | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or >70% coronary artery narrowing) without HF | Stroke | Perindopril 8mg/d Placebo | 98/6110 102/6108 | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | NR | Candesartan 4mg/d Control | NR | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | Stroke or TIA | Enalapril 20mg/d Amlodipine 10mg/d | 8/673 6/663 12/655 | HR 0.66 (0.27 to 1.62)^†^ HR 0.76 (0.26 to 2.20)^¶^ HR 0.50 (0.19 to 1.32)^‡^
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | Cerebrovascular accidents | ACEI∝ Nifedipine 10–20mg/d | 16/822 16/828 | RR 0.76 (0.56 to 2.02)∂
PEACE, 2004^47^ | RCT | Documented CAD | Stroke | Trandolapril 4mg/d Placebo | 71/4158 92/4132 | HR 0.76 (0.56 to 1.04)
FOSIDIAL, 2006^*,48^ | RCT | Hemodialysis and LVH | Stroke | Fosinopril 20mg/d Placebo | 18/196 11/201 | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | New focal neurological deficits of vascular origin with s/sx>24h, or death if occurred earlier | Telmisartan 80mg/d Placebo | 112/2954 136/2972 | AHR 0.83 (0.64 to 1.06)

† = Enalapril vs placebo

¶ = Amlodipine vs enalapril

‡ = Amlodipine vs placebo

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d

* = Clinical outcome data provided by FOSIDIAL corresponding author

∂ = Nifedipine vs ACEI

Appendix Table 6 KQ1 Composite—Cardiovascular mortality, nonfatal myocardial infarction, or stroke—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38^ | RCT | CAD, Stroke, PVD or DM + 1 Risk Factor | Ramipril 10mg/d Placebo | 651/4645 826/4652 | RR 0.78 (0.70 to 0.86)
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | Ramipril 5–10mg/d Placebo | NR | NR
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | Enalapril 20mg/d Placebo | NR | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or >70% coronary artery narrowing) w/o HF | Perindopril 8mg/d Placebo | NR | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | Candesartan 4mg/d Control | NR | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | Enalapril 20mg/d Amlodipine 10mg/d Placebo | NR | NR
JMIC-B, 2004^46^ | RCT | HTN and CAD | ACEI∝ Nifedipine 10–20mg/d | NR | NR
PEACE, 2004^47^ | RCT | Documented CAD | Trandolapril 4mg/d Placebo | 396/4158 420/4132 | HR 0.93 (0.81 to 1.07)
FOSIDIAL, 2006^*,48^ | RCT | Hemodialysis and LVH | Fosinopril 20mg/d Placebo | 48/196 41/201 | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | Telmisartan 80mg/d Placebo | 384/2954 440/2972 | AHR 0.86 (0.74 to 1.00)

† = Enalapril vs placebo

‡ = Amlodipine vs placebo

¶ = Amlodipine vs enalapril

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d

* = Clinical outcome data provided by FOSIDIAL corresponding author

Appendix Table 7 KQ1 Atrial Fibrillation - Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | Atrial Fibrillation | Ramipril 10mg/d Placebo | 86/4291 91/4044 | OR 0.92 (0.68 to 1.24)
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | NR | Ramipril 5–10mg/d Placebo | NR | NR
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | NR | Enalapril 20mg/d Placebo | NR | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or >70% coronary artery narrowing) without HF | NR | Perindopril 8mg/d Placebo | NR | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | NR | Candesartan 4mg/d Control | NR | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | NR | Enalapril 20mg/d Amlodipine 10mg/d Placebo | NR | NR
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | NR | ACEI∝ Nifedipine 10–20mg/d | NR | NR
PEACE, 2004^47^ | RCT | Documented CAD | NR | Trandolapril 4mg/d Placebo | NR | NR
FOSIDIAL, 2006^*,48^ | RCT | Hemodialysis and LVH | NR | Fosinopril 20mg/d Placebo | NR | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | New atrial fibrillation | Telmisartan 80mg/d Placebo | 182/2954 180/2972 | AHR 1.02 (0.83 to 1.26)

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d

Appendix Table 8 KQ1 Hospitalizations—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | NR | Ramipril 10mg/d Placebo | NR | NR
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | Admitted to the hospital at least once | Ramipril 5–10mg/d Placebo | 279/308 289/309 | NR
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | NR | Enalapril 20mg/d Placebo | NR | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or >70% coronary artery narrowing) without HF | NR | Perindopril 8mg/d Placebo | NR | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | NR | Candesartan 4mg/d Control | NR | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | NR | Enalapril 20mg/d Amlodipine 10mg/d Placebo | NR | NR
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | NR | ACEI∝ Nifedipine 10–20mg/d | NR | NR
PEACE, 2004^47^ | RCT | Documented CAD | NR | Trandolapril 4mg/d Placebo | NR | NR
FOSIDIAL, 2006^*,48^ | RCT | Hemodialysis and LVH | NR | Fosinopril 20mg/d Placebo | NR | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | Number of patients hospitalized | Telmisartan 80mg/d Placebo | 1477/2954 1526/2972 | RR 0.97 (0.93 to 1.02)

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d

Appendix Table 9 KQ1 Hospitalization for angina—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | Hospitalization for unstable angina | Ramipril 10mg/d Placebo | 554/4645 565/4652 | RR 0.98 (0.87 to 1.10)
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | Unstable angina requiring hosp | Ramipril 5–10mg/d Placebo | 45/308 42/309 | RR 1.08 (0.71 to 1.65)
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, ↑ cholesterol | Hospitalization for angina | Enalapril 20mg/d Placebo | 40/229 29/231 | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or >70% coronary artery narrowing) without HF | NR | Perindopril 8mg/d Placebo | NR | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | Hospitalization for worsening angina | Candesartan 4mg/d Control | 9/194 14/203 | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | Hospitalization for angina | Enalapril 20mg/d Amlodipine 10mg/d Placebo | 86/673 51/663 84/655 | HR 0.98 (0.72 to 1.32)^†^ HR 0.59 (0.42 to 0.84)^¶^ HR 0.58 (0.41 to 0.82)^‡^
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | Angina pectoris requiring hospitalization | ACEI∝ Nifedipine 10–20mg/d | 56/822 50/828 | RR 0.80 (0.55 to 1.18)∂
PEACE, 2004^47^ | RCT | Documented CAD | NR | Trandolapril 4mg/d Placebo | NR | NR
FOSIDIAL, 2006^*,48^ | RCT | Hemodialysis and LVH | NR | Fosinopril 20mg/d Placebo | NR | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | Angina with hospitalization and ECG changes | Telmisartan 80mg/d Placebo | 253/2954 287/2972 | HR 0.88 (0.74 to 1.04)

† = Enalapril vs placebo

‡ = Amlodipine vs placebo

¶ = Amlodipine vs enalapril

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d

∂ = Nifedipine vs ACEI

Appendix Table 10 KQ1 Hospitalization for heart failure—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | Hospitalization for heart failure | Ramipril 10mg/d Placebo | 141/4645 160/4652 | RR 0.88 (0.70 to 1.10)
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | CHF requiring hospitalization | Ramipril 5–10mg/d Placebo | 7/308 9/309 | RR 0.78 (0.29 to 2.09)
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | NR | Enalapril 20mg/d Placebo | NR | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or >70% coronary artery narrowing) without HF | HF requiring hospital admission | Perindopril 8mg/d Placebo | 63/6110 103/6108 | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | Hospitalization for HF | Candesartan 4mg/d Control | 0/194 2/203 | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | Hospitalization for CHF | Enalapril 20mg/d Amlodipine 10mg/d Placebo | 4/673 3/663 5/655 | HR 0.78 (0.21 to 2.90)^†^ HR 0.78 (0.17 to 3.47)^¶^ HR 0.59 (0.14 to 2.47)^‡^
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | HF requiring hospitalization | ACEI∝ Nifedipine 10–20mg/d | 9/822 12/828 | RR 1.25 (0.52 to 2.98)∂
PEACE, 2004^47^ | RCT | Documented CAD | CHF as primary cause of hospitalization | Trandolapril 4mg/d Placebo | 105/4158 134/4132 | HR 0.77 (0.60 to 1.00)
FOSIDIAL, 2006^*,48^ | RCT | Hemodialysis and LVH | NR | Fosinopril 20mg/d Placebo | NR | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | Hospitalization for HF or attendance in an acute care setting | Telmisartan 80mg/d Placebo | 134/2954 129/2972 | HR 1.05 (0.82 to 1.34)

† = Enalapril vs placebo

‡ = Amlodipine vs placebo

¶ = Amlodipine vs enalapril

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d

∂ = Nifedipine vs ACEI

Appendix Table 11 KQ1 Revascularization—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38^ | RCT | CAD, Stroke, PVD or DM + 1 Risk Factor | All CV revasc (CABG, PCI, carotid endarterectomy, peripheral vascular surgery) | Ramipril 10mg/d Placebo | 742/4645 852/4652 | RR 0.85 (0.77 to 0.94)
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | NR | Ramipril 5–10mg/d Placebo | NR | NR
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | Any revascularization | Enalapril 20mg/d Placebo | 16/229 25/231 | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or >70% coronary artery narrowing) without HF | Revasc (CABG or PTCA) | Perindopril 8mg/d Placebo | 577/6110 601/6108 | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | Revascularization | Candesartan 4mg/d Control | 8/194 15/203 | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | Coronary revascularization | Enalapril 20mg/d Amlodipine 10mg/d Placebo | 95/673 78/663 103/655 | HR 0.86 (0.65 to 1.14)^†^ HR 0.84 (0.62 to 1.13)^¶^ HR 0.73 (0.54 to 0.98)^‡^
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | Performance of coronary interventions (PTCA, CABG or stenting) | ACEI∝ Nifedipine 10–20mg/d | 75/822 81/828 | RR 1.04 (0.76 to 1.43)∂
PEACE, 2004^47^ | RCT | Documented CAD | CABG | Trandolapril 4mg/d Placebo | 271/4158 294/4132 | HR 0.91 (0.77 to 1.07)
PEACE, 2004^47^ | RCT | Documented CAD | PCI | Fosinopril 20mg/d Placebo | 515/4158 497/4132 | HR 1.03 (0.97 to 1.16)
FOSIDIAL, 2006^*,48^ | RCT | Hemodialysis and LVH | NR | Candesartan 4–8mg/d Control | NR | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Ramipril 10mg/d Placebo Zofenopril 60mg/d Placebo | NR NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Ramipril 10mg/d Placebo Zofenopril 60mg/d Placebo | NR NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | Revascularization procedures | Telmisartan 80mg/d Placebo | 349/2954 390/2972 | HR 0.90 (0.77 to 1.03)

† = Enalapril vs placebo

‡ = Amlodipine vs placebo

¶ = Amlodipine vs enalapril

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d

* = Clinical outcome data provided by FOSIDIAL corresponding author

∂ = Nifedipine vs ACEI

Appendix Figure 1 KQ1 Total mortality ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=2.064483 (df=5) p=0.8402

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 2 KQ1 Total mortality sensitivity analysis—Meta-analysis of randomized placebo-controlled and open-label trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=9.913118 (df=7) p=0.1936

I^2^ statistic=29.4%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 3 KQ1 Total mortality sensitivity analysis—Meta-analysis of randomized placebo-controlled & open-label trials in patients with stable ischemic heart disease risk equivalents

Test for heterogeneity: Cochran Q=4.461381 (df=1) p=0.0347

I^2^ statistic=N/A

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 4 KQ1 Cardiovascular mortality ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=7.343875 (df=4) p=0.1188

I^2^ statistic=45.5%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 5 KQ1 Cardiovascular mortality sensitivity analysis—Meta-analysis of randomized placebo-controlled or open-label trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=14.733985 (df=6) p=0.0224

I^2^ statistic=59.3%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 6 KQ1 Nonfatal myocardial infarction ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=7.189476 (df=5) p=0.2069

I^2^ statistic=30.5%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 7 KQ1 Nonfatal myocardial infarction sensitivity analysis—Meta-analysis of randomized placebo-controlled + open-label trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=7.76543 (df=6) p=0.2558

I^2^ statistic=22.7%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 8 KQ1 Stroke ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=8.03054 (df=5) p=0.1546

I^2^ statistic=37.7%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 9 KQ1 Stroke sensitivity analysis—Meta-analysis of randomized placebo-controlled + open-label trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=8.291835 (df=6) p=0.011848

I^2^ statistic=27.6%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 10 KQ1 Composite of cardiovascular mortality, nonfatal myocardial infarction and stroke ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=4.365658 (df=1) p=0.0367

I^2^ statistic=N/A

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 11 KQ1 Hospitalization for angina ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=2.371505 (df=3) p=0.499

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 12 KQ1 Hospitalization for angina sensitivity analysis—Meta-analysis of randomized placebo-controlled + open-label trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=4.876247 (df=5) p=0.4312

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 13 KQ1 Hospitalization for heart failure ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=3.530577 (df=4) p=0.4732

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 14 KQ1 Hospitalization for heart failure sensitivity analysis—Meta-analysis of randomized placebo-controlled + open-label trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=8.660173 (df=6) p=0.1936

I^2^ statistic=30.7%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 15 KQ1 Revascularization ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=2.989717 (df=3) p=0.3932

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 16 KQ1 Revascularization subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease undergoing coronary artery bypass grafting surgery only

Test for heterogeneity: Cochran Q=0.037509 (df=1) p=0.8464

I^2^ statistic=N/A

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 17 KQ1 Revascularization subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease undergoing percutaneous coronary intervention only

Test for heterogeneity: Cochran Q=1.864482 (df=1) p=0.1721

I^2^ statistic=N/A

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 18 KQ1 Revascularization sensitivity analysis—Meta-analysis of randomized placebo-controlled or open-label trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=4.252035 (df=5) p=0.5137

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Table 12 KQ3 Total mortality—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | Death | Cilazapril 20mg/d Placebo | 7/1075 1/361 | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | Mortality due to all causes | Ramipril 10mg/d Placebo | 2/80 8/79 | 1-RR 76% (−1 to 92)
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | Total mortality | Quinapril 20mg/d Control | 0/49 0/50 | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | Deaths | Quinapril 40mg/d Placebo | 0/46 0/45 | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | All cause mortality | Quinapril 20mg/d Placebo | 27/878 27/872 | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | Deaths | Candesartan 32mg/d Placebo | 0/63 0/57 | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | Death due to any cause | Quinapril 40 mg/d Placebo | 28/1280 28/1273 | AHR 1.00 (0.59 to 1.69)

† Outcomes provided by personal communication with corresponding author

Appendix Table 13 KQ3 Cardiovascular mortality—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | NR | Cilazapril 20mg/d Placebo | NR | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | CV death, including cardiac death and fatal stroke | Ramipril 10mg/d Placebo | 1/80 8/79 | 1-RR 88% (24 to 94)
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | Cardiovascular death | Quinapril 20mg/d Control | 0/49 0/50 | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | Deaths^‡^ | Quinapril 40mg/d Placebo | 0/46 0/45 | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | CV death, including cardiac death and vascular/stroke death | Quinapril 20mg/d Placebo | 13/878 14/872 | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | Deaths^‡^ | Candesartan 32mg/d Placebo | 0/63 0/57 | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | Cardiovascular death | Quinapril 40 mg/d Placebo | 18/1280 15/1273 | AHR 1.20 (0.60 to 2.38)

† Outcomes provided by personal communication with corresponding author;

‡ No deaths occurred during the study.

Appendix Table 14 KQ3 Nonfatal myocardial infarction—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | Nonfatal MI | Cilazapril 20mg/d Placebo | 27/1075 8/361 | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | NR | Ramipril 10mg/d Placebo | NR | NR
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | NR | Quinapril 20mg/d Control | NR | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | Nonfatal MI | Quinapril 40mg/d Placebo | 1/46 0/45 | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | Nonfatal MI defined as changes in 1 or more of three parameters: symptomatology, enzyme elevation and ECG changes | Quinapril 20mg/d Placebo | 36/878 40/872 | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | Nonfatal MI^†^ | Candesartan 32mg/d Placebo | 1/63 2/57 | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | Nonfatal MI | Quinapril 40 mg/d Placebo | 16/1280 21/1273 | AHR 0.76 (0.40 to 1.46)

† AACHEN reported no deaths in the trial, with one MI in the Candesartan group and two in the placebo group therefore events were entered as nonfatal.

Appendix Table 15 KQ3 Stroke—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | NR | Cilazapril 20mg/d Placebo | NR | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | Fatal stroke | Ramipril 10mg/d Placebo | 0/80 1/79 | NR
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | NR | Quinapril 20mg/d Control | NR | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | NR | Quinapril 40mg/d Placebo | NR | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | NR | Quinapril 20mg/d Placebo | NR | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | NR | Candesartan 32mg/d Placebo | NR | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | Stroke | Quinapril 40 mg/d Placebo | 15/1280 14/1273 | AHR 1.07 (0.52 to 2.21)

Appendix Table 16 KQ3 Composite: Cardiovascular mortality, nonfatal myocardial infarction, or stroke—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | Cilazapril 20mg/d | NR | NR
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | Placebo | NR | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%)(5–7 days prior to randomization) or PTCA (18%)(1–2 days prior to randomization) for angina | Ramipril 10mg/d Placebo | NR | NR
Kondo et al, 2001^55^ | RCT | Received elective balloon angioplasty followed by coronary stenting | Quinapril 20mg/d Control | NR | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | Quinapril 40mg/d | NR | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | Placebo | NR | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | Quinapril 20mg/d | NR | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | Placebo | NR | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | Candesartan 32mg/d | NR | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | Placebo | NR | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | Quinapril 40 mg/d | 45/1280 | AHR 1.00 (0.66 to 1.51)
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | Placebo | 45/1273 | AHR 1.00 (0.66 to 1.51)

Appendix Table 17 KQ3 Atrial fibrillation—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | NR | Cilazapril 20mg/d Placebo | NR | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | NR | Ramipril 10mg/d Placebo | NR | NR
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | NR | Quinapril 20mg/d Control | NR | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | NR | Quinapril 40mg/d Placebo | NR | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | NR | Quinapril 20mg/d Placebo | NR | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | NR | Candesartan 32mg/d Placebo | NR | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | New-onset atrial fibrillation (after randomization) | Quinapril 40 mg/d Placebo | 114/1280 101/1273 | % risk difference 1 (−1.2 to 3.1)

Appendix Table 18 KQ3 Hospitalization for angina—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | NR | Cilazapril 20mg/d Placebo | NR | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | Patients hospitalized with chest pain on suspicion of unstable angina | Ramipril 10mg/d Placebo | 12/80 9/79 | NR
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | NR | Quinapril 20mg/d Control | NR | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | NR | Quinapril 40mg/d Placebo | NR | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | Patients hospitalized with unstable angina | Quinapril 20mg/d Placebo | 45/878 52/872 | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | NR | Candesartan 32mg/d Placebo | NR | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | Hospitalization for unstable angina | Quinapril 40 mg/d Placebo | 45/1280 38/1273 | AHR 1.19 (0.77 to 1.83)

Appendix Table 19 KQ3 Hospitalization for heart failure—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | NR | Cilazapril 20mg/d Placebo | NR | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | Hospitalization for heart failure | Ramipril 10mg/d Placebo | 2/80 5/79 | NR
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | NR | Quinapril 20mg/d Control | NR | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | NR | Quinapril 40mg/d Placebo | NR | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | NR | Quinapril 20mg/d Placebo | NR | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | NR | Candesartan 32mg/d Placebo | NR | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | Hospitalization for heart failure | Quinapril 40 mg/d Placebo | 15/1280 14/1273 | AHR 1.09 (0.53 to 2.26)

Appendix Table 20 KQ3 Revascularization—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | CABG or repeat angioplasty | Cilazapril 20mg/d Placebo | 207/1075 54/361 | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | NR | Ramipril 10mg/d Placebo | NR | NR
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | NR | Quinapril 20mg/d Control | NR | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | Angioplasty or stent implantation | Quinapril 40mg/d Placebo | 10/46 7/45 | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | Coronary angioplasty | Quinapril 20mg/d Placebo | 223/878 233/872 | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | CABG | Candesartan 32mg/d Placebo | 5/63 4/57
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | Target lesion revascularization | Quinapril 40 mg/d Placebo | 52/1280 41/1273 | NR

Appendix Figure 19 KQ3 Total mortality ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=3.810035 (df=4) p=0.4323

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 20 KQ3 Total mortality sensitivity analysis—Meta-analysis of randomized placebo-controlled or open-label trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=3.811901 (df=6) p=0.7021

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 21 KQ3 Total mortality sensitivity analysis—Meta-analysis of randomized placebo-controlled trials utilizing intention-to-treat methodologies in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=3.810035 (df=4) p=0.4323

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 22 KQ3 Total mortality subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, percutaneous procedure only

Test for heterogeneity: Cochran Q=0.623781 (df=3) p=0.891

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 23 KQ3 Cardiovascular mortality ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=4.351836 (df=3) p=0.2259

I^2^ statistic=31.1%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 24 KQ3 Cardiovascular mortality sensitivity analysis—Meta-analysis of randomized placebo-controlled or open-label trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=4.350679 (df=5) p=0.5001

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 25 KQ3 Cardiovascular mortality sensitivity analysis—Meta-analysis of randomized placebo-controlled trials utilizing intention-to-treat methodologies in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=4.351836 (df=3) p=0.2259

I^2^ statistic=31.1%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 26 KQ3 Cardiovascular mortality sensitivity analysis—Meta-analysis of randomized placebo-controlled or open-label trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, percutaneous procedure only

Test for heterogeneity: Cochran Q=0.000956 (df=2) p=0.9995

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 27 KQ3 Nonfatal myocardial infarction ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=1.11656 (df=3) p=0.767

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 28 KQ3 Nonfatal myocardial infarction sensitivity analysis—Meta-analysis of randomized placebo-controlled + open-label trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=1.46284 (df=4) p=0.8332

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 29 KQ3 Nonfatal myocardial infarction sensitivity analysis—Meta-analysis of randomized placebo-controlled trials utilizing intention-to-treat methodologies in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=1.141656 (df=3) p=0.767

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 30 KQ3 Nonfatal myocardial infarction subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, percutaneous procedure only

Test for heterogeneity: Cochran Q=1.130237 (df=3) p=0.7698

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 31 KQ3 Stroke ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=0.497689 (df=1) p=0.4805

I^2^ statistic=N/A

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 32 KQ3 Stroke sensitivity analysis—Meta-analysis of randomized placebo-controlled or open-label trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=0.497689 (df=1) p=0.4805

I^2^ statistic=N/A

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 33 KQ3 Stroke sensitivity analysis—Meta-analysis of randomized placebo-controlled trials utilizing intention-to-treat methodologies in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=0.497689 (df=1) p=0.4805

I^2^ statistic=N/A

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 34 KQ3 Hospitalization for angina ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=1.573147 (df=2) p=0.4554

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 35 KQ3 Hospitalization for angina sensitivity analysis—Meta-analysis of randomized placebo-controlled or open-label trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=1.573147 (df=2) p=0.4554

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 36 KQ3 Hospitalization for angina sensitivity analysis—Meta-analysis of randomized placebo-controlled trials utilizing intention-to-treat methodologies in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=1.573147 (df=2) p=0.4554

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 37 KQ3 Revascularizations ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=0.043777 (df=2) p=0.9783

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 38 KQ3 Revascularizations sensitivity analysis—Meta-analysis of randomized placebo-controlled or open-label trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=0.082314 (df=3) p=0.9939

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 39 KQ3 Revascularizations sensitivity analysis—Meta-analysis of randomized placebo-controlled trials utilizing intention-to-treat methodologies in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, a coronary revascularization procedure

Test for heterogeneity: Cochran Q=0.043777 (df=2) p=0.9783

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 40 KQ3 Revascularizations subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, percutaneous procedure only

Test for heterogeneity: Cochran Q=4.040768 (df=3) p=0.2571

I^2^ statistic=25.8%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 41 KQ3 Revascularizations subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease who have recently undergone, or are set to undergo, coronary artery bypass grafting surgery only

Test for heterogeneity: Cochran Q=0.291311 (df=1) p=0.5894

I^2^ statistic=N/A

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Table 21 KQ4 Run-in phase data—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Run-in | Description | Exclusions
HOPE, 2000^38^ | Yes | Ramipril 2.5mg/d X7-10d, then placebo qd X10-14d | 1,035/10,576 (9.8%) excluded: Non-compliance (n=NR) ADE (n=NR) Abnormal Scr or potassium (n=NR) Withdrawal of consent (n=NR)
PART-2, 2000^41^ | Yes | Ramipril 5mg/d X 7d, then 10mg/d X 7d | 127/744 (17%) excluded: Ineligibility (n=52, 41%) Suspected ADE (n=52, 41%) Patient preference (n=23, 18%)
SCAT, 2000^42^ | Yes | Dietary and SB placebo X 1 month | ~33% excluded^†^
EUROPA, 2003^43^ | Yes | Perindopril 4mg/d X14d, then 8mg/d X 14d^‡^ | 1,437/13,655 (10.5%) excluded: Hypotension (n=290, 20.2%) Raised Scr or potassium (n=149, 10.4%) Other intolerance (n=332, 23.1%) Major clinical event (n=75, 5.2%) Poor adherence (n=80, 5.6%) Exclusion criteria (n=44, 3.1%) Withdrawn consent (n=9, 0.6%) Unspecified stop reason (n=446, 31%) Never randomized (n=12, 0.8%)
Kondo et al, 2003^44^ | No | N/A | N/A
CAMELOT, 2004^45^ | Yes | Placebo tablet + placebo capsule qd X 14d | NR
JMIC-B, 2004^46^ | No | N/A | N/A
PEACE, 2004^47^ | Yes | Trandolapril 2mg/d X 14d | NR
FOSIDIAL, 2006^48^ | Yes | Single-blind placebo X 14d, then fosinopril 5mg X1 dose | NR
Takahashi et al, 2006^49^ | No | N/A | N/A
SMILE-ISCHEMIA, 2007^50^ | No | N/A | N/A
TRANSCEND, 2008^51^ | Yes | Placebo qd X 7d, then Telmisartan 80mg/d X 14d | 740/6666 (11.1%) excluded: Poor compliance (n=311, 42.0%) Consent withdrawn (n=135, 18.2%) Raised Scr or potassium (n=37, 5.0%) Symptomatic hypotension (n=53, 7.2%) Deaths (n=3, 0.4%) Other reasons (n=201, 27.2%)

† = Specific numbers of patients who entered run-in, and number who were excluded following run-in were not provided

‡ = Patients >70 years old received Perindopril 2mg/d X 7d, then 4mg/d X 7d, then 8mg/d X 14d during run-in period

Appendix Table 22 KQ4 Study withdrawals—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease.

Study, year | Report Withdrawals | Group | n | Reasons
HOPE, 2000^38^ | Yes | Ramipril 10mg/d | 1511 (32.5%) | Cough (n=340, 7.3%) Hypotension/Dizziness (n=88, 1.9%) Angioedema (n=17, 0.4%) Uncontrolled HTN (n=109, 2.3%) Clinical Events (n=309, 6.7%) Other (n=1101, 23.7%)
HOPE, 2000^38^ | Yes | Placebo | 1430 (30.7%) | Cough (n=85, 1.8%) Hypotension/Dizziness (n=70, 1.5%) Angioedema (n=7, 0.2%) Uncontrolled HTN (n=183, 3.9%) Clinical Events (n=418, 9.0%) Other (n=1074, 23.1%)
PART-2, 2000^41^ | Yes | Ramipril 5–10mg/d | 53 (17.2%) | Suspected ADE (n=31, 10%) Patient preference (n=22, 7%)
PART-2, 2000^41^ | Yes | Placebo | 25 (8.1%) | Suspected ADE (n=3, 1%) Patient preference (n=22, 7%)
SCAT, 2000^42^ | No | Enalapril 20mg/d | N/A | N/A
SCAT, 2000^42^ | No | Placebo | N/A | N/A
EUROPA, 2003^43^ | Yes | Perindopril 8mg/d | 1391 (22.8%) | Cough (n=162, 2.7%) Hypotension (n=60, 1.0%) Kidney failure (n=20, 0.3%) Intolerance (n=144, 2.4%) Study endpoint (n=376, 6.2%) Hypertension (n=22, 0.4%) Refusal to continue (n=261, 4.3%) Other (n=347, 5.7%)
EUROPA, 2003^43^ | Yes | Placebo | 1266 (20.7%) | Cough (n=32, 0.5%) Hypotension (n=17, 0.3%) Kidney failure (n=16, 0.3%) Intolerance (n=80, 1.3%) Study endpoint (n=460, 7.5%) Hypertension (n=46, 0.8%) Refusal to continue (n=257, 4.2%) Other (n=359, 5.9%)
Kondo et al, 2003^44^ | Yes | Candesartan 4mg/d | 9 (4.4%) | Dizziness/Lightheadedness (n=9, 4.4%)
Kondo et al, 2003^44^ | Yes | Control | 2 (1.0%) | Relocation (n=2, 1.0%)
CAMELOT, 2004^45^ | Yes | Enalapril 20mg/d | 236 (35.0%) | ADE (n=102, 15.1%) Withdrew consent (n=33, 4.9%) Death (n=4, 0.6%) Protocol violation (n=6, 0.9%) Laboratory abnormality (n=3, 0.4%) Lost to follow-up (n=22, 3.3%) Insufficient response (n=5, 0.7%) Other (n=61, 9.0%)
CAMELOT, 2004^45^ | Yes | Amlodipine 10mg/d | 194 (29.2%) | ADE (n=87, 13.1%) Withdrew consent (n=38, 5.7%) Death (n=2, 0.3%) Laboratory abnormality (n=2, 0.3%) Lost to follow-up (n=18, 2.7%) Insufficient response (n=2, 0.3%) Other (n=45, 6.8%)
CAMELOT, 2004^45^ | Yes | Placebo | 204 (31.1%) | ADE (n=71, 10.8%) Withdrew consent (n=50, 7.6%) Death (n=5, 0.8%) Protocol violation (n=8, 1.2%) Laboratory abnormality (n=3, 0.5%) Lost to follow-up (n=16, 2.4%) Insufficient response (n=3, 0.5%) Other (n=48, 7.3%)
JMIC-B, 2004^46^ | Yes | ACEI∝ | 143 (17.4%) | ADE (n=72, 8.8%) No effect (n=20, 2.4%) Withdrawal of consent (n=10, 1.2%) Protocol deviation (n=5, 0.6%) Alleviating symptoms (n=11, 1.3%) Others (n=25, 3.0%)
JMIC-B, 2004^46^ | Yes | Nifedipine 10–20mg/d | 107 (12.9%) | ADE (n=41, 5.0%) No effect (n=11, 1.3%) Withdrawal of consent (n=9, 1.1%) Protocol deviation (n=9, 1.1%) Alleviating symptoms (n=17, 2.1%) Others (n=20, 2.4%)
PEACE, 2004^†,47^ | No | Trandolapril 4mg/d | N/A | N/A
PEACE, 2004^†,47^ | No | Placebo | N/A | N/A
FOSIDIAL, 2006^48^ | Yes | Fosinopril 20mg/d | 7 (3.6%) | Renal transplantation (n=7, 3.6%)
FOSIDIAL, 2006^48^ | Yes | Placebo | 10 (5.0%) | Renal transplantation (n=8, 4.0%) Protocol violations (n=2, 1.0%)
Takahashi et al, 2006^49^ | Yes | Candesartan 4–8mg/d | 0 (0%) 0 (0%) | N/A
Takahashi et al, 2006^49^ | Yes | Control | 0 (0%) 0 (0%) | N/A
SMILE-ISCHEMIA, 2007^50^ | Yes | Zofenopril 60mg/d | 46 (13.2%) | Major protocol violation (n=15, 4.3%) Lost to follow-up (n=3, 0.9%) Inability to perform treadmill test (n=31, 8.9%)
SMILE-ISCHEMIA, 2007^50^ | Yes | Placebo | 46 (13.2%) | Major protocol violation (n=15, 4.3%) Lost to follow-up (n=3, 0.9%) Inability to perform treadmill test (n=31, 8.9%)
TRANSCEND, 2008^51^ | Yes | Telmisartan 80mg/d | 1090 (36.9%) | Hypotensive symptoms (n=29, 1.0%) Syncope (n=1, 0.03%) Cough (n=15, 0.5%) Diarrhea (n=7, 0.2%) Angioedema (n=2, 0.07%) Renal abnormalities (n=24, 0.8%)
TRANSCEND, 2008^51^ | Yes | Placebo | 1143 (38.5%) | Hypotensive symptoms (n=16, 0.5%) Syncope (n=0, 0%) Cough (n=18, 0.6%) Diarrhea (n=2, 0.07%) Angioedema (n=3, 0.1%) Renal abnormalities (n=13, 0.4%)

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d;

† = Listed as side effects leading to discontinuation of the study medication

Appendix Table 23 KQ4 Withdrawals due to adverse events—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, Year | Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38^ | RCT | CAD, Stroke, PVD or DM + 1 Risk Factor | NR | Ramipril 10mg/d | NR | NR
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | Suspected adverse drug reactions leading to stopping randomized treatment | Ramipril 5–10mg/d Placebo | 31/308 3/309 | NR
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | NR | Enalapril 20mg/d Placebo | NR | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or>70% coronary artery narrowing) without HF | NR | Perindopril 8mg/d Placebo | NR | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | NR | Candesartan 4mg/d Control | NR | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | Discontinuations due to adverse events | Enalapril 20mg/d Amlodipine 10mg/d Placebo | 102/673 87/663 71/655 | NR
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | Withdrawals due to adverse events | ACEI∝ Nifedipine 10–20mg/d | 72/822 41/828 | NR
PEACE, 2004^47^ | RCT | Documented CAD | Side effects leading to discontinuation of study medication | Trandolapril 4mg/d Placebo | 599/4158 269/4132 | NR
FOSIDIAL, 2006^48^ | RCT | Hemodialysis and LVH | NR | Fosinopril 20mg/d Placebo | NR | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | NR | Telmisartan 80mg/d Placebo | NR | NR

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d;

Appendix Table 24 KQ4 Hypotension—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38,†^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | Hypotension | Ramipril 10mg/d Placebo | 2/4645 3/4652 | NR
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | NR | Ramipril 5–10mg/d Placebo | NR | NR
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | NR | Enalapril 20mg/d Placebo | NR | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or >70% coronary artery narrowing) without HF | NR | Perindopril 8mg/d Placebo | NR | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | NR | Candesartan 4mg/d Control | NR | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | Hypotension | Enalapril 20mg/d Amlodipine 10mg/d Placebo | 64/673 22/663 21/655 | NR
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | NR | ACEI∝ Nifedipine 10–20mg/d | NR | NR
PEACE, 2004^47^ | RCT | Documented CAD | NR | Trandolapril 4mg/d Placebo | NR | NR
FOSIDIAL, 2006^48^ | RCT | Hemodialysis and LVH | NR | Fosinopril 20mg/d Placebo | NR | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | Severe hypotension | Zofenopril 60mg/d Placebo | 2/172 2/177 | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | NR | Telmisartan 80mg/d Placebo | NR | NR

† = Data are reported as “serious adverse events” found within the New Drug Application from www.fda.gov.

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d;

Appendix Table 25 KQ4 Syncope—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38,†^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | Syncope | Ramipril 10mg/d Placebo | 3/4645 1/4652 | NR
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | NR | Ramipril 5–10mg/d Placebo | NR | NR
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | NR | Enalapril 20mg/d Placebo | NR | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or >70% coronary artery narrowing) without HF | NR | Perindopril 8mg/d Placebo | NR | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | NR | Candesartan 4mg/d Control | NR | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | NR | Enalapril 20mg/d Amlodipine 10mg/d Placebo | NR | NR
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | NR | ACEI∝ Nifedipine 10–20mg/d | NR | NR
PEACE, 2004^47^ | RCT | Documented CAD | Syncope | Trandolapril 4mg/d Placebo | 200/4158 161/4132 | NR
FOSIDIAL, 2006^48^ | RCT | Hemodialysis and LVH | NR | Fosinopril 20mg/d Placebo | NR | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | NR | Telmisartan 80mg/d Placebo | NR | NR

† = Data are reported as “serious adverse events” found within the New Drug Application from www.fda.gov.

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d;

Appendix Table 26 KQ4 Cough—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38,†^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | Cough | Ramipril 10mg/d Placebo | 16/4645 9/4652 | NR
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | NR | Ramipril 5–10mg/d Placebo | NR | NR
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | NR | Enalapril 20mg/d Placebo | NR | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or >70% coronary artery narrowing) without HF | NR | Perindopril 8mg/d Placebo | NR | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | NR | Candesartan 4mg/d Control | NR | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | Cough | Enalapril 20mg/d Amlodipine 10mg/d Placebo | 84/673 34/663 38/655 | NR
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | NR | ACEI∝ Nifedipine 10–20mg/d | NR | NR
PEACE, 2004^47^ | RCT | Documented CAD | Cough | Trandolapril 4mg/d Placebo | 1626/4158 1136/4132 | NR
FOSIDIAL, 2006^48^ | RCT | Hemodialysis and LVH | NR | Fosinopril 20mg/d Placebo | NR | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | NR | Telmisartan 80mg/d Placebo | NR | NR

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d;

† = Data are reported as “serious adverse events” found within the New Drug Application from www.fda.gov.

Appendix Table 27 KQ4 Angioedema—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38,†^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | Angioedema | Ramipril 10mg/d Placebo | 5/4645 1/4652 | NR
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | NR | Ramipril 5–10mg/d Placebo | NR | NR
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | NR | Enalapril 20mg/d Placebo | NR | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or >70% coronary artery narrowing) without HF | NR | Perindopril 8mg/d Placebo | NR | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | NR | Candesartan 4mg/d Control | NR | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | NR | Enalapril 20mg/d Amlodipine 10mg/d Placebo | NR | NR
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | NR | ACEI∝ Nifedipine 10–20mg/d | NR | NR
PEACE, 2004^47^ | RCT | Documented CAD | Angioedema | Trandolapril 4mg/d Placebo | 8/4158 5/4132 | NR
FOSIDIAL, 2006^48^ | RCT | Hemodialysis and LVH | NR | Fosinopril 20mg/d Placebo | NR | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | NR | Telmisartan 80mg/d Placebo | NR | NR

† = Data are reported as “serious adverse events” found within the New Drug Application from www.fda.gov.

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d;

Appendix Table 28 KQ4 Hyperkalemia—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38,†^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | Serum potassium level> 5.0 mmol/L | Ramipril 10mg/d Placebo | 395/4539 297/4572 | NR
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | NR | Ramipril 5–10mg/d Placebo | NR | NR
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | NR | Enalapril 20mg/d Placebo | NR | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or>70% coronary artery narrowing) without HF | NR | Perindopril 8mg/d Placebo | NR | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | NR | Candesartan 4mg/d Control | NR | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | NR | Enalapril 20mg/d Amlodipine 10mg/d Placebo | NR | NR
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | NR | ACEI∝ Nifedipine 10–20mg/d | NR | NR
PEACE, 2004^47^ | RCT | Documented CAD | NR | Trandolapril 4mg/d Placebo | NR | NR
FOSIDIAL, 2006^48^ | RCT | Hemodialysis and LVH | NR | Fosinopril 20mg/d Placebo | NR | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | Serum potassium level> 5.5 mmol/L | Telmisartan 80mg/d Placebo | 111/2954 49/2972 | NR

† = Data taken from Mann JFE, et al. Serum potassium, cardiovascular risk, and effects of an ACE inhibitor: results of the HOPE Study. Clin Nephrol 2005;63:181–7;

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d

Appendix Table 29 KQ4 Blood dyscrasias—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38,†^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | NR | Ramipril 10mg/d Placebo | NR | NR
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | NR | Ramipril 5–10mg/d Placebo | NR | NR
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | NR | Enalapril 20mg/d Placebo | NR | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or >70% coronary artery narrowing) without HF | NR | Perindopril 8mg/d Placebo | NR | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | NR | Candesartan 4mg/d Control | NR | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | NR | Enalapril 20mg/d Amlodipine 10mg/d Placebo | NR | NR
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | NR | ACEI∝ Nifedipine 10–20mg/d | NR | NR
PEACE, 2004^47^ | RCT | Documented CAD | NR | Trandolapril 4mg/d Placebo | NR | NR
FOSIDIAL, 2006^48^ | RCT | Hemodialysis and LVH | NR | Fosinopril 20mg/d Placebo | NR | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | NR | Telmisartan 80mg/d Placebo | NR | NR

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d

Appendix Table 30 KQ4 Rash—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
HOPE, 2000^38,†^ | RCT | CAD, Stroke, PVD or DM + 1 CV Risk Factor | NR | Ramipril 10mg/d Placebo | NR | NR
PART-2, 2000^41^ | RCT | MI, angina with confirmed CAD, TIA or IC | NR | Ramipril 5–10mg/d Placebo | NR | NR
SCAT, 2000^42^ | RCT | Coronary atherosclerosis in >3 major arteries, elevated cholesterol | NR | Enalapril 20mg/d Placebo | NR | NR
EUROPA, 2003^43^ | RCT | CAD (previous MI, revasc. or>70% coronary artery narrowing) without HF | NR | Perindopril 8mg/d Placebo | NR | NR
Kondo et al, 2003^44^ | RCT | H/o coronary intervention with no significant stenosis on 6 mo f/o angiography | NR | Candesartan 4mg/d Control | NR | NR
CAMELOT, 2004^45^ | RCT | PCI or chest pain requiring coronary angiography | NR | Enalapril 20mg/d Amlodipine 10mg/d Placebo | NR | NR
JMIC-B, 2004^46^ | RCT | Hypertension and CAD | NR | ACEI∝ Nifedipine 10–20mg/d | NR | NR
PEACE, 2004^47^ | RCT | Documented CAD | NR | Trandolapril 4mg/d Placebo | NR | NR
FOSIDIAL, 2006^48^ | RCT | Hemodialysis and LVH | NR | Fosinopril 20mg/d Placebo | NR | NR
Takahashi et al, 2006^49^ | RCT | Chronic maintenance hemodialysis | NR | Candesartan 4–8mg/d Control | NR | NR
SMILE-ISCHEMIA, 2007^50^ | RCT | MI within 6 weeks | NR | Zofenopril 60mg/d Placebo | NR | NR
TRANSCEND, 2008^51^ | RCT | CAD, Cerebrovascular disease, PVD, or DM + end-organ damage | NR | Telmisartan 80mg/d Placebo | NR | NR

∝ = Patients in the ACEI group were given enalapril 5–10mg/d, imidapril 5–10mg/d, or lisinopril 10–20mg/d

Appendix Figure 42 KQ4 Withdrawal due to adverse events subgroup ACEI analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=15.650446 (df=2) p=0.0004

I^2^ statistic=87.2%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 43 KQ4 Hypotension ACEI subgroup analysis—Meta-analysis of randomized placebo-controlled trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=3.368646 (df=2) p=0.1856

I^2^ statistic=40.6%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Table 31 KQ6 Run-in phase date—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Run-in | Description | Exclusions
MARCATOR, 1995^53^ | No | N/A | N/A
APRES, 2000^54^ | No | N/A | N/A
Kondo et al, 2001^55^ | No | N/A | N/A
PARIS, 2001^56^ | No | N/A | N/A
QUIET, 2001^57^ | No | N/A | N/A
AACHEN, 2006^58^ | No | N/A | N/A
IMAGINE, 2008^59^ | No | N/A | N/A

Appendix Table 32 KQ6 Study withdrawals—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Report Withdrawals | Group | n | Reasons
MARCATOR, 1995^53^ | Yes | Cilazapril 20mg/d | 350 (24.4%)^†^ | No follow-up angiogram (n=159, 11.1%) Protocol violation (n=22, 1.5%) Severe hypotension (n=33, 2.3%) Severe cough (n=21, 1.5%) Angina pectoris (range 10–14% per group)
MARCATOR, 1995^53^ | Yes | Placebo | 350 (24.4%)^†^ | No follow-up angiogram (n=159, 11.1%) Protocol violation (n=22, 1.5%) Severe hypotension (n=33, 2.3%) Severe cough (n=21, 1.5%) Angina pectoris (range 10–14% per group)
APRES, 2000^54^ | Yes | Ramipril 10mg/d | 13 (16.3%) | Open-label ACEI treatment (n=5, 6.3%) Loss of consent/follow-up (n=5, 6.3%) Side effects (n=2, 2.5%) Endocarditis requiring surgery (n=1, 1.3%) Open-label ACEI treatment (n=7, 8.9%) Loss of consent/follow-up (n=4, 5.1%) Side effects (n=2, 2.5%)
APRES, 2000^54^ | Yes | Placebo | 13 (16.5%)
Kondo, 2001^55^ | Yes | Quinapril 20mg/d | 1 (2%) 0 (0%) | Severe cough (n=1, 2%) N/A
Kondo, 2001^55^ | Yes | Control | 1 (2%) 0 (0%) | Severe cough (n=1, 2%) N/A
PARIS, 2001^56^ | Yes | Quinapril 40mg/d | 0 (0%) 0 (0%) | N/A 0 (0%)
PARIS, 2001^56^ | Yes | Placebo | 0 (0%) 0 (0%) | N/A 0 (0%)
QUIET, 2001^57^ | Yes | Quinapril 20mg/d | 246 (28.0%) 218 (25.0%) | NR NR
QUIET, 2001^57^ | Yes | Placebo | 246 (28.0%) 218 (25.0%) | NR NR
AACHEN, 2006^58^ | No | Candesartan 32mg/d | N/A | N/A
AACHEN, 2006^58^ | No | Placebo | N/A | N/A
IMAGINE, 2008^59^ | Yes | Quinapril 40 mg/d | 444 (34.7%) | Adverse event (n=228, 17.8%) Worsening diabetes (n=8, 0.6%) Patient decision (n=103, 8.0%) Physician decision (n=73, 5.7%) Other (n=32, 2.5%) Adverse event (n=103, 8.1%) Worsening diabetes (n=3, 0.2%) Patient decision (n=89, 7.0%) Physician decision (n=97, 7.6%) Other (n=23, 1.8%)
IMAGINE, 2008^59^ | Yes | Placebo | 321 (25.2%)

† = Reasons for all 350 patient withdrawals was not given

Appendix Table 33 KQ6 Withdrawals due to adverse events—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | NR | Cilazapril 20mg/d Placebo | NR | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | Withdrawal due to side effects | Ramipril 10mg/d Placebo | 2/80 2/79 | NR
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | Dropped out of the study due to adverse events | Quinapril 20mg/d Control | 1/49 0/50 | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | N/A^†^ | Quinapril 40mg/d Placebo | 0/46 0/45 | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | NR | Quinapril 20mg/d Placebo | NR | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | NR | Candesartan 32mg/d Placebo | NR | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | Discontinuations due to adverse events | Quinapril 40 mg/d Placebo | 228/1280 103/1273 | NR

† All patients were followed-up

Appendix Table 34 KQ6 Hypotension—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | NR | Cilazapril 20mg/d Placebo | NR | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | NR | Ramipril 10mg/d Placebo | NR | NR
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | NR | Quinapril 20mg/d Control | NR | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | NR | Quinapril 40mg/d Placebo | NR | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | NR | Quinapril 20mg/d Placebo | NR | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | NR | Candesartan 32mg/d Placebo | NR | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | Hypotension | Quinapril 40 mg/d Placebo | 154/1280 70/1273 | Absolute difference 6.5% (4.5% to 8.5%)

Appendix Table 35 KQ6 Syncope—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | NR | Cilazapril 20mg/d Placebo | NR | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | NR | Ramipril 10mg/d Placebo | NR | NR
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | NR | Quinapril 20mg/d Control | NR | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | NR | Quinapril 40mg/d Placebo | NR | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | NR | Quinapril 20mg/d Placebo | NR | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | NR | Candesartan 32mg/d Placebo | NR | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | NR | Quinapril 40 mg/d Placebo | NR | NR

Appendix Table 36 KQ6 Cough—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | NR | Cilazapril 20mg/d Placebo | NR | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | NR | Ramipril 10mg/d Placebo | NR | NR
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | Severe cough | Quinapril 20mg/d Control | 1/49 0/50 | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | NR | Quinapril 40mg/d Placebo | NR | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | Cough | Quinapril 20mg/d Placebo | 33/878 2/872 | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | NR | Candesartan 32mg/d Placebo | NR | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | Cough | Quinapril 40 mg/d Placebo | 269/1280 141/1273 | Absolute difference 10% (7.2% to 12.7%)

Appendix Table 37 KQ6 Angioedema—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | NR | Cilazapril 20mg/d Placebo | NR | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | NR | Ramipril 10mg/d Placebo | NR | NR
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | NR | Quinapril 20mg/d Control | NR | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | NR | Quinapril 40mg/d Placebo | NR | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | NR | Quinapril 20mg/d Placebo | NR | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | NR | Candesartan 32mg/d Placebo | NR | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | NR | Quinapril 40 mg/d Placebo | NR | NR

Appendix Table 38 KQ6 Hyperkalemia—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | NR | Cilazapril 20mg/d Placebo | NR | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | Electrolytic derangement | Ramipril 10mg/d Placebo | 0/80 0/79 | NR
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | NR | Quinapril 20mg/d Control | NR | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | NR | Quinapril 40mg/d Placebo | NR | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | NR | Quinapril 20mg/d Placebo | NR | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | NR | Candesartan 32mg/d Placebo | NR | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | NR | Quinapril 40 mg/d Placebo | NR | NR

Appendix Table 39 KQ6 Rash—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | NR | Cilazapril 20mg/d Placebo | NR | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%; 5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | NR | Ramipril 10mg/d Placebo | NR | NR
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | NR | Quinapril 20mg/d Control | NR | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | NR | Quinapril 40mg/d Placebo | NR | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | NR | Quinapril 20mg/d Placebo | NR | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | NR | Candesartan 32mg/d Placebo | NR | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | NR | Quinapril 40 mg/d Placebo | NR | NR

Appendix Table 40 KQ6 Blood dyscrasias—Comparative effectiveness of medical therapies with or without ACEI or ARBs for stable ischemic heart disease

Study, year | Study Design | Population | Outcome/Definition | Group | Events, n/N | Events, “X”R (95% CI)
MARCATOR, 1995^53^ | RCT | Undergoing elective coronary angioplasty | NR | Cilazapril 20mg/d Placebo | NR | NR
APRES, 2000^54^ | RCT | Underwent elective CABG (82%;5–7 days prior to randomization) or PTCA (18%; 1–2 days prior to randomization) for angina | NR | Ramipril 10mg/d Placebo | NR | NR
Kondo et al, 2001^55,†^ | RCT | Received elective balloon angioplasty followed by coronary stenting | NR | Quinapril 20mg/d Control | NR | NR
PARIS, 2001^56^ | RCT | Underwent successful elective PCI with stent implantation | NR | Quinapril 40mg/d Placebo | NR | NR
QUIET, 2001^57^ | RCT | Underwent successful elective coronary angioplasty of atherectomy within 12–72 hours | NR | Quinapril 20mg/d Placebo | NR | NR
AACHEN, 2006^58^ | RCT | Undergoing elective coronary stent implantation (treatment started 7–14 days prior to intervention) | NR | Candesartan 32mg/d Placebo | NR | NR
IMAGINE, 2008^59^ | RCT | Underwent CABG (7–10 days prior) | NR | Quinapril 40 mg/d Placebo | NR | NR

Appendix Figure 44 KQ6. Withdrawals due to adverse events sensitivity analysis—Meta-analysis of randomized placebo-controlled + open-label trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=0.856866 (df=3) p=0.8358

I^2^ statistic=0%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Figure 45 KQ6. Cough sensitivity analysis—Meta-analysis of randomized placebo-controlled + open-label trials in patients with stable ischemic heart disease

Test for heterogeneity: Cochran Q=9.185671 (df=2) p=0.0101

I^2^ statistic=78.2%

Note: The squares represent individual point estimates. The size of the square represents the weight given to each study in the meta-analysis. Horizontal lines through each square represent 95% confidence intervals. The diamond represents the combined results. The solid vertical line extending from 1 is the null value.

Appendix Table 41 KQ1—Strength of evidence grading

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Evidence Grade | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Treatment | Control^*^ | Relative Risk (95% CI) | Absolute Risk | Evidence Grade | Importance
Total mortality - IHD (follow-up 2–4.8 years)
7 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1552/1907 7 (8.1%) | 1714/1905 9 (9%) | RR 0.91 (0.84 to 0.98) | 8 fewer per 1000 (from 2 fewer to 14 fewer) | HIGH | CRITICAL
7 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1552/1907 7 (8.1%) | 0.9% | RR 0.91 (0.84 to 0.98) | 0 fewer per 1,000 | HIGH | CRITICAL
7 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1552/1907 7 (8.1%) | 12% | RR 0.91 (0.84 to 0.98) | 10 fewer per 1,000 | HIGH | CRITICAL
Total mortality - vs. CCB (follow-up 2–3 years)
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 23/1495 (1.5%) | 19/1491 (1.3%) | RR 1.21 (0.66 to 2.21) | 3 more per 1000 (from 4 fewer to 16 more) | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 23/1495 (1.5%) | 1.1% | RR 1.21 (0.66 to 2.21) | 2 more per 1,000 | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 23/1495 (1.5%) | 1.4% | RR 1.21 (0.66 to 2.21) | 2 more per 1,000 | MODERATE | CRITICAL
Total mortality - IHD risk equivalents (follow-up 1.6–4.8 years)
1 | randomized trial | single trial | no serious inconsistency | no serious indirectness | very serious | none | 53/196 (27.0%) | 50/201 (24.9%) | RR 1.08 (0.78 to 1.52) | 20 more per 1000 (from 55 fewer to 129 more) | LOW | CRITICAL
Cardiovascular mortality - IHD (follow-up 2–4.8 years)
6 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 883/18848 (4.7%) | 1021/1882 8 (5.4%) | RR 0.87 (0.75 to 1.02) | 7 fewer per 1000 (from 14 fewer to 1 more) | MODERATE | CRITICAL
6 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 883/18848 (4.7%) | 0.3% | RR 0.87 (0.75 to 1.02) | 0 fewer per 1,000 | MODERATE | CRITICAL
6 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 883/18848 (4.7%) | 8.1% | RR 0.87 (0.75 to 1.02) | 10 fewer per 1,000 | MODERATE | CRITICAL
Cardiovascular mortality - vs. CCB (follow-up 2–3 years)
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 11/1495 (0.7%) | 11/1491 (0.7%) | RR 1.00 (0.43 to 2.29) | 0 fewer per 1000 (from 4 fewer to 9 more) | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 11/1495 (0.7%) | 0.73% | RR 1.00 (0.43 to 2.29) | 0 fewer per 1,000 | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 11/1495 (0.7%) | 0.75% | RR 1.00 (0.43 to 2.29) | 0 fewer per 1,000 | MODERATE | CRITICAL
Cardiovascular mortality - IHD risk equivalents (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 32/196 (16.3%) | 31/201 (15.4%) | RR 1.06 (0.67 to 1.67) | 9 more per 1000 (from 51 fewer to 103 more) | MODERATE | CRITICAL
Nonfatal myocardial infarction - IHD (follow-up 2–4.8 years)
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 813/16123 (5%) | 981/16087 (6.1%) | RR 0.83 (0.73 to 0.94) | 10 fewer per 1000 (from 4 fewer to 16 fewer) | HIGH | CRITICAL
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 813/16123 (5%) | 2.9% | RR 0.83 (0.73 to 0.94) | 4 fewer per 1,000 | HIGH | CRITICAL
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 813/16123 (5%) | 7.2% | RR 0.83 (0.73 to 0.94) | 12 fewer per 1,000 | HIGH | CRITICAL
Nonfatal myocardial infarction - vs. CCB (follow-up 2 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 11/673 (1.6%) | 14/663 (2.1%) | RR 0.77 (0.35 to 1.69) | 5 fewer per 1000 (from 14 fewer to 14 more) | MODERATE | CRITICAL
Nonfatal myocardial infarction - IHD risk equivalents (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | very serious | none | 9/196 (4.6%) | 7/201 (3.5%) | RR 1.31 (0.50 to 3.47) | 11 more per 1000 (from 18 fewer to 86 more) | LOW | CRITICAL
Stroke - IHD (follow-up 2–4.8 years)
7 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 454/19077 (2.4%) | 581/19059 (3%) | RR 0.79 (0.67 to 0.93) | 6 fewer per 1000 (from 2 fewer to 10 fewer) | MODERATE | CRITICAL
7 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 454/19077 (2.4%) | 1.3% | RR 0.79 (0.67 to 0.93) | 2 fewer per 1,000 | MODERATE | CRITICAL
7 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 454/19077 (2.4%) | 4.9% | RR 0.79 (0.67 to 0.93) | 10 fewer per 1,000 | MODERATE | CRITICAL
Stroke - vs. CCB (follow-up 2–3 years)
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 24/1495 (1.6%) | 22/1491 (1.5%) | RR 1.09 (0.61 to 1.94) | 1 more per 1000 (from 6 fewer to 14 more) | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 24/1495 (1.6%) | 0.9% | RR 1.09 (0.61 to 1.94) | 0 more per 1,000 | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 24/1495 (1.6%) | 1.9% | RR 1.09 (0.61 to 1.94) | 1 more per 1,000 | MODERATE | CRITICAL
Stroke - IHD risk equivalents (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | very serious | none | 18/196 (9.2%) | 11/201 (5.5%) | RR 1.60 (0.81 to 3.46) | 33 more per 1000 (from 10 fewer to 135 more) | LOW | CRITICAL
Cardiovascular mortality, myocardial infarction, stroke - IHD (follow-up 4.5–4.8 years)
3 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1431/1175 7 (12.2%) | 1686/1175 6 (14.3%) | RR 0.86 (0.77 to 0.95) | 20 fewer per 1000 (from 7 fewer to 33 fewer) | HIGH | CRITICAL
3 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1431/1175 7 (12.2%) | 10% | RR 0.86 (0.77 to 0.95) | 13 fewer per 1,000 | HIGH | CRITICAL
3 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1431/1175 7 (12.2%) | 18% | RR 0.86 (0.77 to 0.95) | 25 fewer per 1,000 | HIGH | CRITICAL
Cardiovascular mortality, myocardial infarction, stroke - IHD risk equivalents (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | very serious | none | 48/196 (24.5%) | 41/201 (20.4%) | RR 1.20 (0.83 to 1.73) | 41 more per 1000 (from 35 fewer to 149 more) | LOW | CRITICAL
Atrial fibrillation - IHD (follow-up 4.5–4.7 years)
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 268/7245 (3.7%) | 271/7016 (3.9%) | RR 0.98 (0.83 to 1.15) | 1 fewer per 1000 (from 7 fewer to 6 more) | HIGH | IMPORTANT
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 268/7245 (3.7%) | 2.3% | RR 0.98 (0.83 to 1.15) | 0 fewer per 1,000 | HIGH | IMPORTANT
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 268/7245 (3.7%) | 6.1% | RR 0.98 (0.83 to 1.15) | 1 fewer per 1,000 | HIGH | IMPORTANT
Angina symptoms: Treadmill exercise test (follow-up 6 months)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 151 | 152 | WMD 3.5 minutes | 3.5 (2.82 to 4.18) | MODERATE | IMPORTANT
Total Hospitalizations – IHD (follow-up 4.7 years)
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 1756/3262 (53.8%) | 1815/3281 (55.3%) | RR 0.97 (0.94 to 1.00) | 17 fewer per 1000 (from 33 fewer to 0 more) | MODERATE | IMPORTANT
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 1756/3262 (53.8%) | 51% | RR 0.97 (0.94 to 1.00) | 15 fewer per 1,000 | MODERATE | IMPORTANT
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 1756/3262 (53.8%) | 94% | RR 0.97 (0.94 to 1.00) | 28 fewer per 1,000 | MODERATE | IMPORTANT
Hospitalizations for angina - IHD (follow-up 2–4.7 years)
5 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 978/8809 (11.1%) | 1007/8819 (11.4%) | RR 0.97 (0.89 to 1.06) | 3 fewer per 1000 (from 13 fewer to 7 more) | HIGH | IMPORTANT
5 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 978/8809 (11.1%) | 9.7% | RR 0.97 (0.89 to 1.06) | 2 fewer per 1,000 | HIGH | IMPORTANT
5 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 978/8809 (11.1%) | 13.6% | RR 0.97 (0.89 to 1.06) | 4 fewer per 1,000 | HIGH | IMPORTANT
Hospitalizations for angina - vs. CCB (follow-up 2–3 years)
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 142/1498 (9.5%) | 101/1491 (6.8%) | RR 1.38 (0.95 to 2.02) | 26 more per 1000 (from 3 fewer to 69 more) | MODERATE | IMPORTANT
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 142/1498 (9.5%) | 6% | RR 1.38 (0.95 to 2.02) | 22 more per 1,000 | MODERATE | IMPORTANT
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 142/1498 (9.5%) | 7.7% | RR 1.38 (0.95 to 2.02) | 29 more per 1,000 | MODERATE | IMPORTANT
Hospitalizations for heart failure - IHD (follow-up 2–4.8 years)
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 454/18848 (2.4%) | 540/18828 (2.9%) | RR 0.83 (0.70 to 0.98) | 5 fewer per 1000 (from 1 fewer to 9 fewer) | HIGH | IMPORTANT
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 454/18848 (2.4%) | 0.8% | RR 0.83 (0.70 to 0.98) | 1 fewer per 1,000 | HIGH | IMPORTANT
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 454/18848 (2.4%) | 4.3% | RR 0.83 (0.70 to 0.98) | 7 fewer per 1,000 | HIGH | IMPORTANT
Hospitalizations for heart failure - vs. CCB (follow-up 2–3 years)
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 13/1495 (0.9%) | 15/1491 (1%) | RR 0.87 (0.41 to 1.83) | 1 fewer per 1000 (from 6 fewer to 8 more) | MODERATE | IMPORTANT
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 13/1495 (0.9%) | 0.5% | RR 0.87 (0.41 to 1.83) | 0 fewer per 1,000 | MODERATE | IMPORTANT
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 13/1495 (0.9%) | 1.4% | RR 0.87 (0.41 to 1.83) | 1 fewer per 1,000 | MODERATE | IMPORTANT
Need for revascularization - IHD (follow-up 2–4.7 years)
5 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1779/14611 (12.2%) | 1971/1461 8 (13.5%) | RR 0.90 (0.85 to 0.96) | 14 fewer per 1000 (from 5 fewer to 20 fewer) | HIGH | CRITICAL
5 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1779/14611 (12.2%) | 9.8% | RR 0.90 (0.85 to 0.96) | 9 fewer per 1,000 | HIGH | CRITICAL
5 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1779/14611 (12.2%) | 18.3% | RR 0.90 (0.85 to 0.96) | 18 fewer per 1,000 | HIGH | CRITICAL
Need for revascularization - vs. CCB (follow-up 2–3 years)
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 170/1495 (11.4%) | 159/1491 (10.7%) | RR 1.06 (0.83 to 1.36) | 6 more per 1000 (from 18 fewer to 39 more) | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 170/1495 (11.4%) | 9.8% | RR 1.06 (0.83 to 1.36) | 5 more per 1,000 | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 170/1495 (11.4%) | 11.8% | RR 1.06 (0.83 to 1.36) | 7 more per 1,000 | MODERATE | CRITICAL

* Risk in the control group is reported as observed pooled, low and high-risks derived from included trials

Abbreviations: CCB=calcium channel blocker; CI=confidence interval; CV=cardiovascular; IHD=ischemic heart disease; MI=myocardial infarction; RR=relative risk

Appendix Table 41a KQ1—Pertinent subgroup strength of evidence grading

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Quality | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Treatment | Control^*^ | Relative(95% CI) | Absolute | Quality | Importance
Total mortality - IHD ACEI only (follow-up 2–4.8 years)
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1188/16123 (7.4%) | 1365/16087 (8.5%) | RR 0.87 (0.81 to 0.94) | 11 fewer per 1000 (from 5 fewer to 16 fewer) | HIGH | CRITICAL
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1188/16123 (7.4%) | 0.9% | RR 0.87 (0.81 to 0.94) | 1 fewer per 1,000 | HIGH | CRITICAL
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1188/16123 (7.4%) | 12.2% | RR 0.87 (0.81 to 0.94) | 15 fewer per 1,000 | HIGH | CRITICAL
Total mortality - IHD ARB only (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 364/2954 (12.3%) | 349/2972 (11.7%) | RR 1.05(0.91 to1.2) | 6 more per1000 (from 11 fewer to 23 more) | MODERATE | CRITICAL
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 364/2954 (12.3%) | 11.7% | RR 1.05(0.91 to1.2) | 5 more per1,000 | MODERATE | CRITICAL
Total mortality - ACEI vs CCB (follow-up 2–3 years)
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 23/1495(1.5%) | 19/1491(1.3%) | RR 0 (0 to0) | 13 fewer per1000 (from 13 fewer to 13 fewer) | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 23/1495(1.5%) | 1.1% | RR 0 (0 to0) | 10 fewer per 1,000 | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 23/1495(1.5%) | 1.4% | RR 0 (0 to0) | 13 fewer per1,000 | MODERATE | CRITICAL
Total mortality - ARB vs CCB
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to0) | 0 fewer per1,000 | INSUFFICIENT
Total mortality - IHD risk equivalents ACEI only (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | very serious | none | 53/196(27%) | 50/201(24.9%) | RR 1.08(0.78 to1.52) | 20 more per1000 (from 55 fewer to 129 more) | LOW | CRITICAL
Total mortality - IHD risk equivalents ARB only
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to0) | 0 fewer per1,000 | INSUFFICIENT
Cardiovascular mortality - IHD ACEI only (follow-up 2–4.8 years)
5 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 656/15894(4.1%) | 798/15856(5%) | RR 0.83(0.70 to0.98) | 9 fewer per1000 (from 1 fewer to 15 fewer) | MODERATE | CRITICAL
5 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 656/15894(4.1%) | 0.3% | RR 0.83(0.70 to0.98) | 0 fewer per1,000 | MODERATE | CRITICAL
5 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 656/15894(4.1%) | 8.1% | RR 0.83(0.70 to0.98) | 13 fewer per1,000 | MODERATE | CRITICAL
Cardiovascular mortality - IHD ARB only (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 227/2954(7.7%) | 223/2972(7.5%) | RR 1.02(0.86 to1.22) | 1 more per1000 (from 10 fewer to 17 more) | MODERATE | CRITICAL
Cardiovascular mortality - ACEI vs CCB (follow-up 2–3 years)
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 11/1495(0.7%) | 11/1491(0.7%) | RR 1.00(0.43 to2.29) | 0 fewer per1000 (from 4 fewer to 9 more) | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 11/1495(0.7%) | 0.73% | RR 1.00(0.43 to2.29) | 0 fewer per1,000 | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 11/1495(0.7%) | 0.75% | RR 1.00(0.43 to2.29) | 0 fewer per1,000 | MODERATE | CRITICAL
Cardiovascular mortality - ARB vs CCB
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to0) | 0 fewer per1,000 | INSUFFICIENT
Cardiovascular mortality - IHD risk equivalents ACEI only (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 32/196(16.3%) | 31/201(15.4%) | RR 1.06(0.67 to1.67) | 9 more per1000 (from 51 fewer to 103 more) | MODERATE | CRITICAL
Cardiovascular mortality - IHD risk equivalents ARB only
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to0) | 0 fewer per1,000 | INSUFFICIENT
Nonfatal myocardial infarction - IHD ACEI only (follow-up 2–4.8 years)
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 813/16123(5%) | 987/16087(6.1%) | RR 0.83(0.73 to0.94) | 10 fewer per1000 (from 4 fewer to 16 fewer) | HIGH | CRITICAL
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 813/16123(5%) | 2.9% | RR 0.83(0.73 to0.94) | 4 fewer per1,000 | HIGH | CRITICAL
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 813/16123(5%) | 7.2% | RR 0.83(0.73 to0.94) | 12 fewer per1,000 | HIGH | CRITICAL
Nonfatal myocardial infarction - IHD ARB only
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to0) | 0 fewer per1,000 | INSUFFICIENT
Nonfatal myocardial infarction - ACEI vs CCB (follow-up 2 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 11/673(1.6%) | 14/663(2.1%) | RR 0.77(0.35 to1.69) | 5 fewer per1000 (from 14 fewer to 14 more) | MODERATE | CRITICAL
Nonfatal myocardial infarction - ARB vs CCB
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to0) | 0 fewer per1,000 | INSUFFICIENT
Nonfatal myocardial infarction - IHD risk equivalents ACEI only (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | very serious | none | 9/196 (4.6%) | 7/201 (3.5%) | RR 1.31(0.50 to3.47) | 11 more per1000 (from 18 fewer to 86 more) | LOW | CRITICAL
Nonfatal myocardial infarction - IHD risk equivalents ARB only
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to 0) | 0 fewer per1,000 | INSUFFICIENT
Stroke - IHD ACEI only (follow-up 2–4.8 years)
6 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 342/16123(2.1%) | 445/16087(2.8%) | RR 0.78(0.63 to0.97) | 6 fewer per1000 (from 1 fewer to 10 fewer) | MODERATE | CRITICAL
6 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 342/16123(2.1%) | 1.7% | RR 0.78(0.63 to0.97) | 3 fewer per1,000 | MODERATE | CRITICAL
6 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 342/16123(2.1%) | 4.9% | RR 0.78(0.63 to0.97) | 10 fewer per1,000 | MODERATE | CRITICAL
Stroke - IHD ARB only (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 112/2954(3.8%) | 136/2972(4.6%) | RR 0.83(0.65 to1.06) | 8 fewer per1000 (from 16 fewer to 3 more) | MODERATE | CRITICAL
Stroke - ACEI vs CCB (follow-up 2–3 years)
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 24/1495(1.6%) | 22/1491(1.5%) | RR 1.09(0.61 to1.94) | 1 more per1000 (from 6 fewer to 14 more) | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 24/1495(1.6%) | 0.9% | RR 1.09(0.61 to1.94) | 0 more per1,000 | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 24/1495(1.6%) | 1.9% | RR 1.09(0.61 to1.94) | 1 more per1,000 | MODERATE | CRITICAL
Stroke - ARB vs CCB
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to0) | 0 fewer per1,000 | NSUFFICIENT
Stroke - IHD risk equivalents ACEI only (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | very serious | none | 18/196(9.2%) | 11/201(5.5%) | RR 1.60(0.81 to3.46) | 33 more per1000 (from 10 fewer to 135 more) | LOW | CRITICAL
Stroke - IHD risk equivalents ARB only
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to0) | 0 fewer per1,000 | INSUFFICIENT
Cardiovascular mortality, myocardial infarction, stroke - IHD ACEI only (follow-up 4.5–4.8 years)
2 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 1047/8803(11.9%) | 1246/8784(14.2%) | RR 0.85(0.72 to1.01) | 21 fewer per1000 (from 40 fewer to 1 more) | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 1047/8803(11.9%) | 10.8% | RR 0.85(0.72 to1.01) | 16 fewer per 1,000 | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 1047/8803(11.9%) | 17.8% | RR 0.85(0.72 to1.01) | 26 fewer per 1,000 | MODERATE | CRITICAL
Cardiovascular mortality, myocardial infarction, stroke - IHD ARB only (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | no serious imprecision | none | 384/2954(13%) | 440/2972(14.8%) | RR 0.8 8(0.77 to1.00) | 18 fewer per1000 (from 34 fewer to 0 more) | MODERATE | CRITICAL
Cardiovascular mortality, myocardial infarction, stroke - ACEI vs CCB
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to0) | 0 fewer per1,000 | INSUFFICIENT
Cardiovascular mortality, myocardial infarction, stroke - ARB vs CCB
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to0) | 0 fewer per1,000 | INSUFFICIENT
Cardiovascular mortality, myocardial infarction, stroke - IHD risk equivalents ACEI only (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | very serious | none | 48/196(24.5%) | 41/201(20.4%) | RR 1.20(0.83 to1.73) | 41 more per1000 (from 35 fewer to 149 more) | LOW | CRITICAL
Cardiovascular mortality, myocardial infarction, stroke - IHD risk equivalents ARB only
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to0) | 0 fewer per1,000 | INSUFFICIENT
Hospitalizations for heart failure - IHD ACEI only (follow-up 2–4.8 years)
5 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 320/15894(2%) | 411/15856(2.6%) | RR 0.78(0.67 to 0.90) | 6 fewer per1000 (from 3 fewer to 9 fewer) | HIGH | IMPORTANT
5 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 320/15894(2%) | 0.8% | RR 0.78(0.67 to 0.90) | 1 fewer per1,000 | HIGH | IMPORTANT
5 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 320/15894(2%) | 3.4% | RR 0.78(0.67 to 0.90) | 7 fewer per1,000 | HIGH | IMPORTANT
Hospitalizations for heart failure - IHD ARB only (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 134/2954(4.5%) | 129/2972(4.3%) | RR 1.04(0.83 to1.32) | 2 more per1000 (from 7 fewer to 14 more) | MODERATE | IMPORTANT
Hospitalizations for heart failure - ACEI vs CCB
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 13/1495(0.9%) | 15/1491(1%) | RR 0.87(0.41 to1.83) | 1 fewer per1000 (from 6 fewer to 8 more) | MODERATE | IMPORTANT
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 13/1495(0.9%) | 0.5% | RR 0.87(0.41 to1.83) | 0 fewer per1,000 | MODERATE | IMPORTANT
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 13/1495(0.9%) | 1.4% | RR 0.87(0.41 to1.83) | 1 fewer per1,000 | MODERATE | IMPORTANT
Hospitalizations for heart failure - ARB vs CCB
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to0) | 0 fewer per1,000 | INSUFFICIENT
Hospitalizations for heart failure - IHD risk equivalents ACEI only
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to 0) | 0 fewer per 1,000 | INSUFFICIENT
Hospitalizations for heart failure - IHD risk equivalents ARB only
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to 0) | 0 fewer per 1,000 | INSUFFICIENT
Need for revascularization - IHD ACEI only (follow-up 2–4.7 years)
4 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1430/11657 (12.3%) | 1581/11646 (13.6%) | RR 0.90 (0.84 to 0.96) | 14 fewer per 1000 (from 5 fewer to 22 fewer) | HIGH | CRITICAL
4 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1430/11657 (12.3%) | 9.8% | RR 0.90 (0.84 to 0.96) | 9 fewer per 1,000 | HIGH | CRITICAL
4 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 1430/11657 (12.3%) | 18.3% | RR 0.90 (0.84 to 0.96) | 18 fewer per 1,000 | HIGH | CRITICAL
Need for revascularization - IHD ARB only (follow-up 4.8 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 349/2954 (11.8%) | 390/2972 (13.1%) | RR 0.90 (0.79 to 1.03) | 13 fewer per 1000 (from 28 fewer to 4 more) | MODERATE | CRITICAL
Need for revascularization - ACEI vs CCB (follow-up 2–3 years)
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 170/1495 (11.4%) | 159/1491 (10.7%) | RR 1.06 (0.83 to 1.36) | 6 more per 1000 (from 18 fewer to 39 more) | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 170/1495 (11.4%) | 9.8% | RR 1.06 (0.83 to 1.36) | 5 more per 1,000 | MODERATE | CRITICAL
2 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 170/1495 (11.4%) | 11.8% | RR 1.06 (0.83 to 1.36) | 7 more per 1,000 | MODERATE | CRITICAL
Need for revascularization - ARB vs CCB
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to 0) | 0 fewer per 1,000 | INSUFFICIENT
Need for revascularization - IHD risk equivalents ACEI only
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to 0) | 0 fewer per 1,000 | INSUFFICIENT
Need for revascularization - IHD risk equivalents ARB only
0 | no evidence available | | | | | none | 0/0 (0%) | 0/0 (0%) | RR 0 (0 to 0) | 0 fewer per 1,000 | INSUFFICIENT

* Risk in the control group is reported as observed pooled, low and high-risks derived from included trials

Abbreviations: CCB=calcium channel blocker; CI=confidence interval; CV=cardiovascular; IHD=ischemic heart disease; MI=myocardial infarction; RR=relative risk

Appendix Table 42 KQ2—Strength of evidence grading

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Evidence Grade | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Treatment | Control | Relative (95% CI) | Absolute Risk | Evidence Grade | Importance
Total mortality (follow-up 56 months)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 1065/8502 (12.5%) | 1014/8576 (11.8%) | RR 1.07 (0.98 to 1.16) | 8 more per 1000 (from 2 fewer to 19 more) | MODERATE | CRITICAL
Cardiovascular mortality (follow-up 56 months)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 620/8502 (7.3%) | 603/8576 (7%) | RR 1.04 (0.93 to 1.17) | 3 more per 1000 (from 5 fewer to 12 more) | MODERATE | CRITICAL
Mmyocardial infarction (follow-up 56 months)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 438/8502 (5.2%) | 413/8576 (4.8%) | RR 1.08 (0.94 to 1.23) | 4 more per 1000 (from 3 fewer to 11 more) | MODERATE | CRITICAL
Stroke (follow-up 56 months)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 373/8502 (4.4%) | 405/8576 (4.7%) | RR 0.93 (0.81 to 1.07) | 3 fewer per 1000 (from 9 fewer to 3 more) | MODERATE | CRITICAL
Cardiovascular mortality, myocardial infarction, stroke (follow-up 56 months)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 1200/8502 (14.1%) | 1210/8576 (14.1%) | RR 1.00 (0.93 to 1.09) | 0 fewer per 1000 (from 10 fewer to 13 more) | MODERATE | CRITICAL
New onset atrial fibrillation (follow-up 56 months)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 537/8502 (6.3%) | 570/8576 (6.6%) | RR 0.96 (0.85 to 1.07) | 3 fewer per 1000 (from 10 fewer to 5 more) | MODERATE | IMPORTANT
Worsening/new angina (follow-up 56 months)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 538/8502 (6.3%) | 567/8576 (6.6%) | RR 0.96 (0.85 to 1.08) | 3 fewer per 1000 (from 10 fewer to 5 more) | MODERATE | IMPORTANT
Hospitalization for angina (follow-up 56 months)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 952/8502 (11.2%) | 925/8576 (10.8%) | RR 1.04 (0.95 to 1.14) | 4 more per 1000 (from 5 fewer to 15 more) | MODERATE | IMPORTANT
Hospitalization for heart failure (follow-up 56 months)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 332/8502 (3.9%) | 354/8576 (4.1%) | RR 0.95 (0.82 to 1.1) | 2 fewer per 1000 (from 7 fewer to 4 more) | MODERATE | CRITICAL
Revascularization (follow-up 56 months)
1 | randomized trial | no serious limitations | single study | no serious indirectness | no serious imprecision | none | 1303/8502 (15.3%) | 1269/8576 (14.8%) | RR 1.04 (0.97 to 1.13) | 6 more per 1000 (from 4 fewer to 19 more) | Moderate | CRITICAL

Abbreviations: CI=confidence interval; RR=relative risk

Appendix Table 43 KQ3—Strength of evidence grading

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Evidence Grade | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Treatment | Control^*^ | Relative Risk (95% CI) | Absolute Risk | Evidence Grade | Importance
Total mortality (follow-up 0.5–3 years)
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 64/3422 (1.9%) | 64/2687 (2.4%) | RR 0.94 (0.67 to 1.37) | 1 fewer per 1000 (from 8 fewer to 9 more) | MODERATE | CRITICAL
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 64/3422 (1.9%) | 0% | RR 0.94 (0.67 to 1.37) | 0 fewer per 1,000 | MODERATE | CRITICAL
6 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 64/3422 (1.9%) | 10% | RR 0.94 (0.67 to 1.37) | 6 fewer per 1,000 | MODERATE | CRITICAL
Cardiovascular mortality (follow-up 0.5–3 years)
5 | randomized trial | no serious limitations | Serious | no serious indirectness | serious | none | 32/2347 (1.4%) | 37/2326 (1.6%) | RR 0.91 (0.53 to 1.57) | 1 fewer per 1000 (from 8 fewer to 9 more) | LOW | CRITICAL
5 | randomized trial | no serious limitations | Serious | no serious indirectness | serious | none | 32/2347 (1.4%) | 0% | RR 0.91 (0.53 to 1.57) | 0 fewer per 1,000 | LOW | CRITICAL
5 | randomized trial | no serious limitations | Serious | no serious indirectness | serious | none | 32/2347 (1.4%) | 10% | RR 0.91 (0.53 to 1.57) | 8 fewer per 1,000 | LOW | CRITICAL
Nonfatal myocardial infarction (follow-up 0.5–3 years)
5 | randomized trial | no serious limitations | Serious | no serious indirectness | serious | none | 81/3342 (2.4%) | 71/2608 (2.7%) | RR 0.89 (0.65 to 1.24) | 3 fewer per 1000 (from 9 fewer to 6 more) | LOW | CRITICAL
5 | randomized trial | no serious limitations | Serious | no serious indirectness | serious | none | 81/3342 (2.4%) | 0% | RR 0.89 (0.65 to 1.24) | 0 fewer per 1,000 | LOW | CRITICAL
5 | randomized trial | no serious limitations | Serious | no serious indirectness | serious | none | 81/3342 (2.4%) | 4.6% | RR 0.89 (0.65 to 1.24) | 5 fewer per 1,000 | LOW | CRITICAL
Stroke (follow-up 2.8–3 years)
2 | randomized trial | no serious limitations | Serious | no serious indirectness | serious | none | 15/1360 (1.1%) | 15/1352 (1.1%) | RR 1.01 (0.50 to 2.04) | 0 fewer per 1000 (from −1 fewer to 1 more) | LOW | CRITICAL
2 | randomized trial | no serious limitations | Serious | no serious indirectness | serious | none | 15/1360 (1.1%) | 1.1% | RR 1.01 (0.50 to 2.04) | 0 more per 1,000 | LOW | CRITICAL
2 | randomized trial | no serious limitations | Serious | no serious indirectness | serious | none | 15/1360 (1.1%) | 1.3% | RR 1.01 (0.50 to 2.04) | 0 more per 1,000 | LOW | CRITICAL
Cardiovascular mortality, myocardial infarction, stroke (follow-up 3 years)
1 | randomized trial | no serious limitations | single trial | no serious indirectness | serious | none | 45/1280 (3.5%) | 45/1273 (3.5%) | RR 0.99 (0.66 to 1.49) | 0 fewer per 1000 (from 12 fewer to 17 more) | MODERATE | CRITICAL
Atrial fibrillation (follow-up 3 years)
1 | randomized trial | no serious limitations | single trial | no serious indirectness | serious | none | 114/1280 (8.9%) | 101/1273 (7.9%) | RR 1.12 (0.87 to 1.45) | 9 more per 1000 (from 10 fewer to 36 more) | MODERATE | IMPORTANT
Hospitalization for angina (follow-up 2.3–3 years)
3 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 102/2238 (4.6%) | 99/2224 (4.5%) | RR 1.02 (0.78 to 1.34) | 1 more per 1000 (from 10 fewer to 15 more) | MODERATE | IMPORTANT
3 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 102/2238 (4.6%) | 3.0% | RR 1.02 (0.78 to 1.34) | 0 more per 1,000 | MODERATE | IMPORTANT
3 | randomized trial | no serious limitations | serious | no serious indirectness | no serious imprecision | none | 102/2238 (4.6%) | 11.4% | RR 1.02 (0.78 to 1.34) | 2 more per 1,000 | MODERATE | IMPORTANT
Hospitalization for heart failure (follow-up 3 years)
1 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | serious | none | 15/1280 (1.2%) | 14/1273 (1.1%) | RR 1.07 (0.52 to 2.20) | 1 more per 1000 (from 5 fewer to 13 more) | LOW | CRITICAL
Revascularization (follow-up 0.5–3 years)
4 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 274/2464 (11.1%) | 106/1736 (6.1%) | RR 1.28 (1.03 to 1.59) | 17 more per 1000 (from 2 more to 36 more) | HIGH | CRITICAL
4 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 274/2464 (11.1%) | 3.2% | RR 1.28 (1.03 to 1.59) | 8 more per 1,000 | HIGH | CRITICAL
4 | randomized trial | no serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | none | 274/2464 (11.1%) | 15.6% | RR 1.28 (1.03 to 1.59) | 43 more per 1,000 | HIGH | CRITICAL

* Risk in the control group is reported as observed pooled, low and high-risks derived from included trials

Abbreviations: CI=confidence interval; RR=relative risk

Appendix Table 44 KQ4—Strength of evidence grading

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Evidence Grade | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Control | | Relative (95% CI) | Absolute | Evidence Grade | Importance
Withdrawals due to ADR - IHD (follow-up 2–4.8 years)
3 | randomised trial | no serious limitations | serious | no serious indirectness | serious | reporting bias | 732/5139 (14.2%) | 343/5096 (6.7%) | RR 2.30 (1.34 to 3.95) | 87 more per 1000 (from 23 more to 198 more) | LOW | IMPORTANT
3 | randomised trial | no serious limitations | serious | no serious indirectness | serious | reporting bias | 732/5139 (14.2%) | 1.0% | RR 2.30 (1.34 to 3.95) | 12 more per 1,000 | LOW | IMPORTANT
3 | randomised trial | no serious limitations | serious | no serious indirectness | serious | reporting bias | 732/5139 (14.2%) | 10.8% | RR 2.30 (1.34 to 3.95) | 140 more per 1,000 | LOW | IMPORTANT
Withdrawals due to ADR - vs CCBs (follow-up 2–3 years)
2 | randomised trial | no serious limitations | serious | no serious indirectness | serious | reporting bias | 174/1495 (11.6%) | 128/1491 (8.6%) | RR 1.40 (0.92 to 2.12) | 34 more per 1000 (from 7 fewer to 96 more) | LOW | IMPORTANT
2 | randomised trial | no serious limitations | serious | no serious indirectness | serious | reporting bias | 174/1495 (11.6%) | 5.0% | RR 1.40 (0.92 to 2.12) | 19 more per 1,000 | LOW | IMPORTANT
2 | randomised trial | no serious limitations | serious | no serious indirectness | serious | reporting bias | 174/1495 (11.6%) | 13.1% | RR 1.40 (0.92 to 2.12) | 52 more per 1,000 | LOW | IMPORTANT
Hypotension - IHD (follow-up 0.5–4.5 years)
3 | randomised trial | no serious limitations | serious | no serious indirectness | serious | reporting bias | 68/5490 (1.2%) | 26/5484 (0.5%) | RR 1.79 (0.68 to 4.71) | 5 fewer per 1000 (from 5 fewer to 5 fewer) | LOW | IMPORTANT
3 | randomised trial | no serious limitations | serious | no serious indirectness | serious | reporting bias | 68/5490 (1.2%) | 0.06% | RR 1.79 (0.68 to 4.71) | 0 fewer per 1,000 | LOW | IMPORTANT
3 | randomised trial | no serious limitations | serious | no serious indirectness | serious | reporting bias | 68/5490 (1.2%) | 3.2% | RR 1.79 (0.68 to 4.71) | 32 fewer per 1,000 | LOW | IMPORTANT
Hypotension - vs CCBs (follow-up 2 years)
1 | randomised trial | no serious limitations | single trial | no serious indirectness | Very serious imprecision | none | 64/673 (9.5%) | 22/663 (3.3%) | RR 2.87 (1.79 to 4.60) | 62 more per 1000 (from 26 more to 119 more) | LOW | IMPORTANT
Syncope - IHD (follow-up 4.5–4.8 years)
2 | randomised trial | no serious limitations | serious | no serious indirectness | Serious | none | 203/8803 (2.3%) | 162/8784 (1.8%) | RR 1.24 (1.02 to 1.52) | 4 more per 1000 (from 0 more to 9 more) | LOW | IMPORTANT
2 | randomised trial | no serious limitations | serious | no serious indirectness | Serious | none | 203/8803 (2.3%) | 0.2% | RR 1.24 (1.02 to 1.52) | 0 more per 1,000 | LOW | IMPORTANT
2 | randomised trial | no serious limitations | serious | no serious indirectness | Serious | none | 203/8803 (2.3%) | 3.9% | RR 1.24 (1.02 to 1.52) | 9 more per 1,000 | LOW | IMPORTANT
Cough - IHD (follow-up 2–4.8 years)
3 | randomised trial | no serious limitations | serious | no serious indirectness | Serious | reporting bias | 1729/9476 (18.2%) | 1183/9439 (12.5%) | RR 1.67 (1.22 to 2.29) | 84 more per 1000 (from 28 more to 161 more) | LOW | IMPORTANT
3 | randomised trial | no serious limitations | serious | no serious indirectness | Serious | reporting bias | 1729/9476 (18.2%) | 0.2% | RR 1.67 (1.22 to 2.29) | 1 more per 1,000 | LOW | IMPORTANT
3 | randomised trial | no serious limitations | serious | no serious indirectness | Serious | reporting bias | 1729/9476 (18.2%) | 27.5% | RR 1.67 (1.22 to 2.29) | 184 more per 1,000 | LOW | IMPORTANT
Cough - vs CCBs (follow-up 2 years)
1 | randomised trial | no serious limitations | single trial | no serious indirectness | very serious imprecision | none | 84/673(12.5%) | 34/663 (5.1%) | RR 2.43 (1.66 to 3.57) | 73 more per 1000 (from 34 more to 131 more) | LOW | IMPORTANT
1 | randomised trial | no serious limitations | single trial | no serious indirectness | very serious imprecision | none | 84/673(12.5%) | 0% | RR 2.43 (1.66 to 3.57) | 0 more per 1,000 | LOW | IMPORTANT
Angioedema - IHD (follow-up 4.5–4.8 years)
2 | randomised trial | no serious limitations | serious | no serious indirectness | serious | none | 13/8803 (0.1%) | 6/8784 (0.1%) | RR 2.03 (0.75 to 5.47) | 1 more per 1000 (from 0 fewer to 4 more) | LOW | IMPORTANT
2 | randomised trial | no serious limitations | serious | no serious indirectness | serious | none | 13/8803 (0.1%) | 0.2% | RR 2.03 (0.75 to 5.47) | 2 more per 1,000 | LOW | IMPORTANT
2 | randomised trial | no serious limitations | serious | no serious indirectness | serious | none | 13/8803 (0.1%) | 1.2% | RR 2.03 (0.75 to 5.47) | 12 more per 1,000 | LOW | IMPORTANT
Hyperkalemia - IHD (follow-up 4.5–4.7 years)
2 | randomised trial | no serious limitations | serious | no serious indirectness | serious | reporting bias | 506/7493 (6.8%) | 346/7544 (4.6%) | RR 1.71 (1.02 to 2.87) | 33 more per 1000 (from 1 more to 86 more) | LOW | IMPORTANT
2 | randomised trial | no serious limitations | serious | no serious indirectness | serious | reporting bias | 506/7493 (6.8%) | 1.6% | RR 1.71 (1.02 to 2.87) | 11 more per 1,000 | LOW | IMPORTANT
2 | randomised trial | no serious limitations | serious | no serious indirectness | serious | reporting bias | 506/7493 (6.8%) | 6.5% | RR 1.71 (1.02 to 2.87) | 46 more per 1,000 | LOW | IMPORTANT

Abbreviations: CCB=calcium channel blocker; CI=confidence interval; CV=cardiovascular; IHD=ischemic heart disease; MI=myocardial infarction; RR=relative risk

Appendix Table 45 KQ5—Strength of evidence grading

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Evidence Grade | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Treatment | Control | Relative Risk (95% CI) | Absolute Risk | Evidence Grade | Importance
Study withdrawals (follow-up 56 months)
1 | randomized trial | no serious limitations | single trial | no serious indirectness | Serious | none | 2495/8502 (29.3%) | 2099/8576 (24.5%) | RR 1.20 (1.14 to 1.26) | 49 more per 1000 (from 34 more to 64 more) | MODERATE | IMPORTANT
Hypotension withdrawals (follow-up 56 months)
1 | randomized trial | no serious limitations | single trial | no serious indirectness | Serious | none | 406/8502 (4.8%) | 149/8576 (1.7%) | RR 2.75 (2.28 to 3.31) | 30 more per 1000 (from 22 more to 39 more) | MODERATE | IMPORTANT
Syncope withdrawals (follow-up 56 months)
1 | randomized trial | no serious limitations | single trial | no serious indirectness | Serious | none | 29/8502 (0.3%) | 15/8576 (0.2%) | RR 1.95 (1.06 to 3.60) | 2 more per 1000 (from 0 more to 5 more) | MODERATE | IMPORTANT
Cough withdrawals (follow-up 56 months)
1 | randomized trial | no serious limitations | single trial | no serious indirectness | Serious | none | 392/8502 (4.6%) | 360/8576 (4.2%) | RR 1.10 (0.96 to 1.26) | 4 more per 1000 (from 2 fewer to 11 more) | MODERATE | IMPORTANT
Angioedema withdrawals (follow-up 56 months)
1 | randomized trial | no serious limitations | single trial | no serious indirectness | very serious | none | 18/8502 (0.2%) | 25/8576 (0.3%) | RR 0.73 (0.40 to 1.32) | 1 fewer per 1000 (from 2 fewer to 1 more) | LOW | IMPORTANT
Renal impairment withdrawals (follow-up 56 months)
1 | randomized trial | no serious limitations | single trial | no serious indirectness | serious | none | 94/8502 (1.1%) | 60/8576 (0.7%) | RR 1.58 (1.15 to 2.18) | 4 more per 1000 (from 1 more to 8 more) | MODERATE | IMPORTANT

Abbreviations: CI=confidence interval; RR=relative risk

Appendix Table 46 KQ6—Strength of evidence grading

Quality assessment | | | | | | | Summary of findings | | | | | Importance
Quality assessment | | | | | | | No of patients | | Effect | | Evidence Grade | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Treatment | Control | Relative Risk (95% CI) | Absolute Risk | Evidence Grade | Importance
Study withdrawals (follow-up 0.5–3 years)
3 | randomized trial | no serious limitations | Serious | no serious indirectness | serious | none | 230/1406 (16.4%) | 105/1397 (7.5%) | RR 2.17 (1.75 to 2.7) | 88 more per 1000 (from 56 more to 128 more) | LOW | IMPORTANT
3 | randomized trial | no serious limitations | Serious | no serious indirectness | serious | none | 230/1406 (16.4%) | 0% | RR 2.17 (1.75 to 2.7) | 0 more per 1,000 | LOW | IMPORTANT
3 | randomized trial | no serious limitations | Serious | no serious indirectness | serious | none | 230/1406 (16.4%) | 8.1% | RR 2.17 (1.75 to 2.7) | 94 more per 1,000 | LOW | IMPORTANT
Hypotension (follow-up 3 years)
1 | randomized trial | no serious limitations | single study | no serious indirectness | serious | none | 154/120 (128.3%) | 70/1273 (5.5%) | RR 2.19 (1.67 to 2.87) | 65 more per 1000 (from 37 more to 103 more) | MODERATE | IMPORTANT
Cough (follow-up 2.3–3 years)
2 | randomized trial | no serious limitations | serious | no serious indirectness | very serious | none | 302/2158 (14%) | 143/2145 (6.7%) | RR 4.97 (0.58 to 42.95) | 266 more per 1000 (from 28 fewer to 1000 more) | LOW | IMPORTANT
2 | randomized trial | no serious limitations | serious | no serious indirectness | very serious | none | 302/2158 (14%) | 0.2% | RR 4.97 (0.58 to 42.95) | 7 more per 1,000 | LOW | IMPORTANT
2 | randomized trial | no serious limitations | serious | no serious indirectness | very serious | none | 302/2158 (14%) | 11.1% | RR 4.97 (0.58 to 42.95) | 440 more per 1,000 | LOW | IMPORTANT

* Risk in the control group is reported as observed pooled, low and high-risks derived from included trials

Abbreviations: CI=confidence interval; RR=relative risk

Appendix Table 47 KQ7—Strength of evidence grading

Quality assessment | | | | | | | Summary of findings | | Importance
No of studies | Design | Limitations | Inconsistency | Indirectness | Imprecision | Other considerations | Findings | Evidence Grade | Importance
Sex impact on benefits: ACE inhibitor vs. placebo
2 | randomized trial | serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses. Composite endpoint not exactly the same in the two trials. | ACE inhibitors provide similar efficacy in males and females. | MODERATE | CRITICAL
Sex impact on benefits: ARB vs. placebo
1 | randomized trial | serious limitations | single study | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses. Composite endpoint not exactly the one selected in the CER. | ARBs may not reduce the composite endpoint in females as much as males. | LOW | CRITICAL
Sex impact on benefits: ACE inhibitor vs. ARB
1 | randomized trial | serious limitations | single study | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses. Composite endpoint not exactly the one selected in the CER. | ACE inhibitors may be superior to ARBs in females but similar in males. | LOW | CRITICAL
Sex impact on benefits: ACE inhibitor vs. ACE inhibitor + ARB
1 | randomized trial | serious limitations | single study | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses. Composite endpoint not exactly the one selected in the CER. | Combination therapy may be superior to ACE inhibitors in females but similar in males. | LOW | CRITICAL
Sex impact on benefits: ACE inhibitor vs. CCB
1 | randomized trial | serious limitations | single study | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses. Composite endpoint not exactly the one selected in the CER. | ACE inhibitors appear to be similar to CCBs in efficacy in either males or females. | LOW | CRITICAL
Age impact on benefits: ACE inhibitor vs. placebo
2 | randomized trial | serious limitations | no serious imprecision | no serious indirectness | serious | Only the composite endpoint included in subgroup analyses. Composite endpoints not exactly the same in the two trials. Different age categories evaluated in different trials. | ACE inhibitors provide similar benefits in patients of different ages. | LOW | CRITICAL
Age impact on benefits: ARB vs. placebo
1 | randomized trial | serious limitations | single trial | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses. Composite endpoint not exactly the one selected in the CER. | ARBs provide similar benefits in patients of different ages. | LOW | CRITICAL
Age impact on benefits: ACE inhibitor vs. ARB
1 | randomized trial | serious limitations | single trial | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses. Composite endpoint not exactly the one selected in the CER. | ACE inhibitors provide similar benefits as ARBs in patients of different ages. | LOW | CRITICAL
Age impact on benefits: ACE inhibitor vs. ACE inhibitor + ARB
1 | randomized trial | serious limitations | single trial | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses. Composite endpoint not exactly the one selected in the CER. | ACE inhibitors provide similar benefits as combination therapy in patients of different ages. | LOW | CRITICAL
Age impact on benefits: ACE inhibitor vs. CCB
1 | randomized trial | serious limitations | single trial | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses. Composite endpoint not exactly the one selected in the CER. | ACE inhibitors provide similar benefits as calcium channel blockers in younger and older subjects. | LOW | CRITICAL
Diabetes mellitus impact on benefits: ACE inhibitor vs. Placebo
2 | randomized trial | serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses, which was not exactly the same in the two studies. Evaluated in subgroups (HOPE and EUROPA) and prespecified substudies (MICRO-HOPE, PERSUADE) from these trials. | ACE inhibitors provide similar benefits in those with and without diabetes mellitus. | MODERATE | CRITICAL
Diabetes mellitus impact on benefits: ARB vs. Placebo
1 | randomized trial | serious limitations | single study | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses. Composite endpoint not exactly the one selected in the CER. | ARBs provide similar benefits in those with and without diabetes mellitus. | LOW | CRITICAL
Diabetes mellitus impact on benefits: ACE inhibitor vs. ARB
1 | randomized trial | serious limitations | single study | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses. Composite endpoint not exactly the one selected in the CER. | ACE inhibitors provide similar benefits as ARBs in those with and without diabetes mellitus. | LOW | CRITICAL
Diabetes mellitus impact on benefits: ACE inhibitor vs. ACE inhibitor + ARB
1 | randomized trial | serious limitations | single study | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses. Composite endpoint not exactly the one selected in the CER. | Combination therapy may be better than ACE inhibitors alone amongst those with diabetes mellitus but similar in non- diabetics. | LOW | CRITICAL
Diabetes mellitus impact on benefits: ACE inhibitor vs. CCB
1 | randomized trial | serious limitations | single study | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses. Composite endpoint not exactly the one selected in the CER | ACE inhibitor therapy provides similar benefits as calcium channel blockers in subjects with diabetes. | LOW | CRITICAL
Renal dysfunction impact on benefits: ACE inhibitor vs. placebo
3 | randomized trial | serious limitations | serious inconsistency | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses in two trials. Composite endpoint not exactly the same in these two trials. The third trial evaluated total mortality instead of a composite endpoint. | ACE inhibitors may benefit those with renal dysfunction more than those without it. | LOW | CRITICAL
Hypertension impact on benefits: ACE inhibitor vs. placebo
2 | randomized trial | serious limitations | no serious inconsistency | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses in two trials. Composite endpoints not exactly the same in the two studies. | ACE inhibitors provide similar benefits to those with and without hypertension. | MODERATE | CRITICAL
Hypertension impact on benefits: ARB vs. placebo
1 | randomized trial | serious limitations | single study | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses in two trials. Composite endpoint not exactly the one selected in the CER. | ARBs provide similar benefits in those with and without hypertension. | LOW | CRITICAL
Hypertension impact on benefits: ACE inhibitor vs. ARB
1 | randomized trial | serious limitations | single study | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses in two trials. Composite endpoint not exactly the one selected in the CER. | ACE inhibitors may provide more benefits to those with systolic hypertension while ARBs may provide more benefits to those with normal systolic blood pressure. | LOW | CRITICAL
Hypertension impact on benefits: ACE inhibitor vs. ACE inhibitor + ARB
1 | randomized trial | serious limitations | single study | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses in two trials. Composite endpoint not exactly the one selected in the CER. | Combination therapy with an ACE inhibitor and ARB may provide more benefits in lower and higher systolic blood pressure ranges but patients with modestly elevated systolic blood pressure may benefit more from ACE inhibitor therapy alone. | LOW | CRITICAL
Baseline risk impact on benefits: ACE inhibitor vs. placebo
1 | Meta-analysis/IPD meta- analysis | no limitations | single study | no serious indirectness | no serious imprecision | None | ACE inhibitors provide benefits in low, medium and high risk subjects. As baseline risk increases, the benefits derived from ACE inhibitor therapy might be accentuated | LOW | CRITICAL
Baseline risk impact on benefits: ARB vs. placebo
1 | randomized trial | serious limitations | single study | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses in two trials. Composite endpoint not exactly the one selected in the CER. | ARBs may provide more benefits for those at lower baseline risk as compared to those at moderate to higher risk. | LOW | CRITICAL
Baseline risk impact on benefits: ACE inhibitors vs. ARBs
1 | randomized trial | serious limitations | single study | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses in two trials. Composite endpoint not exactly the one selected in the CER. | ACE inhibitor therapy might provide more benefits to those with moderate to high risk and ARBs may provide more benefits to those with lower baseline risk. | LOW | CRITICAL
Baseline risk impact on benefits: ACE inhibitor vs. ACE inhibitor + ARB
1 | randomized trial | serious limitations | single study | no serious indirectness | no serious imprecision | Only the composite endpoint included in subgroup analyses in two trials. Composite endpoint not exactly the one selected in the CER. | Combination therapy with an ACE inhibitor + ARB provides similar benefits as an ACE inhibitor alone regardless of baseline risk. | LOW | CRITICAL
Antiplatelet therapy impact on benefits: ACE inhibitor vs. placebo
1 | Meta-analysis/no IPD meta- analysis | no limitations | no serious inconsistency | no serious indirectness | no serious imprecision | None | ACE inhibitors may provide more benefits to those without concurrent antiplatelet therapy as compared to those with antiplatelet therapy. ACE inhibitors provide significant benefits versus placebo in both subgroups. | MODERATE | CRITICAL
History of revascularization impact on benefits: ACE inhibitors vs. placebo
1 | Meta-analysis/no IPD meta- analysis | no limitations | no serious inconsistency | no serious indirectness | no serious imprecision | None | ACE inhibitors may provide more benefits to those without a history of revascularization as compared to those with such a history. ACE inhibitors provide significant benefits versus placebo in both subgroups. | MODERATE | CRITICAL
Beta-blocker therapy impact on benefits: ACE inhibitor vs. placebo
1 | Meta-analysis/IPD meta- analysis | No limitations | no serious inconsistency | no serious indirectness | no serious imprecision | None | ACE inhibitors provide similar benefits to those with and without beta-blocker therapy. ACE inhibitors provided significant benefits in those with and without beta-blockers. | MODERATE | CRITICAL
Lipid lowering therapy impact on benefits: ACE inhibitor vs. placebo
1 | Meta-analysis/IPD meta- analysis | no limitations | no serious inconsistency | no serious indirectness | no serious imprecision | None | ACE inhibitors provide similar benefits to those with and lipid lowering therapy. inhibitors provided significant benefits in those with and without beta-blockers. | MODERATE | CRITICAL
Vitamin E therapy impact on benefits: ACE inhibitor vs. placebo
1 | Randomized trial | no limitations | single study | no serious indirectness | serious imprecision | 95% confidence intervals and p-values not provided for this analysis. | ACE inhibitors provide similar benefits to those with and without vitamin E therapy. | LOW | CRITICAL