# List of Excluded Studies

## Efficacy/Harms Search

1 Ahmad J, Siddiqui MA, Ahmad H. Effective postponement of diabetic nephropathy with enalapril in normotensive type 2 diabetic patients with microalbuminuria. Diabetes Care. 1997;20(10):1576-58. [pmid: 9314638].
2 Aksnes TA, Kjeldsen SE, Rostup M, et al. Impact of new-onset diabetes mellitus on cardiac outcomes in the Valsartan Antihypertensive Long-term Use Evaluation (VALUE) trial population. Hypertension. 2007;50(3):467-73. [pmid: 17679652].
3 Alderman EL, Botas J. Selection of revascularization for patients with stable angina pectoris. Coron Artery Dis. 1993;4(12):1061-7. [pmid: 8162236].
4 Al-Khadra AS, Salem DN, Rand WM, et al. Antiplatelet agents and survival: a cohort analysis from the Studies of Left Ventricular Dysfunction (SOLVD) trial. J Am Coll Cardiol. 1998;31(2):419-25. [pmid: 9462588].
5 Al-Khadra AS, Salem DN, Rand WM, et al. Antiplatelet agents and survival: a cohort analysis from the Studies of Left Ventricular Dysfunction (SOLVD) trial. J Am Coll Cardiol. 1998;31(2):419-25. [pmid: 9462588].
6 ALLHAT Officers and Coordinators for the ALLHAT Collaborative Research Group. Major outcomes in high-risk hypertensive patients randomized to angiotensin-converting enzyme inhibitor or calcium channel blocker vs diuretic: The Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). JAMA. 2002;288(23):2981-97. [pmid: 12479763].
7 Ambrosioni E, Borghi C, Magnani B. Early treatment of acute myocardial infarction with angiotensin-converting enzyme inhibition: safety considerations. SMILE pilot study working party. Am J Cardiol. 1991;68(14):101D-110D.
8 Anavekar NS, McMurray JJ, Velazquez EJ, et al. Relation between renal dysfunction and cardiovascular outcomes after myocardial infarction. N Engl J Med. 2004;351(13):1285-95. [pmid: 15385655].
9 Anavekar NS, Solomon SD, McMurray JD, et al. Comparison of renal function and cardiovascular risk following acute myocardial infarction in patients with and without diabetes mellitus. Am J Cardiol. 2008;101(7):925-9. [pmid: 18359309].
10 Anderson C. Rationale and design of the cardiac magnetic resonance imaging substudy of The ONTARGET Trial Programme. J Int Med Res. 2005;33(Suppl 1):50A-57A.
11 Anderson TJ, Elstein E, Haber H, et al. Comparative study of ACE-inhibition, angiotensin II antagonism, and calcium channel blockade on flow-mediated vasodilation in patients with coronary disease (BANFF study). J Am Coll Cardiol. 2000;35(1):60-6. [pmid: 10636260].
12 Arima H, Hart RG, Colman S, et al. Perindopril-based blood pressure-lowering reduces major vascular events in patients with atrial fibrillation and prior stroke or transient ischemic attack. Stroke. 2005;36(10):2164-9. [pmid: 16141420].
13 Arima H, Tzourio C, Butcher K, et al. Prior events predict cerebrovascular and coronary outcomes in the PROGRESS trial. Stroke. 2006;37(6):1497-1502. [pmid: 16627794].
14 Arnett DK, Davis BR, Ford CE, et al. Pharmacogenetic associationof the angiotensin -converting enzyme insertion/deletion polymorphism on blood pressure and cardiovascular risk in relation to antihypertensive treatment: the Genetics of Hypertension-Associated Treatment (GenHAT) study. Circulation. 2005;111(25):3374-83. [pmid: 15967849].
15 Asselbergs FW, Diercks GF, Hillege HL, et al. Effects of fosinopril and pravastatin on cardiovascular events in subjects with microalbuminuria. Circulation. 2004;110(18):2809-16. [pmid: 15492322].
16 Asselbergs FW, Hillege HL, van Gilst WH. Framingham score and microalbuminuria: combined future targets for primary prevention?. Kidney Int. 2004;6(Suppl 92):S111-4.
17 Athyros VG, Mikhailidis DP, Papageorgiou AA, et al. Effect of statins and ACE inhibitors alone and in combination on clinical outcome in patients with coronary heartdisease. J Hum Hypertens. 2004;18(11):781-8. [pmid: 15229622].
18 Atthobari J, Asselbergs FW, Boersma C, et al. Cost-effectiveness of screening for albuminuria with subsequent fosinopril treatment to prevent cardiovascular events: A pharmacoeconomic analysis linked to the prevention of renal and vascular endstage disease (PREVEND) study and the prevention of renal and vascular endstage disease intervention trial (PREVEND IT). Clin Ther. 2006;28(3):432-44. [pmid: 16750458].
19 Atthobari J, Brantsma AH, Gansevoort RT, et al. The effect of statins on urinary albumin excretion and glomerular filtration rate: results from both a randomized clinical trial and an observational cohort study. Nephrol Dial Transplant. 2006;21:3106-14. [pmid: 16720593].
20 Baba S. the J-MIND Study Group. Nifedipine and enalapril equally reduce the progression of nephropathy in hypertensive type 2 diabetics. Diabetes Res Clin Pract. 2001;54(3):191-201. [pmid: 11689274].
21 Bakins GL. Benefits of combination therapy for achieving goal blood pressure in high CV risk patients. Cardiovasc J S Afr. 2001;12:54-5. [pmid: 11474688].
22 Bakris GL, Ruilope L, Locatelli F, et al. Treatment of microalbuminuria in hypertensive subjects with elevated cardiovascular risk: results of the IMPROVE trial. Kidney Int. 2007;72:879-85. [pmid: 17667984].
23 Barzilay JI, Jones CL, Davis BR. Baseline characteristics of the diabetic participants in the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). Diabetes Care. 2001;24(4):654-8. [pmid: 11315826].
24 Baumgart P. Antihypertensive therapy: risk stratification in diabetes and cardiac diseases. MMW Fortschr Med. 2006;148(11):57-60. (German). [pmid: 16612965].
25 Bayliss J, Canepa-Anson R, Norell M, et al. The renal response to neuroendocrine inhibition in chronic heart failure: double-blind comparison of captopril and prazosin. Eur Heart J. 1986;7(10):877-84. [pmid: 3539615].
26 Berger PB, Holmes DR, Ohman EM, et al. Restenosis, reocclusion and adverse cardiovascular events after successful balloon angioplasty of occluded versus nonoccluded coronary arteries. Results from the Multicenter American Research Trial With Cilazapril After Angioplasty to Prevent Transluminal Coronary Obstruction and Restenosis (MARCATOR). J Am Coll Cardiol. 1996;27(1):1-7. [pmid: 8522681].
27 Berl T, Hunsicker LG, Lewis JB, et al. Cardiovascular outcomes in the irbesartan diabetic nephropathy trial of patients with type 2 diabetes and overt nephropathy. Ann Intern Med. 2003;138(7):542-9. [pmid: 12667024].
28 Berl T, Hunsicker LG, Lewis JB, et al. Impact of achieved blood pressure on cardiovascular outcomes in the Irbesartan Diabetic Nephropathy Trial. J Am Soc Nephrol. 2005;16(7):2170-9. [pmid: 15930097].
29 Biasucci LM, Lombardi M, Piro M, et al. Irbesartan significantly reduces C reactive protein concentrations after 1 month of treatment in unstable angina. Heart. 2005;91(5):670-1. [pmid: 15831660].
30 Bibbins-Domingo K, Lin F, Vittinghoff E, et al. Renal insufficiency as an independent predictor of mortality among women with heart failure. J Am Coll Cardiol. 2004;44(8):1593-1600. [pmid: 15489091].
31 Bjorholt I, Andersson FL, Kahan T, et al. The cost-effectiveness of ramipril in the treatment of patients at high risk of cardiovascular events: a Swedish sub-study to the HOPE study. J Intern Med. 2002;251(6):508-17. [pmid: 12028506].
32 Black HR, Davis B, Barzilay J, et al. Metabolic and clinical outcomes in nondiabetic individuals with the metabolic syndrome assigned to chlorthalidone, amlodipine, or lisinopril as initial treatment for hypertension: a report from the Antihypertensive and Lipid-Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). Diabetes Care. 2008;31(2):353-60. [pmid: 18000186].
33 Blankenberg S, McQueen MJ, Smieja M, et al. Comparative impact of multiple biomarkers and N-Terminal pro-brain natriuretic peptide in the context of conventional risk factors for the prediction of recurrent cardiovascular events in the Heart Outcomes Prevention Evaluation (HOPE) Study. Circulation. 2005;114(3):201-8. [pmid: 16831981].
34 Boersma C, Carides GW, Atthobari J, et al. An economic assessment of losartan-based versus atenolol-based therapy in patients with hypertension and left-ventricular hypertrophy: results from the Losartan Intervention For Endpoint reduction (LIFE) study adapted to The Netherlands. Clin Ther. 2007;29(5):963-71. [pmid: 17697915].
35 Bohm M, Baumhakel M, Probstfield JL, et al. Sexual function, satisfaction, and association of erectile dysfunction with cardiovascular disease and risk factors in cardiovascular high-risk patients: substudy of the ONgoing Telmisartan Alone and in Combination with Ramipril Global Endpoint Trial/Telmisartan Randomized AssessmeNT Study in ACE-INtolerant Subjects with Cardiovascular Disease (ONTARGET/TRANSCEND). Am Heart J. 2007;154(1):94-101. [pmid: 17584560].
36 Boldt J, Rothe G, Schindler E, et al. Can clonidine, enoximone, and enalaprilat help to protect the myocardium against ischaemia in cardiac surgery?. Heart. 1996;76(3):207-13. [pmid: 8868976].
37 Boner G, Cooper ME, McCarroll K, et al. Adverse effects of left ventricular hypertrophy in the reduction of endpoints in NIDDM with the angiotensin II antagonist losartan (RENAAL) study. Diabetologia. 2005;48(10):1980-7. [pmid: 16082528].
38 Bots ML, Remme WJ, Luscher TF, et al. ACE inhibition and endothelial function: main findings of PERFECT, a sub-study of the EUROPA trial. Cardiovasc Drugs Ther. 2007;21(4):269-79. [pmid: 17657599].
39 Bots ML, Remme WJ, Luscher TF, et al. PERindopril-Function of the Endothelium in Coronary Artery Disease Trial: The PERFECT Study-Sub Study of EUROPA: Rationale and Design. Cardiovasc Drugs Ther. 2002;16(3):227-36. [pmid: 12374901].
40 Boulanger JM, Hill MD. Morbidity and mortality after stroke--eprosartan compared with nitrendipine for secondary prevention: principal results of a prospective randomized controlled study (MOSES). Stroke. 2006;37(2):335-6. [pmid: 16397169].
41 Brener SJ, Ivanc TB, Poliszczuk R, et al. Antihypertensive therapyand regression of coronary artery disease: insights from the Comparison of Amlodipine versus Enalapril to Limit Occurrences of Thrombosis (CAMELOT) and Norvasc for Regression of Manifest Atherosclerotic Lesions by Intravascular Sonographic Evaluation (NORMALISE) trials. Am Heart J. 2006;152(6):1059-63. [pmid: 17161053].
42 Brenner BM, Cooper ME, Zeeuw DD, et al. Effects of losartan on renal and cardiovascular outcomes in patients with type 2 diabetes and nephropathy. N Engl J Med. 2001;345(12):861-9. [pmid: 11565518].
43 Briggs A, Mihaylova B, Sculpher M, et al. Cost effectiveness of perindopril in reducing cardiovascular events in patients with stable coronary artery disease using data from the EUROPA study. Heart. 2007;93(9):1081-6. [pmid: 17135223].
44 Burduli FY, Khadzhidis PK, Vatsadze TG, et al. Use of prazosin and capoten in the treatment of heart failure in patients with ischemic heart disease. Kardiologia. 1989;29:49-52. (Russian).
45 Campbell DJ, Woodward M, Chalmers JP, et al. Perindopril-based blood pressure-lowering therapy reduces amino-terminal-pro-B-type natriuretic peptide in individuals with cerebrovascular disease. J Hypertens. 2007;25(3):699-705. [pmid: 17278987].
46 Capri S, Perlini S. Cost-effectiveness in Italy of preventive treatment with ramipril in patients at high risk of cardiovascular events. Curr Med Res Opin. 2005;21(6):913-21. [pmid: 16003858].
47 Carson P, Massie BM, Mckelvie R, et al. The Irbesartan in Heart Failure with Preserved Systolic Function. J Card Fail. 2005;11(8):576-85. [pmid: 16230259].
48 Cashin-Hemphill L, Holmvang G, Chan RC, et al. Angiotensin-converting enzyme inhibition as antiatherosclerotic therapy: no answer yet. QUIET Investigators. QUinapril Ischemic Event Trial. Am J Cardiol. 1999;83(1):43-7. [pmid: 10073783].
49 Cashin-Hemphill L, Holmvang G, Chan RC, et al. Angiotensin-converting enzyme inhibition as antiatherosclerotic therapy: no answer yet. QUIET Investigators. QUinapril Ischemic Event Trial. Am J Cardiol. 1999;83(1):43-7. [pmid: 10073783].
50 Catalano M, Libretti A. Captopril for the treatment of patients with hypertension and peripheral vascular disease. Angiology. 1985;36(5):293-6. [pmid: 3896045].
51 Ceconi C, Fox KM, Remme W, et al. ACE inhibition with perindopril and endothelial function. Results of a substudy of the EUROPA study: PERTINENT. Cardiovasc Res. 2007;73(1):237-46. [pmid: 17140552].
52 Cesari M, Kritchevsky SB, Atkinson HH, et al. Angiotensin-converting enzyme inhibition and novel cardiovascular risk biomarkers: results from the Trial of Angiotensin Converting Enzyme Inhibition and Novel cardiovascular risk factors (TRAIN) study. Am Heart J. 2009;157(2):e1-e8. [pmid: 19185642].
53 Chaitman BR, Ivleva AY, Ujda M, et al. Antianginal efficacy of omapatrilat in patients with chronic angina pectoris. Am J Cardiol. 2005;95(11):1283-9. [pmid: 15904630].
54 Charbonneau F. Background rationale for a study to assess normalization of brachial artery forearm flow function. Can J Cardiol. 1998;14(Suppl D):16D-17D.
55 Coca A, Messerli FH, Benetos A, et al. Predicting stroke risk in hypertensive patients with coronary artery disease: a report from the INVEST trial. Stroke. 2008;39(2):343-8. [pmid: 18162623].
56 Cohen-Solal A, McMurray JJ, Swedberg K, et al. for the CHARM Investigators. Benefits and safety of candesartan treatment in heart failure are independent of age: insights from the Candesartan in Heart Failure – Assessment of Reduction in Mortality and morbidity programme. Eur Heart J. 2008;29(24):3022-8. [pmid: 18987098].
57 Colombo GL, Caruggi M, Ottolini C, et al. Candesartan in Heart failure: Assessment of Reduction in Mortality and morbidity (CHARM) and resource utilization and costs in Italy. Vasc Health Risk Manag. 2008;4(1):223-34. [pmid: 18629370].
58 Cooper DeHoff RM, Handberg EM, Cohen J, et al. Characteristics of contemporary patients with hypertension and coronary artery disease. Clin Cardiol. 2004;27(10):571-6. [pmid: 15553310].
59 Dagenais GR, Yi Q, Lonn E, et al. Impact of cigarette smoking in high-risk patients participating in a clinical trial. A substudy from the Heart Outcomes Prevention Evaluation (HOPE) trial. Eur J Cardiovasc Prev Rehabil. 2005;12(1):75-81. [pmid: 15703510].
60 Dahlof B, Devereux RB, Kjeldsen SE, et al. Cardiovascular morbidity and mortality in the Losartan Intervention For Endpoint reduction in hypertension study (LIFE): a randomised trial against atenolol. Lancet. 2002;359:995-1003. [pmid: 11937178].
61 Daly CA, Hildebrandt P, Bertrand M, et al. Adverse prognosis associated with the metabolic syndrome in established coronary artery disease: data from the EUROPA trial. Heart. 2007;93(11):1406-11. [pmid: 17540689].
62 Dauterman KW, Go AS, Rowell R, et al. Congestive heart failure with preserved systolic function in a statewide sample of community hospitals. J Card Fail. 2001;7(3):221-8. [pmid: 11561221].
63 Dauterman KW, Go AS, Rowell R, et al. Congestive heart failure with preserved systolic function in a statewide sample of community hospitals. J Card Fail. 2001;7(3):221-8. [pmid: 11561221].
64 Davis BR, Arnett DK, Boerwinkle E, et al. Antihypertensive therapy, the alpha-adducin polymorphism, and cardiovascular disease in high-risk hypertensive persons: the Genetics of Hypertension-Associated Treatment Study. The Pharmacogenomics Journal. 2007;7(2):112-22. [pmid: 16702981].
65 Davis BR, Cutler JA, Gordon D, et al. Rationale and design for the Antihypertensive and Lipid Lowering Treatment to Prevent Heart Attack Trial (ALLHAT). ALLHAT Research Group. Am J Hypertens. 1996;9(4 pt 1):342-60. [pmid: 8722437].
66 Davis BR, Kostis JB, Simpson LM, et al. for the ALLHAT Collaborative Research Group. Heart failure with preserved and reduced left ventricular ejection fraction in the antihypertensive and lipid-lowering treatment to prevent heart attack trial. Circulation. 2008;118(22):2259-67. [pmid: 19001024].
67 de Simone G, Wachtell K, Palmieri V, et al. Body build and risk of cardiovascular events in hypertension and left ventricular hypertrophy: the LIFE (Losartan Intervention For Endpoint reduction in hypertension) study. Circulation. 2005;111(15):1924-31. [pmid: 15837945].
68 de Zeeuw D, Remuzzi G, Parving HH, et al. Albuminuria, a therapeutic target for cardiovascular protection in type 2 diabetic patients with nephropathy. Circulation. 2004;110(8):921-7. [pmid: 15302780].
69 Desmet W, Vrolix M, Scheerder ID, et al. Angiotensin-converting enzyme inhibition with fosinopril sodium in the prevention of restenosis after coronary angioplasty. Circulation. 1994;89:385-92. [pmid: 8281674].
70 Devereux RB, Dahlof B, Kjeldsen SE, et al. Effects of losartan or atenolol in hypertensive patients without clinically evident vascular disease: a substudy of the LIFE randomized trial. Ann Intern Med. 2003;139(3):169-77. [pmid: 12899584].
71 Devereux RB, Wachtell K, Gerdts E, et al. Prognostic significance of left ventricular mass change during treatment of hypertension. JAMA. 2004;292(19):2350-6. [pmid: 15547162].
72 Diercks GF, Janssen WM, van Boven AJ, et al. Rationale, design, and baseline characteristics of a trial of prevention of cardiovascular and renal disease with fosinopril and pravastatin in nonhypertensive, nonhypercholesterolemic subjects with microalbuminuria (the Prevention of REnal and Vascular ENdstage Disease Intervention Trial [PREVEND IT]). Am J Cardiol. 2000;86(6):635-8. [pmid: 10980214].
73 Domanski MJ, Jablonski KA, Rice MM, et al. Obesity and cardiovascular events in patients with established coronary disease. Eur Heart J. 2006;27(12):1416-22. [pmid: 16707546].
74 Duprez DA, Florea ND, Jones K, et al. Beneficial effects of valsartan in asymptomatic individuals with vascular or cardiac abnormalities: the DETECTIV Pilot Study. J Am Coll Cardiol. 2007;50(9):835-9. [pmid: 17719468].
75 Ekbom T, Linjer E, Hedner T, et al. Cardiovascular events in elderly patients with isolated systolic hypertension. A subgroup analysis of treatment strategies in STOP-Hypertension-2. Blood Press. 2004;13(3):137-41. [pmid: 15223721].
76 Ekeberg O, Klemsdal TO, Kjeldsen SE. Quality of life on enalapril after acute myocardial infarction. Eur Heart J. 1994;15(8):1135-9. [pmid: 7988608].
77 Erinc K, Yamani MH, Starling RC, et al. The effect of combined Angiotensin-converting enzyme inhibition and calcium antagonism on allograft coronary vasculopathy validated by intravascular ultrasound. J Heart Lung Transplant. 2005;24(8):1033-8. [pmid: 16102438].
78 Estacio RO, Coll JR, Tran ZV, et al. Effect of intensive blood pressure control with valsartan on urinary albumin excretion in normotensive patients with type 2 diabetes. Am J Hypertens. 2006;19(12):1241-8. [pmid: 17161769].
79 Estacio RO, Jeffers BW, Gifford N, et al. Effect of blood pressure control on diabetic microvascular complications in patients with hypertension and type 2 diabetes. Diabetes Care. 2000;23(Suppl 2):B54-64. [pmid: 10860192].
80 Estacio RO, Jeffers BW, Hiatt WR, et al. The effect of nisoldipine as compared with enalapril on cardiovascular outcomes in patients with non-insulin-dependent diabetes and hypertension. N Engl J Med. 1998;338:645-52. [pmid: 9486993].
81 Evidence-based Clinical Practice. Addition of an ACE inhibitor to conventional treatment is not beneficial in people with stable coronary artery disease and preserved left ventricular function. Evid Based Healthc Public Health. 2005;9(3):259-60.
82 Ezekowitz JA, Lee DS, Tu JV, et al. Comparison of one-year outcome (death and rehospitalization) in hospitalized heart failure patients with left ventricular ejection fraction >50% versus those with ejection fraction <50%. Am J Cardiol. 2008;102(1):79-83. [pmid: 18572040].
83 Fagard RH, Staessen JA, Thijs L, et al. Prognostic significance of electrocardiographic voltages and their serial changes in elderly with systolic hypertension. Hypertension. 2004;44(4):459-64. [pmid: 15326091].
84 Fallowfield JM, Blenkinsopp J, Raza A, et al. Post-marketing surveillance of lisinopril in general practice in the UK. Br J Clin Pract. 1993;47(6):296-304. [pmid: 8117550].
85 Ferrari R. The PREAMI Investigators. Effects of angiotensin-converting enzyme inhibition with perindopril on left ventricular remodeling and clinical outcome: results of the randomized Perindopril and Remodeling in Elderly with Acute Myocardial Infarction (PREAMI) Study. Arch Intern Med. 2006;166(6):659-66. [pmid: 16567606].
86 Fossum E, Gleim GW, Kjeldsen SE, et al. The effect of baseline physical activity on cardiovascular outcomes and new-onset diabetes in patients treated for hypertension and left ventricular hypertrophy: the LIFE study. J Intern Med. 2007;262(4):439-48. [pmid: 17875180].
87 Fukami K, Hiromori K, Kishida H, et al. Assessment and controversy of long-term medical treatment in ischemic heart disease. Japanese Angina and Myocardial infarction Prospective (JAMP) study. Jpn Circ J. 1994;58(Suppl 4):1293-6. (Japanese). [pmid: 7699778].
88 Gaede PH, Jepsen PV, Larsen JN, et al. The Steno-2 study. Intensive multifactorial intervention reduces the occurrence of cardiovascular disease in patients with type 2 diabetes. Ugeskr Laeger. 2003;165(26):2658-61. (Danish). [pmid: 12886549].
89 Geluk CA, Asselbergs FW, Hillege HL, et al. Impact of statins in microalbuminuric subjects with the metabolic syndrome: a substudy of the PREVEND Intervention. Trial Eur Heart J. 2005;26(13):1314-20. [pmid: 15820998].
90 Gerdts E, Wachtell K, Omvik P, et al. Left atrial size and risk of major cardiovascular events during antihypertensive treatment: losartan intervention for endpoint reduction in hypertension trial. Hypertension. 2007;49(2):311-6. [pmid: 17178978].
91 Gerstein HC, Pogue J, Mann JF, et al. The relationship between dysglycaemia and cardiovascular and renal risk in diabetic and non-diabetic participants in the HOPE study: a prospective epidemiological analysis. Diabetologia. 2005;48(9):1749-55. [pmid: 16059716].
92 Gerstein HC, Swedberg K, Carlsson J, et al. for the CHARM Program Investigators. The hemoglobin A1c level as a progressive risk factor for cardiovascular death, hospitalization for heart failure, or death in patients with chronic heart failure: an analysis of the Candesartan in Heart failure: Assessment of Reduction in Mortality and Morbidity (CHARM) program. Arch Intern Med. 2008;168(15):1699-704. [pmid: 18695086].
93 Gibas M, Miszczak-Smialek J, Madry E. Influence of preventive therapy with quinapril on IL-6 level in patients with chronic stable angina. Pharmacol Rep. 2007;59(3):330-8. [pmid: 17652834].
94 Gnecchi M, Ardissino D. Effects of ACE inhibitors on angiographic restenosis after coronary stenting (PARIS): double-blind randomized trial. Ital Heart J. 2001;2(9):1027-8. (Italian).
95 Go AS, Iribarren C, Chandra M, et al. Statin and beta-blocker therapy and the initial presentation of coronary heart disease. Ann Intern Med. 2006;144(4):229-38. [pmid: 16490908].
96 Hager WD, Davis BR, Riba A, et al. Absence of a deleterious effect of calcium channel blockers in patients with left ventricular dysfunction after myocardial infarction: The SAVE Study Experience. SAVE Investigators. Survival and Ventricular Enlargement. Am Heart J. 1998;135(3):406-13. [pmid: 9506325].
97 Hansson L. The Captopril Prevention Project (CAPPP): description and status. Am J Hypertens. 1994;7(9 Pt 2):82S-83S. [pmid: 7818840].
98 Hansson L, Lithell H, Skoog I, et al. Study on COgnition and Prognosis in the Elderly (SCOPE). Blood Press. 1999;8(3):177-83. [pmid: 10595696].
99 Hansson L, Lithell H, Skoog I, et al. Study on COgnition and Prognosis in the Elderly (SCOPE):baseline characteristics. Blood Press. 2000;9:146-51. [pmid: 10855739].
100 Harrap SB, Tzourio C, Cambien F, et al. The ACE gene I/D polymorphism is not associated with the blood pressure and cardiovascular benefits of ACE inhibition. Hypertension. 2003;42(3):297-303. [pmid: 12925557].
101 Hart WM, Rubio-Terres C, Margalet Fernandez I, et al. Cost-effectiveness analysis of Ramipril treatment of patients at high-risk of cardiovascular events in Spain. An Med Interna. 2002;19(10):515-20. (Spanish). [pmid: 12481494].
102 Hawkins NM, Wang D, McMurray JJ, et al. Prevalence and prognostic impact of bundle branch block in patients with heart failure: evidence from the CHARM programme. Eur J Heart Fail. 2007;9(5):510-7. [pmid: 17317308].
103 Hermans WR, Foley DP, Rensing BJ, et al. Morphologic changes during follow-up after successful percutaneous transluminal coronary balloon angioplasty: quantitative angiographic analysis in 778 lesions--further evidence for the restenosis paradox. MERCATOR Study Group (Multicenter European Research trial with Cilazapril after Angioplasty to prevent TransluminalCoronary Obstruction and Restenosis). Am Heart J. 1994;127(3):483-94. [pmid: 8122593].
104 Hermans WR, Rensing BJ, Foley DP, et al. Therapeutic dissection after successful coronary balloon angioplasty: no influence on restenosis or on clinical outcome in 693 patients. The MERCATOR Study Group (Multicenter European Research Trial with Cilazapril after Angioplasty to prevent Transluminal Coronary Obstruction and Restenosis). J Am Coll Cardiol. 1992;20(4):767-80. [pmid: 1388181].
105 Hermans WR, Rensing BJ, Foley DP, et al. Patient, lesion, and procedural variables as risk factors for luminal re-narrowing after successful coronary angioplasty: a quantitative analysis in 653 patients with 778 lesions. Multicenter European Research Trial with Cilazapril after Angioplasty to prevent Transluminal Coronary Obstruction and Restenosis (MERCATOR) Study Group. J Cardiovasc Pharmacol. 1993;22(Suppl 4):S45-57. [pmid: 7523772].
106 Heyndrickx GR. the MERCATOR Study Group. Angiotensin-converting enzyme inhibitor in a human model of restenosis. MERCATOR (“Multicenter European Research Trial with Cilazapril after Angioplasty to Prevent Transluminal Coronary Obstruction and Restenosis”) Study Group. Basic Res Cardiol. 1993;88(Suppl 1):169-82. [pmid: 8357332].
107 Hofmann M, Bauer R, Handrock R, et al. Prognostic value of the QRS duration in patients with heart failure: a subgroup analysis from 24 centers of Val-HeFT. J Card Fail. 2005;11(7):523-8. [pmid: 16198248].
108 Hoieggen A, Alderman MH, Kjeldsen SE, et al. The impact of serum uric acid on cardiovascular outcomes in the LIFE study. Kidney Int. 2004;65(3):1041-9. [pmid: 14871425].
109 Hoogwerf BJ, Young JB. The HOPE study. Ramipril lowered cardiovascular risk, but vitamin E did not. Cleve Clin J Med. 2000;67(4):287-93. [pmid: 10780101].
110 Hosomi N, Mizushige K, Ohyama H, et al. Angiotensin-converting enzyme inhibition with enalapril slows progressive intima-media thickening of the common carotid artery in patients with non-insulin-dependent diabetes mellitus. Stroke. 2001;32(7):1539-45. [pmid: 11441198].
111 Hsia J, Jablonski KA, Rice MM, et al. Sudden Cardiac Death in Patients With Stable Coronary Artery Disease and Preserved Left Ventricular Systolic Function. Am J Cardiol. 2008;101(4):457-61. [pmid: 18312757].
112 Hughes S. EUROPA study results: Perindopril benefits broad range of patients with stable coronary disease. Br J Cardiol. 2003;10(5):339-40.
113 Ibsen H, Olsen MH, Wachtell K. Reduction in albuminuria translates to reduction in cardiovascular events in hypertensive patients: losartan intervention for endpoint reduction in hypertension study. Hypertension. 2005;45(2):198-202. [pmid: 15655123].
114 Ibsen H, Olsen MH, Wachtell K, et al. Does albuminuria predict cardiovascular outcomes on treatment with losartan versus atenolol in patients with diabetes, hypertension, and left ventricular hypertrophy? The LIFE study. Diabetes Care. 2006;29(3):595-600. [pmid: 16505512].
115 Ibsen H, Pedersen OL, Dahlof B, et al. The effect of losartan versus atenolol on cardiovascular morbidity and mortality in patients with hypertension and ECG-verified left ventricular hypertrophy in the LIFE-study. Ugeskr Laeger. 2003;165(5):456-9. (Danish). [pmid: 12599843].
116 Ikeda N, Nishimura S, Kyo S, et al. Valsartan cardio-renal protection in patients undergoing coronary angiography complicated with chronic renal insufficiency (VAL-CARP) trial: rationale and design. Circ J. 2006;70(5):548-52. [pmid: 16636488].
117 Ishani A, Herzog CA, Collins AJ, et al. Cardiac medications and their association with cardiovascular events in incident dialysis patients: cause or effect?. Kidney Int. 2004;65(3):1017-25. [pmid: 14871422].
118 Janardhanan R, Kenchaiah S, Velazquez EJ, et al. Extent of coronary artery disease as a predictor of outcomes in acute myocardial infarction complicated by heart failure, left ventricular dysfunction, or both. Am Heart J. 2006;152(1):183-9. [pmid: 16824854].
119 Jezek T, Balazovjech I. The Valsartan Antihypertensive Long-term Use Evaluation (VALUE) trial in Slovakia. Bratisl Lek Listy. 2003;104(1):19-25. [pmid: 12830992].
120 Johnstone D, Limacher M, Rousseau M, et al. Clinical characteristics of patients in studies of left ventricular dysfunction (SOLVD). Am J cardiol. 1992;70(9):894-900. [pmid: 1529944].
121 Jonsson B, Buxton M, Hertzman P, et al. Health economics of prevention of coronary heart disease and vascular events: a cost-effectiveness analysis based on the Anglo-Scandinavian Cardiac Outcomes Trial (ASCOT). J Hum Hypertens. 2001;15(Suppl 1):S53-6. [pmid: 11685911].
122 Jose P, Skali H, Anavekar N, et al. Increase in creatinine and cardiovascular risk in patients with systolic dysfunction after myocardial infarction. J Am Soc Nephrol. 2006;17(10):2886-91. [pmid: 16928807].
123 Julius S, Kjeldsen SE, Brunner H, et al. VALUE trial: Long-term blood pressure trends in 13,449 patients with hypertension and high cardiovascular risk. Am J Hypertens. 2003;16(7):544-8. [pmid: 12850387].
124 Julius S, Kjeldsen SE, Weber M, et al. Outcomes in hypertensive patients at high cardiovascular risk treated with regimens based on valsartan or amlodipine: the VALUE randomised trial. Lancet. 2004;363(9426):2022-31. [pmid: 15207952].
125 Just H, Drexler H, Taylor SH, et al. Captopril versus digoxin in patients with coronary artery disease and mild heart failure. A prospective, double-blind, placebo-controlled multicenter study. The CADS Study Group. Herz. 1993;18(Suppl 1):S436-43.
126 Kaul U, Chandra S, Bahl VK, et al. Enalapril for prevention of restenosis after coronary angioplasty. Indian Heart J. 1993;45(6):469-73. [pmid: 8070823].
127 Kenchaiah S, Davis BR, Braunwald E, et al. Antecedent hypertension and the effect of captopril on the risk of adverse cardiovascular outcomes after acute myocardial infarction with left ventricular systolic dysfunction: Insights from the Survival and Ventricular Enlargement Trial. Am Heart J. 2004;148(2):356-64. [pmid: 15309009].
128 Kenchaiah S, Pocock SJ, Wang D, et al. Body mass index and prognosis in patients with chronic heart failure: insights from the Candesartan in Heart failure: Assessment of Reduction in Mortality and morbidity (CHARM) program. Circulation. 2007;116(6):627-36. [pmid: 17638930].
129 Kessler M, Zannad F, Lehert P, et al. Predictors of cardiovascular events in patients with end-stage renal disease: an analysis from the Fosinopril in dialysis study. Nephrol Dial Transplant. 2007;22(12):3573-9. [pmid: 17611249].
130 Kjeldsen SE, Dahlof B, Devereux RB, et al. Effects of losartan on cardiovascular morbidity and mortality in patients with isolated systolic hypertension and left ventricular hypertrophy: a Losartan Intervention for Endpoint Reduction (LIFE) substudy. JAMA. 2002;288(12):1491-8. [pmid: 12243636].
131 Kjeldsen SE, Julius S, Brunner H, et al. Characteristics of 15,314 hypertensive patients at high coronary risk. The VALUE trial. The Valsartan Antihypertensive Long-term Use Evaluation. Blood Press. 2001;10(2):83-91. [pmid: 11467764].
132 Kleber FX, Niemoller L, Fischer M, et al. Influence of severity of heart failure on the efficacy of angiotensin-converting enzyme inhibition. Am J Cardiol. 1991;68(14):121D-126D.
133 Kober L, Torp-Pedersen C, Carlsen JE, et al. A clinical trial of the angiotensin-converting-enzyme inhibitor trandolapril in patients with left ventricular dysfunction after myocardial infarction. Trandolapril Cardiac Evaluation (TRACE) Study Group. N Engl J Med. 1995;333(25):1670-6. [pmid: 7477219].
134 Kontopoulos AG, Athyros VG, Papageorgiou AA, et al. Effect of angiotensin-converting enzyme inhibitors on the power spectrum of heart rate variability in post-myocardial infarction patients. Coron Artery Dis. 1997;8:517-24. [pmid: 9431480].
135 Kowey PR, Dickson TZ, Zhang Z, et al. Losartan and end-organ protection--lessons from the RENAAL study. Clin Cardiol. 2005;28(3):136-42. [pmid: 15813620].
136 Kristianson K, Fyhrguist F, Devereux RB, et al. An analysis of cholesterol control and statin use in the Losartan Intervention for Endpoint Reduction in Hypertension Study. Clin Ther. 2003;25(4):1186-99. [pmid: 12809965].
137 Krysiak R, Okopien B. Pleiotropic effects of angiotensin-converting enzyme inhibitors in normotensive patients with coronary artery disease. Pharmacol Rep. 2008;60(4):514-23. [pmid: 18799820].
138 Lahoz C, Mostaza JM, Mantilla MT, et al. Achievement of therapeutic goals and utilization of evidence-based cardiovascular therapies in coronary heart disease patients with chronic kidney disease. Am J Cardiol. 2008;101(8):1098-1102. [pmid: 18394440].
139 Lamas GA, Mitchell GF, Flaker GC, et al. Clinical significance of mitral regurgitation after acute myocardial infarction. Survival and Ventricular Enlargement Investigators. Circulation. 1997;96(3):827-33. [pmid: 9264489].
140 Landmesser U, Spiekermann S, Preuss C, et al. Angiotensin II induces endothelial xanthine oxidase activation: role for endothelial dysfunction in patients with coronary disease. Arterioscler Thromb Vasc Biol. 2007;27(4):943-8. [pmid: 17234726].
141 Leenen FH, Nwachuku CE, Black HR, et al. Clinical events in high-risk hypertensive patients randomly assigned to calcium channel blocker versus angiotensin-converting enzyme inhibitor in the antihypertensive and lipid-lowering treatment to prevent heart attack trial. Hypertension. 2006;48(3):374-84. [pmid: 16864749].
142 Leor J, Reicher-Reiss H, Goldbourt U, et al. Aspirin and mortality in patients treated with angiotensin-converting enzyme inhibitors: a cohort study of 11,575 patients with coronary artery disease. J Am Col Cardiol. 1999;33(7):1920-5.
143 Lievre M, Marre M, Chatellier G, et al. The non -insulin-dependent diabetes, hypertension, microalbuminuria or proteinuria, cardiovascular events, and ramipril (DIABHYCAR) study: design, organization, and patient recruitment. DIABHYCAR Study Group. Control Clin Trials. 2000;21(4):383-96. [pmid: 10913814].
144 Lindholm LH, Ibsen H, Dahlof B, et al. Cardiovascular morbidity and mortality in patients with diabetes in the Losartan Intervention For Endpoint reduction in hypertension study (LIFE): a randomised trial against atenolol. Lancet. 2002;359(9311):1004-10. [pmid: 11937179].
145 Linjer E, Jornmark J, Hedner T, et al. Predictors for high costs of hospital care in elderly hypertensive patients. Blood Press. 2006;15(4):245-50. [pmid: 17078183].
146 Lithell H, Hansson L, Skoog I, et al. The Study on COgnition and Prognosis in the Elderly (SCOPE); outcomes in patients not receiving add-on therapy after randomization. J Hypertens. 2004;22(8):1605-12. [pmid: 15257185].
147 Lithell H, Hansson L, Skoog I, et al. The Study on Cognition and Prognosis in the Elderly (SCOPE): principal results of a randomized double-blind intervention trial. J Hypertens. 2003;21(5):875-86. [pmid: 12714861].
148 Lobos Bejarano JM, Del Castillo JC. The angiotensin-converting enzyme inhibitors reduce the morbidity-mortality in patients with a stable coronary artery disease, in the absence of left ventricular dysfunction or heart failure. FMC. 2007;14(3):184.
149 Lonn E, Shaikholeslami R, Yi Q, et al. Effects of ramipril on left ventricular mass and function in cardiovascular patients with controlled blood pressure and with preserved left ventricular ejection fraction: A substudy of the Heart Outcomes Prevention Evaluation (HOPE) trial. J Am Coll Cardiol. 2004;43(12):2200-6. [pmid: 15193680].
150 Lonn E, Yusuf S, Dzavik V, et al. Effects of ramipril and vitamin E on atherosclerosis: the study to evaluate carotid ultrasound changes in patients treated with ramipril and vitamin E (SECURE). Circulation. 2001;103(7):919-25. [pmid: 11181464].
151 Lonn EM, Yusuf S, Doris CI, et al. Study design and baseline characteristics of the study to evaluate carotid ultrasound changes in patients treated with ramipril and vitamin E: SECURE. Am J Cardiol. 1996;78(8):914-9. [pmid: 8888665].
152 Luders S, Schrader J, Berger J, et al. The PHARAO study: prevention of hypertension with the angiotensin-converting enzyme inhibitor ramipril in patients with high-normal blood pressure: a prospective, randomized, controlled prevention trial of the German Hypertension League. J Hypertens. 2008;26(7):1487-96. [pmid: 18551027].
153 Luno J, Garcia de Vinuesa S. Control of arterial pressure in diabetic nephropathy. Nefrologia. 2001;21(3):240-5. (Spanish). [pmid: 11471304].
154 Lynch AI, Boerwinkle E, Davis BR. Pharmacogenetic association of the NPPA T2238C genetic variant with cardiovascular disease outcomes in patients with hypertension. JAMA. 2008;299(3):296-307. [pmid: 18212314].
155 Magrini G, Nicolosi GL, Chiariello M, et al. Rationale, characteristics and study design of PREAMI (Perindopril and Remodelling in the Elderly with Acute Myocardial Infarction) study. Ital Heart J. 2005;6(Suppl 7):14S-23S. (Italian). [pmid: 16485513].
156 Majahalme SK, Baruch L, Aknay N. Comparison of treatment benefit and outcome in women versus men with chronic heart failure (from the Valsartan Heart Failure Trial). Am J Cardiol. 2005;95(4):529-32. [pmid: 15695147].
157 Mancini GB. Quinapril ischemic event trial. Am J Cardiol. 2001;88(11):1348. [pmid: 11728375].
158 Management Committee on behalf of the High Blood Pressure Research Council of Australia. Australian comparative outcome trial of angiotensin-converting enzyme inhibitor and diuretic based treatment of hypertension in the elderly (ANBP2): Objectives and protocol. Clin Exp Pharmacol Physiol. 1997;24(2):188-92. [pmid: 9075595].
159 Mancini GBJ, Henry GC, Macaya C, et al. Angiotensin-converting enzyme inhibition with quinapril improves endothelial vasomotor dysfunction in patients with coronary artery disease. Circulation. 1996;94:258-65. [pmid: 8759064].
160 Mann J, Julius S. The Valsartan Antihypertensive Long-term Use Evaluation (VALUE) trial of cardiovascular events in hypertension. Rationale and design. Blood Press. 1998;7(3):176-83. [pmid: 9758088].
161 Mann JF, Gerstein HC, Yi Q, et al. Development of renal disease in people at high cardiovascular risk: results of the HOPE randomized study. J Am Soc Nephrol. 2003;14(3):641-7. [pmid: 12595499].
162 Mann JF, Schmieder RE, McQueen M, et al. for the ONTARGET Investigators. Renal outcomes with telmisartan, ramipril, or both, in people at high vascular risk (the ONTARGET study): a multicentre, randomized, double-blind, controlled trial. Lancet. 2008;372(9638):547-53. [pmid: 18707986].
163 Marre M, Lievre M, Vasmant D, et al. Determinants of elevated urinary albumin in the 4,937 type 2 diabetic subjects recruited for the DIABHYCAR Study in Western Europe and North Africa. Diabetes Care. 2000;23(Suppl 2):B40-8. [pmid: 10860190].
164 Mason B, Matsuyama J, Jue S. Adherence consistency across treatment regimens. Diabetes Care. 1994;17(4):347-8. [pmid: 8026296].
165 Massie BM, Carson PE, McMurray JJ, et al. Irbesartan in patients with heart failure and preserved ejection fraction. N Engl J Med. 2008;359(23):2456-67. [pmid: 19001508].
166 McCall AL. Reducing CVD risk in type 2 DM. Current Diabetes Report. 2003;3(5):363-4.
167 McConaghy JR. Is treatment of hypertension with acetylcholine esterase inhibitors (ACEIs) superior to other antihypertensives in preventing significant cardiovascular events and death in patients with type 2 diabetes?. J Fam Pract. 2000;49(11):980. [pmid: 11093559].
168 McMurray J, Ostergren J, Pfeffer M, et al. Clinical features and contemporary management of patients with low and preserved ejection fraction heart failure: Baseline characteristics of patients in the Candesartan in Heart failure -Assessment of Reduction in Mortality and morbidity. Eur J Heart Fail. 2003;5(3):261-70. [pmid: 12798823].
169 McMurray J, Ostergren J, Pfeffer M, et al. Clinical features and contemporary management of patients with low andpreserved ejection fraction heart failure: baseline characteristics of patients in the Candesartan in Heart failure-Assessment of Reduction in Mortality and morbidity (CHARM) programme. Eur J Heart Fail. 2003;5(3):261-70. [pmid: 12798823].
170 McMurray J, Solomon S, Pieper K, et al. The effect of valsartan, captopril, or both on atherosclerotic events after acute myocardial infarction: an analysis of the Valsartan in Acute Myocardial Infarction Trial (VALIANT). J Am Coll Cardiol. 2006;47(4):726-33. [pmid: 16487836].
171 McMurray JJ, Ostergren J, Swedberg K, et al. Effects of candesartan in patients with chronic heart failure and reduced left-ventricular systolic function taking angiotensin-converting-enzyme inhibitors: the CHARM-Added trial. Lancet. 2003;362(9386):767-71. [pmid: 13678869].
172 McMurray JJV, Carson PE, Komajda M, et al. Heart failure with preserved ejection fraction: Clinical characteristics of 4133 patients enrolled in the I-PRESERVE trial. Eur J Heart Fail. 2008;10(2):149-56. [pmid: 18279770].
173 Mehler PS, Coll JR, Estacio R, et al. Intensive blood pressure control reduces the risk of cardiovascular events in patients with peripheral arterial disease and type 2 diabetes. Circulation. 2003;107(5):753-6. [pmid: 12578880].
174 Menard J, Patchett AA. Angiotensin-converting enzyme inhibitors. Adv Protein Chem. 2001;56:13-75. [pmid: 11329852].
175 Meredith IT, Alison JF, Zhang FM, et al. Captopril potentiates the effects of nitroglycerin in the coronary vascular bed. J Am Coll Cardiol. 1993;22(2):581-7. [pmid: 8335833].
176 Messerli FH, Grossman E. Doxazosin arm of the ALLHAT study discontinued: how equal are antihypertensive drugs? Antihypertensive and Lipid Lowering Treatment to Prevent Heart Attack Trial. Curr Hypertens Rep. 2000;2(3):241-2. [pmid: 10981155].
177 Messerli FH, Grossman E. CAPPP trial. Captopril Prevention Project. Lancet. 1999;353(9166):1794. [pmid: 10348012].
178 Mitchell GF, Dunlap ME, Warnica W, et al. Long-term trandolapril treatment is associated with reduced aortic stiffness: The prevention of events with angiotensin-converting enzyme inhibition hemodynamic substudy. Hypertension. 2007;49(6):1271-7. [pmid: 17452505].
179 Mitsuyama K. Multiphasic action of AT1 receptor blockers and their therapeutic effects for cardiovascular diseases. Nippon Yakurigaku Zasshi. 2008;131(3):176-7. (Japanese). [pmid: 18350678].
180 Mochizuki S, Dahlof B, Shimizu M, et al. Valsartan in a Japanese population with hypertension and other cardiovascular disease (Jikei Heart Study): a randomised, open-label, blinded endpoint morbidity-mortality study. Lancet. 2007;369(9571):1431-9. [pmid: 17467513].
181 Mochizuki S, Shimizu M, Taniguchi I, et al. JIKEI HEART Study--a morbi-mortality and remodeling study with valsartan in Japanese patients with hypertension and cardiovascular disease. Cardiovasc Drugs Ther. 2004;18(4):305-9. [pmid: 15367828].
182 Nesbitt SD. Perspectives on prehypertension. J Cardiometab Syndr. 2006;1(5):364-5. [pmid: 17679784].
183 Nielsen FS. Diabetic nephropathy in non-insulin dependent diabetes mellitus. Cardiovascular risk factors and antihypertensive treatment. Dan Med Bull. 2000;47(4):249-70. [pmid: 11064829].
184 Niskanen L, Hedner T, Hansson L, et al. Reduced cardiovascular morbidity and mortality in hypertensive diabetic patients on first-line therapy with an ACE inhibitor compared with a diuretic/beta-blocker-based treatment regimen: a subanalysis of the Captopril Prevention Project. Diabetes Care. 2001;24(12):2091-6. [pmid: 11723089].
185 Norris K, Bourgoigne J, Gassman J, et al. Cardiovascular outcomes in the African American Study of Kidney Disease andHypertension (AASK) Trial. Am J Kidney Dis. 2006;48(5):739-51. [pmid: 17059993].
186 Odenthal HJ, Josephs W. Angiotensin-converting enzyme inhibition and angina pectoris. Dtsch Med Wochenschr. 1992;117(48):1849-53. (German). [pmid: 1451651].
187 Ogihara T, Nakao K, Fukui T, et al. Effects of candesartan compared with amlodipine in hypertensive patients with high cardiovascular risks: candesartan antihypertensive survival evaluation in Japan trial. Hypertension. 2008;51(2):393-8. [pmid: 18172059].
188 Okamura A, Ohishi M, Rakugi H, et al. Pharmacogenetic analysis ofthe effect of angiotensin-converting enzyme inhibitor on restenosis after percutaneous transluminal coronary angioplasty. Angiology. 1999;50(10):811-22. [pmid: 10535720].
189 Okimoto T, Imazu M, Hayashi Y, et al. Quinapril with high affinity to tissue angiotensin-converting enzyme reduces restenosis after percutaneous transcatheter coronary intervention. Cardiovasc Drugs Ther. 2001;15(4):323-9. [pmid: 11800416].
190 Okumura K, Sone T, Kondo J, et al. Quinapril prevents restenosis after coronary stenting in patients with angiotensin-converting enzyme D allele. Circ J. 2002;66(4):311-6. [pmid: 11954942].
191 Olsen MH, Wachtell K, Dahlof B, et al. The effect of losartan compared with atenolol on the incidence of revascularization in patients with hypertension and electrocardiographic left ventricular hypertrophy. The LIFEstudy. J Hum Hypertens. 2006;20(6):460-4. [pmid: 16572193].
192 Olsson LG, Swedberg K, Ducharme A, et al. Atrial fibrillation and risk of clinical events in chronic heart failure with and without left ventricular systolic dysfunction: results from the Candesartan in Heart failure-Assessment of Reduction in Mortality and morbidity (CHARM) program. J Am Coll Cardiol. 2006;47(10):1997-2004. [pmid: 16697316].
193 Omland T, Sabatine MS, Jablonski K, et al. Prognostic Value of B-Type Natriuretic Peptides in Patients With Stable Coronary Artery Disease. The PEACE Trial. J Am Coll Cardiol. 2007;50(3):205-14. [pmid: 17631211].
194 Oosterga M, Voors AA, Buikema H, et al. Angiotensin II formation in human vasculature after chronic ACE inhibition: A prospective, randomized, placebo-controlled study. Cardiovasc Drugs Ther. 2000;14:55-60. [pmid: 10755201].
195 Oosterga M, Voors AA, Pinto YM, et al. Effects of quinapril on clinical outcome after coronary artery bypass grafting (The QUO VADIS study). Am J Cardiol. 2001;87(5):542-6. [pmid: 11230836].
196 Opie L, Dalby T, Naidoo DP. Perindopril (Coversyl) prevents cardiovasculardeath and MI in coronary disease patients regardless of their cardiovascular risk. Cardiovasc J S Afr. 2003;14(5):277-9. [pmid: 14664228].
197 Os I, Franco V, Kjeldsen SE, et al. Effects of losartan in women with hypertension and left ventricular hypertrophy: results from the Losartan Intervention for Endpoint Reduction in Hypertension Study. Hypertension. 2008;51(4):1103-8. [pmid: 18259029].
198 Ostergren J, Sleight P, Dagenais G, et al. Impact of ramipril in patients with evidence of clinical or subclinical peripheral arterial disease. Eur Heart J. 2004;25(1):17-24. [pmid: 14683738].
199 Ostergren J, Bjorhold I, Andersson F, et al. Pharmacoeconomic impact of HOPE. Int J Clin Pract. 2001;(Suppl 117):19-21.
200 Otsuka M, Yamamoto H, Okimoto T, et al. Long-term effects of quinapril with high affinity for tissue angiotensin-converting enzyme after coronary intervention in Japanese. Am Heart J. 2004;147(4):662-8. [pmid: 15077082].
201 Otterseted JE, Sleight P. The HOPE study: comparison with other trials of secondary prevention. Eur Heart J. 2001;22(15):1307-10. [pmid: 11465962].
202 Ozdemir M, Arslan U, Turkoglu S, et al. Losartan improves heart rate variability and heart rate turbulence in heart failure due to ischemic cardiomyopathy. J Card Fail. 2007;13(10):812-7. [pmid: 18068613].
203 Palmas W, Ma S, Psaty B, et al. Antihypertensive medications and C-reactive protein in the multi-ethnic study of atherosclerosis. Am J Hypertens. 2007;20(3):233-41. [pmid: 17324732].
204 Passa P, Chatellier G. The DIAB-HYCAR Study. Diabetologia. 1996;39(12):1662-7. [pmid: 9081852].
205 Patel A, Chalmers J, Poulter N. ADVANCE: action in diabetes and vascular disease. J Hum Hypertens. 2005;19(Suppl 1):S27-S32. [pmid: 16075030].
206 Pepine CJ, Rouleau JL, Annis K, et al. Effects of angiotensin-converting enzyme inhibition on transient ischemia: the Quinapril Anti-Ischemia and Symptoms of Angina Reduction (QUASAR) trial. J Am Coll Cardiol. 2003;42(12):2049-59. [pmid: 14680725].
207 Perepech NB. Ischemic heart disease with low risk of vascular complications -- a novel indication for angiotensin converting enzyme inhibitors (results of EUROPA trial). Kardiologiia. 2004;44(3):106-10. (Russian). [pmid: 15489840].
208 Perkovic V, Ninomiya T, Arima H, et al. Chronic kidney disease, cardiovascular events, and the effects of perindopril-based blood pressure lowering: data from the PROGRESS study. J Am Soc Nephrol. 2007;18(10):2766-72. [pmid: 17804673].
209 Persson H, Lonn E, Edner M, et al. Diastolic dysfunction in heart failure with preserved systolic function: need for objective evidence:results from the CHARM Echocardiographic Substudy-CHARMES. J Am Coll Cardiol. 2007;49(6):687-94. [pmid: 17291934].
210 Peters S, Gotting B, Trummel M, et al. Valsartan for prevention of restenosis after stenting of type references.r2/C lesions: the VAL-PREST trial. J Invas Cardiol. 2001;13(2):93-7.
211 Pfeffer MA, Braunwald E, Moye LA, et al. Effect of captopril on mortality and morbidity in patients with left ventricular dysfunction after myocardial infarction. Results of the survival and ventricular enlargement trial. The SAVE Investigators. N Engl J Med. 1992;327(10):669-677. [pmid: 1386652].
212 Pfeffer MA, McMurray JJV, Velazquez EJ, et al. Valsartan, captopril, or both in myocardial infarction complicated by heart failure, left ventricular dysfunction, or both. N Engl J Med. 2003;349(20):1893-906. [pmid: 14610160].
213 Pfeffer MA, Swedberg K, Granger CB, et al. Effects of candesartan on mortality and morbidity in patients with chronic heart failure: the CHARM-Overall programme. Lancet. 2003;362:759-66. [pmid: 13678868].
214 Pfeffer MA, Domanski M, Verter J, et al. The continuation of the prevention of events with angiotensin-converting enzyme inhibition (PEACE) trial. Am Heart J. 2001;142(3):375-7. [pmid: 11526345].
215 Piller LB, Ford CE, Davis BR, et al. Incidence and predictors of angioedema in elderly hypertensive patients at high risk for cardiovascular disease: A report from the antihypertensive and lipid-lowering treatment to prevent heart attack trial (ALLHAT). J Clin Hypertens. 2006;8(9):649-56.
216 Poole-Wilson PA, Lubsen J. Losartan for cardiovascular disease in patients with and without diabetes in the LIFE study. Lancet. 2002;359:2199. [pmid: 12091001].
217 Procopiou M. The ADVANCE trial. Lancet. 2008;371:25. [pmid: 18177767].
218 The PROGRESS Collaborative Group. Effects of a perindopril-based blood pressure lowering regimen on cardiac outcomes among patients with cerebrovascular disease. Eur Heart J. 2003;24(5):475-84. [pmid: 12633548].
219 Rahman M, Pressel S, Davis BR, et al. Cardiovascular outcomes in high-risk hypertensive patients stratified by baseline glomerular filtration rate. Ann Intern Med. 2006;144(3):172-80. [pmid: 16461961].
220 Rahman M, Pressel S, Davis BR, et al. Renal outcomes in high-risk hypertensive patients treated with an angiotensin-converting enzyme inhibitor or a calcium channel blocker vs a diuretic: A report from the antihypertensive and lipid-lowering treatment to prevent heart attack trial (ALLHAT). Arch Intern Med. 2005;165:936-46. [pmid: 15851647].
221 Rahman M, Pressel S, Davis BR, et al. Cardiovascular outcomes in high-risk hypertensive patients stratified by baseline glomerular filtration rate. Ann Intern Med. 2006;144(3):172-80. [pmid: 16461961].
222 Rayner B. Selective imidazoline agonist moxonidine plus the ACE inhibitor ramipril in hypertensive patients with impaired insulin sensitivity: partners in a successful MARRIAGE?. Curr Med Res Opin. 2004;20(3):359-67. [pmid: 15025845].
223 Reims HM, Oparil S, Kjeldsen SE, et al. Losartan benefits over atenolol in non-smoking hypertensive patients with left ventricular hypertrophy: The LIFE study. Blood Press. 2004;13(6):376-84. [pmid: 15771223].
224 Redekop WK, Orlewska E, Maciejewski P, et al. Costs and effects of secondary prevention with perindopril in stable coronary heart disease in Poland: an analysis fo the EUROPA study including 1251 Polish patients. Pharmacoeconomics. 2008;26(10):861-77. [pmid: 18793033].
225 Riegger GA. Effects of quinapril on exercise tolerance in patients with mild to moderate heart failure. Eur Heart J. 1991;12(6):705-11. [pmid: 1830551].
226 Rodgers A, Chapman N, Woodward M, et al. Perindopril-based blood pressure lowering in individuals with cerebrovascular disease: consistency of benefits by age, sex and region. J Hypertens. 2004;22:653-59. [pmid: 15076173].
227 Rodriguez-Granillo GA, Winter S, Bruining N, et al. Effect of perindopril on coronary remondelling: insights from a multicentre, randomized study. Eur Heart J. 2007;28:2326-31. [pmid: 17766284].
228 Rodriguez-Granillo GA, Vos J, Bruining N, et al. Long-term effect of perindopril on coronary atherosclerosis progression (from the perindopril’s prospective effect on cornary atherosclerosis by angiography and intravascular ultrasound evaluation (PERSPECTIVE) study. Am J Cardiol. 2007;100:159-63. [pmid: 17631061].
229 Rouleau JL, Chatterjee K, Benge W, et al. Alterations in left ventricular function and coronary hemodynamics with captopril, hydralazine and prazosin in chronic ischemic heart failure: a comparative study. Circulation. 1982;65:671-78. [pmid: 7037220].
230 Rutherford JD, Pfeffer MA, Moye LA, et al. Effects of captopril on ischemic events after myocardial infarction. Results of the survival and ventricular enlargement trial. SAVE investigators. Circulation. 1994;90:1731-38. [pmid: 7923656].
231 Sabative MS, Morrow DA, Jablonski KA, et al. Prognostic significance of the centers for disease control/American Heart Asssociation high-sensitivity c-reactive protein cut points for cardiovascular and other outcomes in patients with stable coronary artery disease. Circulation. 2007;115:1528-36. [pmid: 17372173].
232 Sadamatsu K, Shimokawa H, Tashiro H, et al. Long term treatment with enalapril reduces plasma concentrations of macrophage colony stimulating factor in patients with coronary artery disease. Heart. 2001;86:456-58. [pmid: 11559690].
233 Safar ME, Vaisse B, Blacher J, et al. Pulse pressure monitoring of open antihypertensive therapy. Am J Hypertens. 2004;12(12 Pt 1):1088-94. [pmid: 15607613].
234 Schadlich PK, Brecht JG, Rangoonwala B, et al. Cost effectiveness of ramipril in patients at high risk for cardiovascular events: Economic evaluation of the HOPE (Heart Outcomes Prevention Evaluation) study for Germany from the statutory health insurance perspective. Pharmacoeconomics. 2004;22(25):955-73. [pmid: 15449961].
235 Schlaifer JD, Mancini GBJ, O’Neill BJ, et al. Influence of smoking status on angiotensin-converting enzyme inhibitor-related improvement in coronary endothelial function. Cardiovasc Drugs Ther. 1999;13:201-9. [pmid: 10439882].
236 Schlaifer JD, Wargovich TJ, O’Neill B, et al. Effects of quinapril on coronary blood flow in coronary artery disease patients with endothelial dysfunction. Am J Cardiol. 1997;80(12):1594-7. [pmid: 9416943].
237 Schmieder RE. Endothelial dysfunction: how can one intervene at the beginning of the cardiovascular continuum?. J Hypertens. 2006;24(suppl 2):S31-5.
238 Schmieder RE, Handrock R. the VALUE study group. Control of systolic blood pressure in the VALUE trial after 12 months. Dtsch Med Wochenschr. 2003;128(10):485-6. (German). [pmid: 12627338].
239 Schrader J, Luders S, Kulschewski A, et al. Morbidity and mortality after stroke, eprosartan compared with nitrendipine for secondary prevention: Principal results of a prospective randomized controlled study (MOSES). Stroke. 2005;36:1218-26. [pmid: 15879332].
240 Schrier RW, Estacio RO. Additional follow-up from the ABCD trial in patients with type 2 diabetes and hypertension. N Engl J Med. 2000;343(26):1969. [pmid: 11186674].
241 Schrier RW, Estacio RO, Esler A, et al. Effects of aggressive blood pressure control in normotensive type 2 diabetic patients on albuminuria, retinopathy and strokes. Kidney Int. 2002;61:1086-97. [pmid: 11849464].
242 Schrier RW, Estacio RO, Jeffers B. Appropriate blood pressure control in NIDDM (ABCD) trial. Diabetologia. 1996;39:1646-54. [pmid: 8960857].
243 Scientific Committee of the PERTINENT Sub-Study on behalf of the EUROPA-PERTINENT Investigators. PERTINENT-Perindopril-thrombosis, inflammation, endothelial dysfunction and neurohormonal activation trial: A sub-study of the EUROPA study. Cardiovasc Drugs Ther. 2003;17:83-91. [pmid: 12843690].
244 Seth S, Mohan A. Quinapril for coronary artery disease. Natl Med J India. 1997;10(2):73-4. [pmid: 9153985].
245 Sever PS, Dahlof B, Poulter NR, et al. Ango-scandinavian cardiac outcomes trial: a brief history, rationale and outline protocol. J Hum Hypertens. 2001;15(suppl 1):S11-12. [pmid: 11685901].
246 Sever PS, Poulter NR, Elliott WJ, et al. Blood pressure reduction is not the only determinant of outcome. Circulation. 2006;113:2754-74. [pmid: 16769926].
247 Simons WR. Comparative cost effectiveness of angiotensin II receptor blockers in a US managed care setting: olmesartan medoxomil compared with losartan, valsartan, and irbesartan. Pharmacoeconomics. 2003;21(1):61-74. [pmid: 12484804].
248 Sleight P. The ONTARGET/TRANSCENT trial programme: baseline data. Acta Diabetol. 2005;42:S50-6. [pmid: 15868120].
249 Smebye ML, Iversen EK, Hoieggen A, et al. Effect of hemoglobin levels on cardiovascular outcomes in patients with isolated systolic hypertension and left ventricular hypertrophy (from the LIFE study). Am J Cardiol. 2007;100:855-9. [pmid: 17719333].
250 Solomon SD, Anavekar N, Skali H, et al. Influence of ejection fraction on cardiovascular outcomes in a broad spectrum of heart failure patients. Circulation. 2005;112:3738-44. [pmid: 16330684].
251 Solomon SD, Wang D, Finn P, et al. Effect of candesartan on cause-specific mortality in heart failure patients: The candesartan in heart failure assessment of reduction in mortality and morbidity (CHARM) program. Circulation. 2004;110:2180-3. [pmid: 15466644].
252 Sutton MSJ, Pfeffer MA, Lemuel M, et al. Cardiovascular death and left ventricular remodeling two years after myocardial infarction: Baseline predictors and impact of long-term use of captopril: Information from the survival and ventricular enlargement (SAVE) trial. Circulation. 1997;96:3294-99. [pmid: 9396419].
253 Stoschitzky K. The EUROPA trial. Lancet. 2003;362:1935-6. [pmid: 14667757].
254 Stumpe KO, Overlack A. on behalf of the Perindopril Therapeutic Safety Study Group (PUTS). A new trial of the efficacy, tolerability, and safety of angiotensin-converting enzyme inhibition in mild systemic hypertension with concomitant diseases and therapies. Am J Cardiol. 1993;71:32E-37E.
255 Suzuki H, Kanno Y, Sugahara S, et al. Effect of angiotensin receptor blockers on cardiovascular events in patients undergoing hemodialysis: an open-label randomized controlled trial. Am J Kidney Dis. 2008;52(3):501-6. [pmid: 18653268].
256 Swedberg K, Pfeffer M, Granger C, et al. Candesartan in heart failure – Assessment of reduction in mortality and morbidity (CHARM): Rationale and design. J Card Fail. 1999;5:276-82. [pmid: 10496201].
257 Tedesco MA, Natale F, Calabro R. Effects of monotherapy and combination therapy on blood pressure control and target organ damage: a randomized prospective intervention study in a large population of hypertensive patients. J Clin Hypertens. 2006;8(9):634-41.
258 The CAPPP Group. The Captopril Prevention Project: a prospective intervention trial of angiotensin converting enzyme inhibition in the treatment of hypertension. The CAPPP Group. J Hypertens. 1990;8(11):985-90. [pmid: 1981218].
259 The GLANT Study Group. A 12-month comparison of ACE inhibitor and CA antagonist therapy in mild to moderate essential hypertension--The GLANT Study. Study Group on Long-term Antihypertensive Therapy. Hypertens Res. 1995;18(3):235-44. [pmid: 7584934].
260 The Multicenter European Trial with Cilazapril After Angioplasty to Prevent Transluminal Coronary Obstruction and Restenosis (MERCATOR) Study Group. Does the new angiotensin converting enzyme inhibitor Cilazapril Prevent Restenosis After Percutaneous Transluminal Coronary Angioplasty? Results of the MERCATOR Study: A Multicenter, Randomized, Double-Blind Placebo-Controlled Trial. Circulation. 1992;86(1):100-10. [pmid: 1535568].
261 The PHYLLIS Project Group. Plaque Hypertension Lipid-Lowering Italian Study (PHYLLIS): a protocol for non-invasive evaluation of carotid atherosclerosis in hypercholesterolaemic hypertensive subjects. J Hypertens. 1993;11(suppl 5):S314-5.
262 The SOLVD Investigators. Effect of enalapril on mortality and the development of heart failure in asymptomatic patients with reduced left ventricular ejection fractions. N Engl J Med. 1992;327(10):685-91. [pmid: 1463530].
263 Timmis AD, Pitt B. Effects of ACE inhibitors on coronary atherosclerosis and restenosis. Br Heart J. 1994;72:57-60.
264 Toprak O, Cirit M, Bayata S, et al. The effect of pre-procedural captopril on contrast-induced nephropathy in patients who underwent coronary angiography. Anadolu Kardiyol Derg. 2003;3:98-103. (Turkish). [pmid: 12826500].
265 Tousoulis D, Kourtellaris P, Antoniades C, et al. Effects of irbesartan and perindopril on forearm reactive hyperemia and inflammatory process, in normotensive patients with coronary artery disease. Int J Cardiol. 2008;124:127-9. [pmid: 17343934].
266 Toyofyuku M, Imazu M, Sumii K, et al. Influence of angiotensinogen M253T gene polymorphism and an angiotensin converting enzyme inhibitor on restenosis after percutaneous coronary intervention. Atherosclerosis. 2002;160(2):339-44. [pmid: 11849656].
267 Trenkwalder P, Elmfeldt D, Hofman A, et al. The study on cognition and prognosis in the elderly (SCOPE) – major CV events and stroke in subgroups of patients. Blood Press. 2005;14(1):31-7. [pmid: 15823945].
268 Trevelyan J, Brull DJ, Needham EW, et al. Effect of enalapril and losartan on cytokines in patients with stable angina pectoris awaiting coronary artery bypass grafting and their interaction with polymorphisms in the interleukin-6 gene. Am J Cardiol. 2004;94(5):564-69. [pmid: 15342284].
269 Tschope C, Tschope R, Unger T. Microalbuminuria in patients with hypertension and cardiovascular comorbidity, REAL observational study oftreatment with Irbesartan/HCTZ. MMW Fortschr Med. 2006;148(25):48-51. (German). [pmid: 16859162].
270 Tzourio C. Vascular factors and cognition: toward a prevention of dementia?. J Hypertens. 2003;21(suppl 5):S15-9.
271 UK Prospective Diabetes Study Group. Tight blood pressure control and risk of macrovascular and microvascular complications in type 2 diabetes: UKPDS 38. BMJ. 1998;317:703-13. [pmid: 9732337].
272 Ujiie Y, Hirosaka A, Mitsugi M, et al. Effects of angiotensin-converting enzyme inhibitors or an angiotensin receptor blocker in combination with aspirin and cilostazol on in-stent restenosis. Int Heart J. 2006;47:173-84. [pmid: 16607045].
273 Umemoto S, Kamiya A, Matsuzaki M, et al. COPE trial. Nippon Rinsho. 2006;64(suppl 6):470-4. (Japanese). [pmid: 16981580].
274 van den Heuvel ADFM, van Gilst WH, van Veldhuisen DJ, et al. Long-term anti-ischemic effects of angiotensin-converting enzyme inhibition in patients after myocardial infarction. J Am Coll Cardiol. 1997;30:400-5. [pmid: 9247511].
275 van Haelst PL, Tervaert JW, van Geel P, et al. Long term angiotensin converting enzyme-inhibition in patients after coronary artery bypass grafting reduces levels of soluble intercellular cell adhesion molecule-1. Eur J Vasc Endovasc Surg. 2003;26:387-91. [pmid: 14512000].
276 Vanuzzo D. The reduction of cardiovascular risk with ramipril. Ital Heart J. 2000;1(suppl 5):713-4. (Italian).
277 Vizir VA, Berezin AE. Losartan in therapy of chronic heart failure. Klin Med. 2000;78(2):36-9. (Russian).
278 Wachtell K, Hornestam B, Lehto M, et al. Cardiovascular morbidity and mortality in hypertensive patients with a history of atrial fibrillation: The losartan intervention for end point reduction in hypertension (LIFE) study. J Am Coll Cardiol. 2005;45(5):705-11. [pmid: 15734614].
279 Wang L, Huang X, Zhou Y, et al. Effects of angiotensin receptor blocker and angiotensin-converting enzyme inhibitor on vascular endothelial function in type 2 diabetic patients with atherosclerosis: a comparative study. J First Mil Med Univ. 2005;25:967-71. (Chinese).
280 Weber MA, Julius S, Kieldsen SE, et al. Blood pressure dependent and independent effects of antihypertensive treatment onclinical events in the VALUE trial. Lancet. 2004;363:2049-51. [pmid: 15207957].
281 Whelton PK, Barzilay J, Cushman WC, et al. Clinical outcomes in antihypertensive treatment of type 2 diabetes, impaired fasting glucose concentration, and normoglycemia. Arch Intern Med. 2005;165:1401-9. [pmid: 15983290].
282 White HD, Aylward PEG, Huang Z, et al. Mortality and morbidity remain high despite captopril and/or valsartan therapy in elderly patients with left ventricular systolic dysfunction, heart failure, or both after acute myocardial infarction: Results from the valsartan in acute myocardial infarction trial (VALIANT). Circulation. 2005;112:3391-9. [pmid: 16301343].
283 Wiedermann CJ. Losartan for cardiovascular disease in patients with and without diabetes in the LIFE study. Lancet. 2002;359:2199. [pmid: 12091002].
284 Wierzchowieski M, Filipiak J, Poprawski K, et al. The effect of on-yeart Captopril treatment on exercise tolerance and myocardial ischemia in patients with myocardial infarction. Pol Merk Lek. 2000;9:536-40. (Polish).
285 Willenheimer R, Juul-Moller S, Forslund L, et al. No effects on myocardial ischaemia in patients with stable ischaemic heart disease after treatment with ramipril for 6 months. Curr Control Trials Cardiovasc Med. 2001;2:99-105. [pmid: 11806779].
286 Willenheimer R, Rydberg E, Oberg L, et al. ACE inhibition with ramipril improves left ventricular function at rest and post exercise in patients with stable ischemic heart disease and preserved left ventricular systolic function. Eur Heart J. 1999;20:1647-56. [pmid: 10543928].
287 Wing LMH, Reid CM, Ryan P, et al. A comparison of outcomes with angiotensin-converting-enzyme inhibitors and diuretics for hypertension in the elderly. N Engl J Med. 2003;348:583-92. [pmid: 12584366].
288 Wing LM, Reid CM, Ryan P, et al. Second Australian National Blood Pressure Study (ANBP2). Australian Comparative Outcome Trial of ACE inhibitor-and di uretic-based treatment of hypertension in the elderly. Management Committee on behalf of the High Blood Pressure Research Council of Australia. Clin and Exper Hypertension. 1997;19(5–6):779-91.
289 Wing LM, Reid CM, Ryan P, et al. Second Australian National Blood Pressure Study (ANBP2). Australian Comparative Outcome Trial of ACE inhibitor-and diuretic -based treatment of hypertension in the elderly. Management Committee on behalf of the High Blood Pressure Research Council of Australia. Clin and Exper Hypertension. 1997;19(5–6):779-91.
290 Wright JT, Dunn JK, Cutler JA, et al. Outcomes in hypertensive black and nonblack patients treated with chlorthalidone, amlodipine, and lisinopril. JAMA. 2005;293:1595-608. [pmid: 15811979].
291 Xie Z, Zeng S. Changes of plasma soluble CD40 ligand, tumor necrosis factor alpha and C reactive protein in patients with coronary heart disease and the intervention of losartan. Zhongguo Linchuang Kangfu. 2005;9:71-3. (Chinese).
292 Yamabe T, Imazu M, Yamamoto H, et al. Effects of cilazapril on vascular restenosis after percutaneous transluminal coronary angioplasty. Coron Artery Dis. 1995;6(7):573-9. [pmid: 7582196].
293 Yip GWK, Wang M, Wang T, et al. The Hong Kong diastolic heart failure study: A randomised controlled trial of diuretics, irbesartan and ramipril on quality of life, exercise capacity, left ventricular global and regional function in heart failure with a normal ejection fraction. Heart. 2008;94:573-80. [pmid: 18208835].
294 Yoshida D, Higashiura K, Shimamoto K. Treatment of hypertensive patients with impaired glucose tolerance (IGT). Nippon Rinsho. 2005;63(suppl 2):533-7. (Japanese). [pmid: 15779436].
295 Young JB. ACE inhibitors and ischemic heart disease. Coron Artery Dis. 1995;6(4):272-80. [pmid: 7655709].
296 Yusuf S, Gerstein H, Hoogwerf B, et al. Ramipril and the development of diabetes. JAMA. 2001;286:1882-5. [pmid: 11597291].
297 Yusuf S, Pfeffer MA, Swedberg K, et al. Effects of candesartan in patients with chronic heart failure and preserved left-ventricular ejection fraction: the CHARM-Preserved trial. Lancet. 2003;362:777-81. [pmid: 13678871].
298 Yusuf S, Diener HC, Sacco RL, et al. for the PRoFESS Study Group. Telmisartan to prevent recurrent stroke and cardiovascular events. N Engl J Med. 2008;359(12):1225-37. [pmid: 18753639].
299 Zamorski MA. CCBs vs ACE inhibitors in patients with diabetes. J Fam Pract. 1998;47:12-3. [pmid: 9673598].

## Systematic Review Search

1 Abdulla J, Barlera S, Latini R, et al. A systematic review: effect of angiotensin converting enzyme inhibition on left ventricular volumes and ejection fraction in patients with a myocardial infarction and in patients with left ventricular dysfunction. Eur J Heart Failure. 2007;9(2):129-35.
2 Abuissa H, Jones PG, Marso SP, et al. Angiotensin-converting enzyme inhibitors or angiotensin receptor blockers for prevention of type 2 diabetes: a meta-analysis of randomized clinical trials. J Am Coll Cardiol. 2005;46(5):821-6. [pmid: 16139131].
3 Aguilar MI, Hart R, Pearce LA. Oral anticoagulants versus antiplatelet therapy for preventing stroke in patients with non-valvular atrial fibrillation and no history of stroke or transient ischemic attacks. Cochrane Database of Systematic Reviews. 2008;4.
4 Amsallem E, Kasparian C, Haddour G, et al. Phosphodiesterase III inhibitors in heart failure. Cochrane Database of Systematic Reviews. 2008;4.
5 Anarow WS. Treatment of congestive heart failure in older persions. J Am Geriatr Soc. 1997;45(10):1252-7. [pmid: 9329490].
6 Andraws R, Brown DL. Effect of inhibition of the renin-angiotensin system on development of type 2 diabetes mellitus (meta-analysis of randomized trials). Am J Cardiol. 2007;99(7):1006-12. [pmid: 17398202].
7 Arici M, Erdem Y. Dual blockade of the renin-angiotensin system for cardiorenal protection: an update. Am J Kidney Dis. 2009;53(2):332-45. [pmid: 19166800].
8 Aronow WS. Management of older persons after myocardial infarction. J Am Geriatr Soc. 1998;46(11):1459-68. [pmid: 9809771].
9 Aronow WS. Treatment of congestive heart failure in older persons. J Am Geriatr Soc. 1997;47(10):1252-7. [pmid: 9329490].
10 Aronson D, Rayfield EJ, Chesebro JH. Mechanisms determining course and outcome of diabetic patients who have had acute myocardial infarction. Ann Intern Med. 1997;126(4):296-306. [pmid: 9036802].
11 Aursnes I, Tvete IF, Gasemyr J, et al. Clinical efficacies of antihypertensive drugs. Scand Cardiovasc J. 2003;37(2):72-9. [pmid: 12775305].
12 Baillie GM, Sherer JT, Weart CW. Insulin and coronary artery disease: is syndrome X the unifying hypothesis?. Ann Pharmacother. 1998;32(2):233-47. [pmid: 9496410].
13 Baker DW. Prevention of heart failure. J Cardiac Failure. 2002;8(5):333-46. [pmid: 12411985].
14 Berry C, Tardif JC, Bourassa MG. Coronary heart disease in patients with diabetes: part I: recent advances in prevention and noninvasive management. J Am Coll Cardiol. 2007;49(6):631-42. [pmid: 17291928].
15 Bethel MA, Holman R, Haffner SM, et al. Determining the most appropriate components for a composite clinical trial outcome. Am Heart J. 2008;56(4):633-40. [pmid: 18926145].
16 Bjelakovic G, Nikolova D, Gluud LL, et al. Antioxidant supplements for preventing gastrointestinal cancers. Cochrane Database of Systematic Reviews. 2008;4.
17 Bjelakovic G, Nikolova D, Gluud LL, et al. Antioxidant supplements for prevention of mortality in healthy participants and patients with various diseases. Cochrane Database of Systematic Reviews. 2008;4.
18 Blood Pressure Lowering Treatment Trialists’ Collaboration. Blood pressure-dependent and independent effects of agents that inhibit the renin-angiotensin system. J Hypertension. 2007;25(5):951-8.
19 Boden WE, Vray M, Eschwege E, et al. Heart rate-lowering and -regulating effects of once-daily sustained-release diltiazem. Clin Cardiol. 2001;24(1):73-9. [pmid: 11195610].
20 Boos CJ. Cardiovascular protection with ace inhibitors--more HOPE for EUROPA. Med Sci Monitor. 2004;10(12):SR23-8.
21 Bugiardini R, Bairey Merz CN. Angina with “normal” coronary arteries: a changing philosophy. JAMA. 2005;293(4):477-84. [pmid: 15671433].
22 Butler R, Morris AD, Struthers AD. Angiotensin-converting enzyme gene polymorphism and cardiovascular disease. Clin Sci. 1997;93(5):391-400. [pmid: 9486084].
23 Chen H, Liu J, Yang M. Corticosteroids for viral myocarditis. Cochrane Database of Systematic Reviews. 2008;4.
24 Chen J, Wu G, Li S, et al. Shengmai (a traditional Chinese herbal medicine) for heart failure. Cochrane Database of Systematic Reviews. 2008;4.
25 Coleman CI, Baker WL, Kluger J, et al. Antihypertensive medication and their impact on cancer incidence: a mixed treatment comparison meta-analysis of randomized controlled trials. J Hypertension. 2008;26(4):622-9.
26 Dahlof B, Devereux RB, Kjeldsen SE, et al. Atenolol as a comparator in outcome trials in hypertension: a correct choice in the past, but not for the future?. Blood Pressure. 2007;16(1):6-12. [pmid: 17453746].
27 de Courten B, Barber MN, Johnston RV, et al. Hypolipidemic and antihypertensive drugs for prevention of cardiovascular complications in patients with rheumatoid arthritis. Cochrane Database of Systematic Reviews. 2008;4.
28 de Vries RJ, van Veldhuisen DJ, Dunselman PH. Efficacy and safety of calcium channel blockers in heart failure: focus on recent trials with second-generation dihydropyridines. Am Heart J. 2000;139(2):185-94. [pmid: 10650289].
29 Dicpinigaitis PV. Angiotensin-converting enzyme inhibitor-induced cough: ACCP evidence-based clinical practice guidelines. Chest. 2006;129(1 Suppl):169S-173S. [pmid: 16428706].
30 Dobre D, van Veldhuisen DJ, DeJongste MJ, et al. The contribution of observational studies to the knowledge of drug effectiveness in heart failure. Br J Clin Pharmacol. 2007;64(4):406-14. [pmid: 17764473].
31 Dornbrook-Lavender KA, Roth MT, Pieper JA. Secondary prevention of coronary heart disease in the elderly. Ann Pharmacother. 2003;37(12):1867-76. [pmid: 14632542].
32 Dzau VJ. Angiotensin converting enzyme inhibitors and the cardiovascular system. J Hypertension. 1992;10(3):S3-10.
33 Elsayed EF, Tighiouart H, Griffith J, et al. Cardiovascular disease and subsequent kidney disease. Arch Intern Med. 2007;167(11):1130-6. [pmid: 17563020].
34 Faris R, Flather MD, Purcell H, et al. Diuretics for heart failure. Cochrane Database of Systematic Reviews. 2008;4.
35 Filion KB, Pilote L, Rahme E, et al. Perioperative use of cardiac medical therapy among patients undergoing coronary artery bypass graft surgery: a systematic review. Am Heart J. 2007;154(3):407-14. [pmid: 17719282].
36 Fretheim A, Bjorndal A, Oxman AD, et al. Which antihypertensive drugs should be used in the primary prevention of cardiovascular disease?. Tidsskrift for Den Norske Laegeforening. 2002;122(23):2283-6. [pmid: 12448269].
37 Gillespie EL, White CM, Kardas M, et al. The impact of ACE inhibitors or angiotensin II type 1 receptor blockers on the development of new-onset type 2 diabetes. Diabetes Care. 2005;28(9):2261-6. [pmid: 16123505].
38 Gluckman TJ, Sachdev M, Schulman SP, et al. A simplified approach to the management of non-ST-segment elevation acute coronary syndromes. JAMA. 2005;293(3):349-57. [pmid: 15657328].
39 Goderis G, Boland B. Cardiovascular prevention in type 2 diabetic patients: review of efficacious treatments. Acta Clinica Belgica. 2004;59(6):329-39. [pmid: 15819377].
40 Hankey GJ, Norman PE, Eikelboom JW. Medical treatment of peripheral arterial disease. JAMA. 2006;295(5):547-53. [pmid: 16449620].
41 Haynes RB, Ackloo E, Sahota N, et al. Inventions for enhancing medication adherence. Cochrane Database of Systematic Reviews. 2008;4.
42 Healey JS, Baranchuk A, Crystal E, et al. Prevention of atrial fibrillation with angiotensin-converting enzyme inhibitors and angiotensin receptor blockers: a meta-analysis. J Am Coll Cardiol. 2005;45(11):1832-9. [pmid: 15936615].
43 Hilleman DE, Banakar UV. Issues in contemporary drug delivery. Part VI: Advanced cardiac drug formulations. J Pharm Tech. 1992;8(5):203-11.
44 Hood WB, Dans AL, Guyatt GH, et al. Digitalis for treatment of congesting heart failure in patients in sinus rhythm. Cochrane Database of Systematic Reviews. 2008;4.
45 Howes LG, Lykos D, Rennie GC. Effects ofantihypertensive drugs on coronary artery disease risk: a meta-analysis. Clin Exp Pharmacol Physiol. 1996;23(6–7):555-8. [pmid: 8800583].
46 Johnson AD, Gong Y, Wang D, et al. Promoter polymorphisms in ACE (angiotensin I-converting enzyme) associated with clinical outcomes in hypertension. Clin Pharmacol Ther. 2009;85(1):36-44. [pmid: 18946466].
47 Kalus JS, White CM. Amlodipine versus Angiotensin-receptor blockers for nonhypertension indications. Ann Pharmacother. 2002;36(11):1759-66. [pmid: 12398574].
48 Kerr CP. Hypertension in the 1990s: a new disease. J Am Board Fam Prac. 1993;6(3):243-54.
49 Kikano GE, Brown MT. Antiplatelet therapy for atherothrombotic disease: an update for the primary care physician. Mayo Clinic Proc. 2007;82(5):583-93.
50 Kramer JM, Newby LK, Chang WC, et al. International variation in the use of evidence-based medicines for acute coronary syndromes. Eur Heart J. 2003;24(23):2133-41. [pmid: 14643274].
51 Kuchenbecker R, Berwanger O, Rosito G. Statins for preventing major vascular events in people with hypertension. Cochrane Database of Systematic Reviews. 2008;4.
52 Lafuente-Lafuente C, Mouly S, Longas-Tejero MA, et al. Antiarrythmics for maintaining sinus rhythm after cardioversion of atrial fibrillation. Cochrane Database of Systematic Reviews. 2008;4.
53 Li J, Zhang Q, Zhang M, et al. Intravenous magnesium for acute myocardial infarction. Cochrane Database of Systematic Reviews. 2008;4.
54 Lip GY, Makin AJ. Treatment of hypertension in peripheral arterial disease. Cochrane Database of Systematic Reviews. 2008;4.
55 Lip GYH, Chung I. Anticoagulation for heart failure in sinus rhythm. Cochrane Database of Systematic Reviews. 2008;4.
56 Lip GYH, Chung I. Antiplatelet agents versus control or anticoagulation for heart failure in sinus rhythm. Cochrane Database of Systematic Reviews. 2008;4.
57 Liu G, Chen X, Qu T. Huangqi preparations for unstable angina. Cochrane Database of Systematic Reviews. 2008;4.
58 Liu X, Li J, Wu T. Nitrates for stable angina. Cochrane Database of Systematic Reviews. 2008;4.
59 Loomba RS, Arora R. Prevention of coronary heart disease in women. Ther Adv Cardiovasc Dis. 2008;2(5):321-7. [pmid: 19124430].
60 Madrid AH, Peng J, Zamora J, et al. The role of angiotensin receptor blockers and/or angiotensin converting enzyme inhibitors in the prevention of atrial fibrillation in patients with cardiovascular diseases: meta-analysis of randomized controlled clinical trials. Pacing and Clin Electrophys. 2004;27(10):1405-10.
61 Mancini GB. Emerging role of angiotensin II type 1 receptor blockers for the treatment of endothelial dysfunction and vascular inflammation. Can J Cardiol. 2002;18(12):1309-16. [pmid: 12518183].
62 Mancini GB. Long-term use of angiotensin-converting enzyme inhibitors to modify endothelial dysfunction: a review of clinical investigations. Clin Invest Med. 2000;23(2):144-61. [pmid: 10852664].
63 Mark L, Dani G, Kiss Z, et al. [A change of attitude in lipidology, achievementof target levels. What comes next?][Hungarian]. Orvosi Hetilap. 2008;149(37):1731-6. [pmid: 18805756].
64 Matchar DB, McCrory DC, Orlando LA, et al. Systematic review: comparative effectiveness of angiotensin-converting enzyme inhibitors and angiotensin II receptor blockers for treating essential hypertension. Ann Intern Med. 2008;148(1):16-29. [pmid: 17984484].
65 McCall KL, Craddock D, Edwards K. Effect of angiotensin-converting enzyme inhibitors and angiotensin II type 1 receptor blockers on the rate of new-onset diabetes mellitus: a review and pooled analysis. Pharmacotherapy. 2006;26(9):1297-306. [pmid: 16945052].
66 McDowell SE, Coleman JJ, Ferner RE. Systematic review and meta-analysis of ethnic differences in risks of adverse reactions to drugs used in cardiovascular medicine. BMJ. 2006;332(7551):1177-81. [pmid: 16679330].
67 McGuinness B, Todd S, Passmore P, et al. Blood pressure lowering in patients without prior cerebrovascular disease for prevention of cognitive impairment and dementia. Cochrane Database of Systematic Reviews. 2008;4.
68 Messerli FH, Grossman E, Goldbourt U. Antihypertensive therapy in diabetic hypertensive patients. Am J Hypertension. 2001;14(5):S12-16.
69 Meune C, Mahe I, Mourad JJ, et al. Interaction between angiotensin-converting enzyme inhibitors and aspirin: a review. Eur J Clin Pharmacol. 2000;56:9-10. 609. 20.
70 Mulrow CD, Mulrow JP, Linn WD, et al. Relative efficacy of vasodilator therapy in chronic congestive heart failure. Implications of randomized trials. JAMA. 1988;259(23):3422-6. [pmid: 3286914].
71 Nawarskas KK, Spinler SA. Update on the interaction between aspirin and angiotensin-converting enzyme inhibitors. Pharmacotherapy. 2000;20(6):698-710. [pmid: 10853626].
72 Neal B, MacMahon S, Chapman N, et al. Effects of ACE inhibitors, calcium antagonists, and other blood-pressure-lowering drugs: results of prospectively designed overviews of randomised trials. Lancet. 2000;356(9246):1955-64. [pmid: 11130523].
73 Nelson KM, Yeager BF. What is the role of angiotensin-converting enzyme inhibitors in congestive heart failure and after myocardial infarction?. Ann Pharmacother. 1996;30(9):986-93. [pmid: 8876861].
74 Nicolai SPA, Kruidenier LM, Bendermacher BLW, et al. Gingko biloba for intermittent claudication. Cochrane Database of Systematic Reviews. 2008;4.
75 Nolan RP, Jong P, Barry-Bianchi SM, et al. Biobehavioral and exercise therapies on heart rate variability in coronary artery disease: a systematic review. Eur J Cardiovasc Prevent Rehab. 2008;15(4):386-96.
76 Nony P, Boissel JP, Girard P, et al. Relative efficacy of angiotensin converting enzyme inhibitors on mortality of patients with congestive heart failure: implications of randomized trials androle of the aetiology (ischaemic or non -ischaemic) of heart failure. Eur Heart J. 1992;13(8):1101-8. [pmid: 1387085].
77 Okrainec K, Platt R, Pilote L, et al. Cardiac medical therapy in patients after undergoing coronary artery bypass graft surgery: a review of randomized controlled trials. J Am Coll Cardiol. 2005;45(2):177-84. [pmid: 15653013].
78 Pahor M, Psaty BM, Alderman MH, et al. Health outcomes associated with calcium antagonists compared with other first-line antihypertensive therapies: a meta-analysis of randomised controlled trials. Lancet. 2000;356(9246):1949-54. [pmid: 11130522].
79 Pahor M, Psaty BM, Alderman MH, et al. Therapeutic benefits of ACE inhibitors and other antihypertensive drugs in patients with type 2 diabetes. Diabetes Care. 2000;23(7):888-92. [pmid: 10895836].
80 Paramothayan NS, Lasserson TJ, Wells AU, et al. Prostacyclin for pulmonary hypertension in adults. Cochrane Database of Systematic Reviews. 2008;4.
81 Paravastu S, Chandra V, Mendonca D, et al. Beta blockers for peripheral aterial disease. Cochrane Database of Systematic Reviews. 2008;4.
82 Park IU, Taylor AL. Race and ethnicity in trials of antihypertensive therapy to prevent cardiovascular outcomes: a systematic review. Ann Fam Med. 2007;5(5):444-52. [pmid: 17893387].
83 Pedersen SA, Galatius S, Olsen MH, et al. High prevalence of risk factors in coronary artery disease in EUROPA gives HOPE for ACE inhibitors after PEACE. Cardiology. 2008;111(1):63-7. [pmid: 18239395].
84 Perez MI, Musini VM, Wright JM. Effect of early treatment with anti-hypertensive drugs on short and long-term health outcomes in patients with an acute cardiovascular event. Cochrane Database of Systematic Reviews. 2008;4.
85 Perez MI, Musini VM, Wright JM. Pharmacological interventions for hypertensive emergencies. Cochrane Database of Systematic Reviews. 2008;4.
86 Pillay A, O’Reagan LL. Methyldopa for the management of essential hypertension. Cochrane Database of Systematic Reviews. 2008;4.
87 Psaty BM, Lumley T, Furberg CD, et al. Health outcomes associated with various antihypertensive therapies used as first-line agents: a network meta-analysis. JAMA. 2003;289(19):2534-44. [pmid: 12759325].
88 Psaty BM, Smith NL, Siscovick DS, et al. Health outcomes associated with antihypertensive therapies used as first-line agents. A systematic review and meta-analysis. JAMA. 1997;277(9):739-45. [pmid: 9042847].
89 Reboldi G, Angeli F, Cavallini C, et al. Comparison between angiotensin-converting enzyme inhibitors and angiotensin receptor blockers on the risk of myocardial infarction, stroke and death: a meta-analysis. J Hypertension. 2008;26(7):1282-9.
90 Ribeiro AB. Angiotensin II antagonists--therapeutic benefits spanning the cardiovascular disease continuum from hypertension to heart failure and diabetic nephropathy. Curr Med Res Opin. 2006;22(1):1-16. [pmid: 16393425].
91 Richter B, Bandeira-Echtler E, Bergerhoff K, et al. Pioglitazone for type 2 dianetes mellitus. Cochrane Database of Systematic Reviews. 2008;4.
92 Richter B, Bandeira-Echtler E, Bergerhoff K, et al. Dipeptidyl peptidase-4 (DPP-4) inhibitors for type 2 diabetes mellitus. Cochrane Database of Systematic Reviews. 2008;4.
93 Richter B, Bandeira-Echtler E, Bergerhoff K, et al. Rosiglitazone for type2 diabetes mellitus. Cochrane Database of Systematic Reviews. 2008;4.
94 Ruilope LM, Segura J. Advantages of new cardiovascular risk-assessment strategies in high-risk patients with hypertension. Clin Ther. 2005;27(10):1658-68. [pmid: 16330303].
95 Scharplatz M, Puhan MA, Steurer J, et al. What is the impact of the ACE gene insertion/deletion (I/D) polymorphism on the clinical effectiveness and adverse events of ACE inhibitors?--Protocol of a systematic review. BCM Medical Genetics. 2004;5:23.
96 Shu D, Dong B, Wu T, et al. Beta blockers for stable angina. Cochrane Database of Systematic Reviews. 2008;4.
97 Siragy H, Huang J, Lieb DC. The development of the direct renin inhibitor aliskiren: treating hypertension and beyond. Exp Opin Emerg Drugs. 2008;13(3):417-30.
98 Sleight P, Jakobsen A, Heroys J, et al. No HOPE without proof: do ARBs meet the standard for cardiovascular protection?. Medscape J Med. 2008;10(Suppl):s6. [pmid: 18449379].
99 Souza LM, Atallah An, Saconato H, et al. Oral drugs for hypertensive urgencies. Cochrane Database of Systematic Reviews. 2008;4.
100 Staessen JA, Wang JG, Thijs L. Cardiovascular protection and blood pressure reduction: a meta-analysis. Lancet. 2001;358(9290):1305-15. [pmid: 11684211].
101 Strippoli GFM, Bonifati C, Craig M, et al. Angiotensin converting enzyme inhibitors and angiotensin II receptor antagonists for preventing the progression on diabetic kidney disease. Cochrane Database of Systematic Reviews. 2008;4.
102 Strippoli GFM, Craig M, Craig JC. Antihypertensive agents for preventing diabetic kidney disease. Cochrane Database of Systematic Reviews. 2008;4.
103 Strippoli GFM, Craig M, Schena FP, et al. Antihypertensive agents for preventing progression of diabetic kidney disease. Cochrane Database of Systematic Reviews. 2008;4.
104 Thorp ML, Ditmer DG, Nash MK, et al. A study of the prevalence of significant increases in serum creatinine following angiotension converting enzyme inhibitor administration. J Human Hypertension. 2005;19(5):389-92.
105 Turnbull F. Blood Pressure Lowering Treatment Trialists’ Collaboration. Effects of different blood-pressure-lowering regimens on major cardiovascular events: results of prospectively-designed overviews of randomised trials. Lancet. 2003;362(9395):1527-35. [pmid: 14615107].
106 Turnbull F, Neal B, Algert C, et al. Effects of different blood pressure-lowering regimens on major cardiovascular events in individuals with and without diabetes mellitus: results of prospectively designed overviews of randomized trials. Arch Intern Med. 2005;165(12):1410-9. [pmid: 15983291].
107 Verdecchia P, Reboldi G, Angeli F, et al. Angiotensin-converting enzyme inhibitors and calcium channel blockers for coronary heart disease and stroke prevention. Hypertension. 2005;46(2):386-92. [pmid: 16009786].
108 Vinjar B, Stewart M. Oral vasodilators for primary Raynaud’s phenomenon. Cochrane Database of Systematic Reviews. 2008;4.
109 Vuong AD, Annis LG. Ramipril for the prevention and treatment of cardiovascular disease. Ann Pharmacother. 2003;37(37):412-9. [pmid: 12639174].
110 Wang JG, Li Y, Franklin SS, et al. Prevention of stroke and myocardial infarction by amlodipine and Angiotensin receptor blockers: a quantitative overview. Hypertension. 2007;50(1):181-8. [pmid: 17502490].
111 Wang JG, Staessen JA, Li Y, et al. Carotid intima-media thickness and antihypertensive treatment: a meta-analysis of randomized controlled trials. Stroke. 2006;37(7):1933-40. [pmid: 16763185].
112 Wang JG, Staessen JA. Benefits of antihypertensive pharmacologic therapy and blood pressure reduction in outcome trials. J Clin Hypertension. 2003;5(1):66-75.
113 Weir MR. Effects of renin-angiotensin system inhibition on end-organ protection: can we do better?. Clin Therapeutics. 2007;29(9):1803-24.
114 Wilson MD, Weart CW. Hypertension: are beta-blockers and diuretics appropriate first-line therapies?. Ann Pharmacother. 1994;28(5):617-25. [pmid: 7915151].
115 Wiysonge C, Shey U, Bradley HA, et al. Beta-blockers for hypertension. Cochrane Database of Systematic Reviews. 2008;4.
116 Wu T, Harrison RA, Chen X, et al. Tongxinluo (Tong xin Luo or Tong-xin-luo) capsule for unstable angina pectoris. Cochrane Database of Systematic Reviews. 2008;4.
117 Zannad F, Jakobsen A, Heroys J, et al. Cardiovascular high-risk patients – treat to protect, but whom?. Medscape J Med. 2008;10(Suppl):s2. [pmid: 18449378].
118 Zheng J, Li J, Liu GJ, et al. Traditional Chinese interventions for stable angina. Cochrane Database of Systematic Reviews. 2008;4.