# Search Strategies

Number of citations in ()

/ after an index term indicates that all subheadings were selected.

* before an index term indicates that that term was focused -i.e. limited to records where major MeSH/Emtree term.

“exp” before an index term indicates that the term was exploded.

.tw. indicates a search for a term in title/abstract.

.mp. indicates a free text search for a term.

.pt. indicates a search for a publication type.

$ at the end of a term indicates that this term has been truncated.

? in the middle of a term indicates the use of a wildcard.

adj indicates a search for two terms where they appear adjacent to one another.

sh indicates a search term for subheading.

## MEDLINE (OVID) for Randomized Controlled Trials Using the Cochrane Highly Sensitive and Specific Search Strategy (Sensitivity and Precision Maximizing Version 2008)

1. Coronary Artery Disease/ or Coronary Disease/
2. Myocardial Ischemia/
3. Angina Pectoris/ or Angina, Unstable/
4. Angina Pectoris/ or Arterial Occlusive Diseases/
5. Peripheral Vascular Diseases/
6. Vascular Diseases/
7. Atherosclerosis/
8. Cardiovascular Diseases/
9. Carotid Artery Diseases/
10. (((preserved adj left) or (stable adj cad) or (stable adj chd) or (stable adj coronary) or (preserved adj coronary) or (preserved adj systolic) or (preserved adj ventricular) or (preserved adj lvef) or (preserved adj ef) or (preserved adj ejection)) or (intact adj left) or (intact adj systolic) or (intact adj ventricular) or (intact adj lvef) or (intact adj ef) or (normal adj systolic) or (normal adj ventricular) or (normal adj lvef) or (normal adj ef)).mp
11. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10
12. randomized controlled trial.pt.
13. controlled clinical trial.pt.
14. randomized.ab.
15. placebo.ab.
16. clinical trials as topic.sh.
17. randomly.ab.
18. trial.ti.
19. 12 or 13 or 14 or 15 or 16 or 17 or 18
20. humans.sh.
21. 19 and 20
22. (alacepril or benazepril or captopril or ceronapril or cilazapril or delapril or enalapril or fosinopril or imidapril or libenzapril or lisinopril or moexipril or moveltipril or pentopril or perindopril or quinapril or ramipril or spirapril or temocapril or teprotide or trandolapril or zofenopril).mp.
23. (losartan or olmesartan or telmisartan or valsartan or eprosartan or candesartan or tasosartan or irbesartan).mp.
24. Angiotensin-Converting Enzyme Inhibitors/
25. Angiotensin II Type 1 Receptor Blockers/
26. (ACEI or ARB).mp.
27. 22 or 23 or 24 or 25 or 26
28. 11 and 21 and 27

## CENTRAL (OVID) for Randomized Controlled Trials

1. (alacepril or benazepril or captopril or ceronapril or cilazapril or delapril or enalapril or fosinopril or imidapril or libenzapril or lisinopril or moexipril).mp.
2. (moveltipril or pentopril or perindopril or quinapril or ramipril or spirapril or temocapril or teprotide or trandolapril or zofenopril).mp.
3. (losartan or olmesartan or telmisartan or valsartan or eprosartan or candesartan or tasosartan or irbesartan).mp.
4. Angiotensin-Converting Enzyme Inhibitors/
5. Angiotensin II Type 1 Receptor Blockers/
6. (ACEI or ARB).mp.
7. 1 or 2 or 3 or 4 or 5 or 6
8. Coronary Artery Disease/ or Coronary Disease/
9. Myocardial Ischemia/
10. Angina Pectoris/ or Angina, Unstable/
11. Arterial Occlusive Diseases/
12. Peripheral Vascular Diseases/
13. Vascular Diseases/
14. Atherosclerosis/
15. Cardiovascular Diseases/
16. Carotid Artery Diseases/
17. (((preserved adj left) or (stable adj cad) or (stable adj chd) or (stable adj coronary) or (preserved adj coronary) or (preserved adj systolic) or (preserved adj ventricular) or (preserved adj lvef) or (preserved adj ef) or (preserved adj ejection)) or (intact adj left) or (intact adj systolic) or (intact adj ventricular) or (intact adj lvef) or (intact adj ef) or (normal adj systolic) or (normal adj ventricular) or (normal adj lvef) or (normal adj ef)).mp
18. 8 or 9 or 10 or 11 or 12 or 13 or 14 or 15 or 16 or 17
19. 7 and 18

## EMBASE (Silver Platter) for Randomized Controlled Trials Using the McMaster Health Information Research Unit (HiRU) highly sensitive, highly specific EMBASE search strategy for treatment articles that minimizes differences between sensitivity and specificity

(((preserved adj left) or (stable adj cad) or (stable adj chd) or (stable adj coronary) or (preserved adj coronary) or (preserved adj systolic) or (preserved adj ventricular) or (preserved adj lvef) or (preserved adj ef) or (preserved adj ejection)) or (intact adj left) or (intact adj systolic) or (intact adj ventricular) or (intact adj lvef) or (intact adj ef) or(normal adj systolic) or (normal adj ventricular) or (normal adj lvef) or (normal adj ef)) and (((angiotensin converting enzyme inhibitor or ACE inhibitor or ACEI or arb or angiotensin receptor blocker or angiotensin ii type 1 receptor blocker) or (alacapril or benazepril or captopril or ceronapril or cilazapril or delapril or enalapril or fosinopril or imidapril or libenzapril or lisinopril or moexipril or moveltipril orpentopril or perinodopril or quinapril or ramipril or spirapril or temocapril or teprotide or trandolapril or zofenopril or losartan or olmesartan or telmisartan or valsartan or eprosartan or can desartan or tasosartan or irbesartan)) and (((random) in AB) or (double-blind) or (placebo) or ((random) in TI)))

## MEDLINE (OVID) for Observational Studies using the Scottish Intercollegiate Guidelines Network Observational Study MEDLINE Search Filter (available at: http://www.sign.ac.uk/methodology/filters.html)

1. epidemiologic studies/
2. exp case control studies/
3. exp Cohort Studies/
4. case control.tw.
5. (cohort adj (study or studies)).tw.
6. cohort analy$.tw.
7. (follow up adj (study or studies)).tw.
8. (observational adj (study or studies)).tw.
9. longitudinal.tw.
10. retrospective.tw.
11. cross sectional.tw.
12. Cross-Sectional Studies/
13. 1 or 2 or 3 or 4 or 5 or 6 or 7 or 8 or 9 or 10 or 11 or 12
14. (alacepril or benazepril or captopril orceronapril or cilazapril or delapril or enalaprilor fosinopril or imidapril or libenzapril orlisinopril or moexipril).mp.
15. (moveltipril or pentopril or perindopril or quinapril or ramipril or spirapril or temocapril or teprotide or trandolapril or zofenopril).mp.
16. (losartan or olmesartan or telmisartan or valsartan or eprosartan or candesartan or tasosartan or irbesartan).mp.
17. Angiotensin-Converting Enzyme Inhibitors/
18. Angiotensin II Type 1 Receptor Blockers
19. (ACEI or ARB).mp.
20. 14 or 15 or 16 or 17 or 18 or 19
21. (((preserved adj left) or (stable adj cad) or (stable adj chd) or (stable adj coronary) or 22. (preserved adj coronary) or (preserved adj systolic) or (preserved adj ventricular) or (preserved adj lvef) or (preserved adj ef) or (preserved adj ejection)) or (intact adj left) or (intact adj systolic) or (intact adj ventricular) or (intact adj lvef) or (intact adj ef) or (normal adj systolic) or (normal adj ventricular) or (normaladj lvef) or (normal adj ef)).mp
22. 13 and 20 and 21

## EMBASE (Silver Platter) for Observational Studies using the Scottish Intercollegiate Guidelines Network Observational Study EMBASE Search Filter (available at: http://www.sign.ac.uk/methodology/filters.html)

1. Clinical study/
2. Case control study
3. Family study/
4. Longitudinal study/
5. Retrospective study/
6. Prospective study/
7. Randomized controlled trials/
8. 6 not 7
9. Cohort analysis/
10. (Cohort adj (study or studies)).mp.
11. (Case control adj (study or studies)).tw.
12. (followup adj (study or studies)).tw.
13. (observational adj (study or studies)).tw.
14. (epidemiologic$ adj (study or studies)).tw.
15. (cross sectional adj (study or studies)).tw.
16. Or/1–5,8–15
17. (((preserved adj left) or (stable adj cad) or (stable adj chd) or (stable adj coronary) or (preserved adj coronary) or (preserved adj systolic) or (preserved adj ventricular) or (preserved adj lvef) or (preserved adj ef) or (preserved adj ejection)) or (intact adj left) or (intact adj systolic) or (intact adj ventricular) or (intact adj lvef) or (intact adj ef) or (normal adj systolic) or (normal adj ventricular) or (normal adj lvef) or (normal adj ef)).mp
18. 16 AND 17

## MEDLINE (OVID) for Systematic Reviews Using the Cochrane Highly Sensitive and Specific Search Strategy (Sensitivity and Precision Maximizing Version 2008)

1. (((preserved adj left) or (stable adj cad) or (stable adj chd) or (stable adj coronary) or (preserved adj coronary) or (preserved adj systolic) or (preserved adj ventricular) or (preserved adj lvef) or (preserved adj ef) or (preserved adj ejection)) or (intact adj left) or (intact adj systolic) or (intact adj ventricular) or (intact adj lvef) or (intact adj ef) or (normal adj systolic) or (normal adj ventricular) or (normal adj lvef) or (normal adj ef)).mp
2. (alacepril orbenazepril or captopril or ceronapril or cilazapril or delapril or enalapril or fosinopril or imidapril or libenzapril or lisinopril or moexipril).mp.
3. (moveltipril or pentopril or perindopril or quinapril or ramipril or spirapril or temocapril or teprotide or trandolapril or zofenopril).mp.
4. (losartan or olmesartan or telmisartan or valsartan or eprosartan or candesartan or tasosartan or irbesartan).mp.
5. 2 or 3 or 4
6. (angiotensin-converting enzyme inhibitors or angiotensin II type 2 receptor blockers or ACEI or ARB).mp.
7. 5 or 6
8. (coronary artery disease or coronary disease or myocardial ischemia or angina pectoris or unstable angina or aterial occlusive diseases or peripheral vascular disease or vascular disease or atherosclerosis or cardiovascular diseases or carotid artery diseases).mp.
9. 1 or 8
10. 7 or 9
11. meta-analysis.pt.
12. search.tw.
13. cochrane database of systematic reviews.jn.
14. medline or systematic review.tw.
15. 11 or 12 or 13 or 14
16. 10 AND 15

## Cochrane Database of Systematic Reviews (OVID) for Systematic Reviews

1. (((preserved adj left) or (stable adj cad) or (stable adj chd) or (stable adj coronary) or (preserved adj coronary) or (preserved adj systolic) or (preserved adj ventricular) or (preserved adj lvef) or (preserved adj ef) or (preserved adj ejection)) or (intact adj left) or (intact adj systolic) or (intact adj ventricular) or (intact adj lvef) or (intact adj ef) or (normal adj systolic) or (normal adj ventricular) or (normal adj lvef) or (normal adj ef)).mp
2. (alacepril or benazepril or captopril or ceronapril or cilazapril or delapril or enalapril or fosinopril or imidapril or libenzapril or lisinopril or moexipril).mp.
3. (moveltipril or pentopril or perindopril or quinapril or ramipril or spirapril or temocapril or teprotide or trandolapril or zofenopril).mp.
4. (losartan or olmesartan or telmisartan or valsartan or eprosartan or candesartan or tasosartan or irbesartan).mp.
5. 2 or 3 or 4
6. (angiotensin-converting enzyme inhibitors or angiotensin II type 2 receptor blockers or ACEI or ARB).mp.
7. 5 or 6
8. (coronary artery disease or coronary disease or myocardial ischemia or angina pectoris or unstable angina or arterial occlusive diseases or peripheral vascular disease or vascular disease or atherosclerosis or cardiovascular diseases or carotid artery diseases).mp.
9. 1 or 8
10. 7 AND 9