# Abbreviations

ACE: Angiotensin Converting Enzyme
AHRQ: Agency for Healthcare Research and Quality
AIRE: Acute Infarction Ramipril Efficacy
AMSTAR: Assess the Methodological quality of SysteMAtic Review
APRES: Angiotensin-converting Enzyme inhibition Post Revascularization Study
ARB: Angiotensin Receptor Blocker
CABG: Coronary Artery Bypass Grafting
CAMELOT: Comparison of Amlodipine vs Enalapril to Limit Occurrences of Thrombosis
CCB: Calcium Channel Blocker
CHARM: Candesartan in Heart failure Assessment of Reduction Mortality
CI: Confidence Interval
DBP: Diastolic Blood Pressure
EPC: Evidence-based Practice Center
EUROPA: EURopean trial On reduction of cardiac events with Perindopril in stable coronary Artery disease
FOSIDIAL: FOSInopril in DIALysis
GRADE: Grading of Recommendations Assessment, DEvelopment
HDL: High Density Lipoprotein
HOPE: Heart Outcomes Prevention Evaluation
HR: Hazard Ratio
IMAGINE: Ischemia Management with Accupril post-bypass Graft via Inhibition of the coNverting Enzyme
ITT: Intention To Treat
JMIC-B: Japan Multicenter Investigation for Cardiovascular Diseases-B
LDL: Low Density Lipoprotein
LVEF: Left Ventricular Ejection Fraction
MARCATOR: Multicenter American Research trial with Cilazapril After angioplasty to prevent Transluminal coronary Obstruction and Restenosis
MI: Myocardial Infarction
MICRO-HOPE: Microalbuminuria, Cardiovascular and Renal Outcomes–Heart Outcomes Prevention Evaluation
ONTARGET: ONgoing Telmisartan Alone in combination with Ramipril Global Endpoint Trial
PARIS: Effect of ACE inhibitors on angiographic restenosis after coronary stenting
PART-2: Prevention of Atherosclerosis with Ramipril Trial-2
PEACE: Prevention of Events with Angiotensin Converting Enzyme Inhibition
PICOTS: Population, Intervention, Comparator, Outcomes, Timing of outcomes measurement, Setting
QUIET: Quinapril Ischemic Event Trial
RCT: Randomized Controlled Trial
Ischemic Heart Disease Risk Equivalent: Diabetes mellitus or chronic kidney disease, or mixed vascular atherosclerotic disorders (coronary disease, peripheral artery disease, carotid atherosclerosis)
RR: Relative Risk
SAVE: Survival And Ventricular Enlargement
SBP: Systolic Blood Pressure
SCAT: Simvastatin/enalapril Coronary Atherosclerosis Trial
SMILE-ISCHEMIA: Survival of Myocardial Infarcton Long-term Evaluation-ISCHEMIA
TRACE: Trandolapril in patients with reduced left-ventricular function after acute myocardial infarction
TRANSCEND: Telmisartan Ransomized AssessmeNt Study in ACE iNtolerant subjects with cardiovascular Disease
SCR: Scientific Resource Center
VALIANT: VALsartan In Acute myocardial infarction Trial
WMD: Weighted Mean Difference