# Results

The literature search yielded 1560 citations (Figure 2). We identified 189 of these as potentially relevant full studies plus 74 case reports of potential interest. These were retrieved for further evaluation. We also rescreened the 50 studies included in the 2006 and 2007 reports to determine their eligibility for this update, plus 4 additional articles found in other existing systematic reviews. Overall, 209 full-text articles and case reports did not meet eligibility criteria (see Appendix B for a list of rejected articles along with reasons for rejection); thus 84 comparative and noncomparative studies (in 88 articles) are included in this report, and an additional 20 case reports were selected for inclusion.

Figure 2 Literature flow diagram

* Excluded list does not include studies that were screened and excluded for the 2006 report.

Figure 2: Literature Flow Diagram. This figure summarizes the study retrieval and selection process of articles relevant to the two key questions. The figure displays the same information as enumerated in the first paragraph of the Results section, with additional details about the excluded studies and case reports in full-text screening: 1560 citations were retrieved from MEDLINE, Cochrane databases, and EMBASE; 1297 were excluded in abstract screening; 189 studies and 74 case reports were retrieved in full text, to which were added 54 studies from the 2006 and 2007 reports and recent systematic reviews; 155 studies and 54 case reports were excluded for the following reasons: Retrospective PTRAS or Rx study (54), PTRAS study with fewer than 30 subjects (20), PTRA with no stent (15), not primarily ARAS treatment (12), no specific intervention (12), natural history study (11), no outcome or analysis of interest (10), less than 6 months of follow up with no adverse event data (8), not a primary study (4), comparative study with fewer than 10 per arm (4), population had restenosis (2), retrospective surgical study with fewer than 100 subjects (1), study of “drive-by” PTRAS (1). Among case reports: old (51) and not ARAS acute decompensation (3). This left 84 studies in 88 articles, plus 20 case reports.

The “grey literature” search for unpublished trials, done to assess publication bias, in the FDA database, clinicaltrials.gov, the WHO International Clinical Trials Registry Platform, and conference proceedings, did not find any trials with results that were not already included in the report.

The strength of evidence for all Key Questions, with summaries of the evidence, is presented at the end of this chapter under Strength of Evidence Across Study Designs.

## Comparative Studies

We identified 20 studies (with a total of 4526 patients, 2279 in randomized controlled trials [RCT]s and 2247 in nonrandomized comparative studies [NRCS]) that assessed the comparative effectiveness of treatment strategies for the treatment of atherosclerotic renal artery stenosis (ARAS) and reported data on clinical outcomes.9, 19, 20, 22–36 Of these, 15 studies compared percutaneous transluminal renal angioplasty with stent placement (PTRAS) with medical therapy in 3887 patients,9, 19, 20, 22, 24, 25, 28–33, 34b, 35 seven of which were RCTs;19, 20, 24, 32, 32b, 34b, 35 one RCT compared surgical revascularization with medical therapy only in 52 patients.34 Four studies compared PTRAS with surgical therapy in 468 patients,23, 26, 27, 36 one of which was a RCT.23 The studies followed patients from 1 to 8 years.

Most (14/20) comparative studies did not report their funding source, including three of the seven RCTs comparing PTRAS with medical therapy (Ziakka 2008^35^ and the two conference abstracts, Scarpioni 2009^32b^ and Zeller 2013^34b^) and the RCTs of surgical revascularization versus medical therapy (Uzzo 2002^34^) and PTRAS versus surgical therapy (Balzer 2009^23^). The remaining comparative studies were funded by government, academic or hospital centers, or nonprofit organizations, except that two RCTs of PTRAS versus medical therapy were partially funded by industry (ASTRAL [Wheatley 2009^20^] and STAR [Bax 2009^24^]). The industry-funded trials had similar findings as the other comparable trials.

### PTRAS Versus Medical Therapy

#### Key Points

- Seven RCTs and eight NRCSs compared PTRAS and medical therapy. Risk of bias concerns included unblinded outcome assessment, attrition bias, and selection bias and selective outcome reporting among the NRCSs. The RCTs may not be fully representative of patients typically considering or undergoing PTRAS since both they and their clinicians had to have equipoise between PTRAS and continued medical therapy alone. Notably, the RCTs excluded patients with acute decompensation, which by one recent prospective study’s estimate represents about half of patients presenting with ARAS. The NRCSs compared fundamentally different cohorts of patients—those for whom it was decided that PTRAS was indicated and those for whom PTRAS was not considered necessary (or an appropriate option). The NRCSs did not adequately adjust for the differences between patient cohorts.
- Mortality: Four RCTs and five NRCS found no statistically significant difference or MCID between interventions, but no study was adequately powered for mortality.
- Renal replacement therapy (RRT): Four RCTs and five NRCSs had wide differences in rates of RRT across studies. Imprecise estimates found no statistically significant differences or minimal clinically important difference (MCID) in incident RRT between interventions.
- Cardiovascular outcomes: Four RCTs and three NRCSs were heterogeneous in which outcomes were reported. No statistically significant differences or MCID between interventions were found.
- Pulmonary edema: Three RCTs reported on incident pulmonary edema or congestive heart failure (CHF). No statistically significant differences or MCID between interventions were found.
- Kidney function: Six RCTs and five NRCSs reported on changes in kidney function. Five of the RCTs found no statistically significant differences in either likelihood of improvement (or worsening) of kidney function or measures of kidney function (glomerular filtration rate [GFR] or serum creatinine [SCr]). In contrast, about half the NRCSs found that patients’ kidney function was more likely to improve (or less likely to worsen) after PTRAS than with medical therapy alone; however, these analyses were not adjusted for underlying differences between the cohorts.
- Blood pressure (BP) control: Seven RCTs and six NRCSs reported on BP control. One RCT found no difference in improvement (or worsening) of BP control; one found that hypertension (HTN) was much more likely to be cured (PTRAS 11% vs. medical 0%), but similar percentages of patients had failure to improve (PTRAS 22% vs. medical 29%). All but one RCT found no statistically significant difference in changes in measured BP. Two trials both found that patients on average were prescribed 0.2 fewer antihypertensive medications than those who remained on medical therapy only. The six NRCSs reported highly heterogeneous results, except that all but one found no difference in changes in number of antihypertensive medications.
- Adverse events: Five RCTs and four NRCSs reported on adverse events, but only related to PTRAS. PTRAS-associated adverse events included periprocedural deaths (about 0.5%), angioplasty-related dissection and other vessel injuries, vessel occlusion, distal embolization, groin hematoma or hemorrhage, acute kidney injury, and stent dislocation.
- Patient factors: Three RCTs reported on analyses of patient factors as predictors of outcomes. Two RCTs found no factor that differentially predicted outcomes (between PTRAS and medical therapy); One prospective cohort found that patients with flash pulmonary edema or with both rapidly declining kidney function and refractory HTN (prerandomization) had significantly better outcomes after PTRAS.
- Treatment factors: No comparative studies addressed differences in treatment factors as a predictor of outcomes in the comparison of PTRAS versus medical therapy.

#### Key Question 1 Effects of Intervention on Outcomes

##### Randomized Controlled Trials (PTRAS vs. Medical Therapy)

Seven RCTs compared PTRAS with medical therapy only.19, 20, 24, 32, 32b, 34b, 35 The median mean age across the RCTs was 69 years. Enrolled patients had uncontrolled HTN while on two or more medications, with or without mild to moderate chronic kidney disease. About one-third of included patients had diabetes. Coronary artery disease among included patients ranged from 26 to 50 percent. Analyzed studies typically included more men (median 63% male) than women. The definitions of ARAS varied across studies, as described for each study, below (Appendix Tables C.1 and C.3). Only CORAL measured stenosis severity with translesional pressure gradients. Of note, the trials excluded patients with acute decompensation. By contrast, a recent, prospective study found that 106 of 467 patients (23%) presenting with ARAS had flash pulmonary edema (8%) or rapidly declining kidney function (18%), or both.9 A recent literature review reported that the overall weighted prevalence of acute flash pulmonary edema in ARAS was 3.5 percent in those with unilateral ARAS and 14.3 percent among those with bilateral ARAS, although it was unclear what studies these patients came from or exactly who they were.37

Three of seven of the RCTs were of high or unclear risk of bias for blinding of outcome assessment or detection bias (1 high; 2 unclear), five for incomplete outcome data (attrition bias) (3 high; 2 unclear), and four for sample representing the entire population (1 high, 3 unclear). In the two conference abstracts selective reporting bias was high (Appendix Table D.1).

The CORAL trial (Cooper 2014) was conducted at more than 100 international (>80% U.S.) medical centers that were vetted for their PTRAS experience and expertise.19 Due to difficulties enrolling patients, the eligibility criteria changed during enrollment. Initially, eligible patients had systolic BP (SBP) ≥155 mmHg on at least two antihypertensive medications and had >80 percent stenosis with a systolic pressure gradient ≥20 mmHg. Patients with stenosis as low as 60 percent who met other imaging criteria were also included. The measurement of translesional pressure gradients were at the discretion of the operators if stenosis measured at 60 to 80 percent; those with <20 mmHg systolic pressure gradient were excluded. The threshold for SBP was subsequently removed, but if patients did not have systolic HTN, they had to have chronic kidney disease defined as GFR <60 mL/min per 1.73 m^2^ not due to a nonischemic cause. The CORAL trial used an angiographic core lab which standardized readings of angiographic stenosis (core lab estimates of stenosis severity were generally lower than investigator “visual estimates). This was the only study to standardize stenosis severity measurement. Patients were randomized to PTRAS with medical therapy or medical therapy alone, consisting of candesartan (an ARB) with or without hydrochlorothiazide (a diuretic), an amlodipine (calcium channel blocker)-atorvastatin (statin) combination pill, and antiplatelet therapy, all as tolerated. PTRAS was conducted with a distal protection device at the discretion of investigators, and the Genesis^TM^ stent was employed. Periprocedural prophylaxis was given with combination regimens of heparin with ticlopidine, clopidogrel, or aspirin. The trial was funded in part by government grants but many principal investigators disclosed industry connections. The trial analyzed 931 patients (90 percent power would have required 1080 patients). The primary end point was the occurrence of a composite outcome of major cardiovascular or kidney-related event. These included a composite of death from cardiovascular or kidney-related cause, stroke, myocardial infarction, hospitalization for CHF, progressive kidney disease, or the need for permanent kidney-replacement therapy. Secondary clinical end points included the individual components of the primary end point (with death from cardiovascular causes and death from renal causes as separate end points), as well as all-cause mortality. Overall, after a mean followup of 43 months, there were no significant differences in primary or secondary outcomes and no significant interactions were found in a predefined list of subgroups. PTRAS-related complications were rare and did not result in death or dialysis in any patient.

The ASTRAL trial (Wheatley 2009) was conducted in 57 hospitals primarily in the UK.20 Patients with poorly controlled HTN or unexplained kidney disease were screened. Patients were enrolled if they had “substantial anatomical atherosclerotic stenosis…that was considered suitable” for PTRAS and “if the patient’s doctor was uncertain that the patient would definitely have a worthwhile clinical benefit from revascularization.” Almost all patients had at least 50 percent stenosis and 60 percent had at least 70 percent stenosis. Angioplasty without stenting was allowed, but 95 percent had a stent. No distal protection devices were used. Only 83 percent of patients assigned to angioplasty had the procedure. Medical therapy varied according to local protocols, but “typically” consisted of “optimal BP control,” statins, and antiplatelet drugs. The study was funded in part by industry. The study analyzed 806 patients (80 percent power was calculated to be achieved with 700 patients). The primary outcome was change in kidney function, measured as the mean slope of 1/SCr level over time. Secondary outcomes assessed were BP, the time to the first renal event, the time to the first major cardiovascular event, and mortality. Overall, during a median 34 month followup, no significant differences were found in the primary or secondary outcomes; however, the rate of progression of renal impairment, measured by the slope of 1/SCr was slower after PTRAS than with medical therapy alone (P=0.06). Serious complications associated with PTRAS occurred in 23 patients (6%), including cardiac death within 1 month, pulmonary edema, myocardial infarction, rehospitalization for hemorrhage, acute kidney injury, and peripheral amputations due to cholesterol embolisms.

The STAR trial (Bax 2009) was conducted in 10 medical centers in the Netherlands and France.24 This study included 140 patients with GFR 15 to 80 mL/min per 1.73 m^2^, 50 percent or greater stenosis, and controlled BP on a stable medication dosage. Patients who had diabetes with proteinuria or malignant HTN were excluded. The STAR trial was the only trial to explicitly include patients with CHF (about 10%). Patients were randomized to PTRAS with medical therapy or medical therapy alone, consisting of antihypertensive treatment (with a target BP of <140/90 mmHg), a statin, and aspirin (and smoking cessation counseling). Multiple stents were used and patients were given periprocedural aspirin. The trial was funded in part by industry. The primary outcome was worsening of kidney function, as assessed on two repeated measurements by a ≥20 percent decrease in estimated creatinine clearance as compared with baseline. Secondary outcomes were procedural complications, changes in BP, incidence of refractory or malignant HTN and pulmonary edema, cardiovascular morbidity and mortality, and total mortality. Overall, after 2 years of followup, no significant differences were found in primary or secondary outcomes between the two groups; however, only 46 of 64 patients (71%) assigned to PTRAS had the procedure (12 patients were found have stenosis <50 percent at angiography). Four of these 64 patients had serious procedure related complications, including death and dialysis related to a cholesterol embolism.

The RASCAD trial (Marcantoni 2012) randomized 84 patients to PTRAS or medical therapy at a single institution in Italy.32 The study enrolled patients who were undergoing nonemergent coronary angiography, who were screened for ARAS by renal arteriography, and who were found to have >50 percent and ≤80 percent stenosis but not a single functioning kidney and elevated serum creatinine (>4 mg/dL) or an aortic aneurysm requiring surgery. All patients were treated with antihypertensive drugs, statins, and antiplatelet drugs. The study was funded by the hospital with no reported industry funding. The trial analyzed 84 patients who were followed for 1 year. The primary outcome was change in echocardiographic left ventricular myocardial index. Secondary outcomes included left ventricular systolic dysfunction, cardiovascular mortality and morbidity, progression of kidney disease, and BP. Overall, there were no significant differences in primary or secondary outcomes. No serious PTRAS-related complications were reported.

The Ziakka 2008 trial was conducted in one institution in Greece.35 They enrolled 82 patients with ARAS that was not specifically defined. Mean stenosis was 74 percent, using angiographic criteria, but no minimum criteria were reported. All patients had HTN. No medication regimen was specified, but patients were treated with different classes of drugs and “some of them” were taking statins. No mention is made of antiplatelet drugs. The funding sources were not reported, but the authors declared that none had a conflict of interest. Patients were followed for a mean of 48 months. The primary or secondary outcomes were not specified in this trial. Compared to medical therapy alone, after PTRAS, significantly more patients had cured HTN (diastolic BP [DBP] <90 mmHg off treatment, 11% vs. 0%) and improved kidney function (SCr decreased >20%, 31% vs. 0%), but similar numbers started dialysis. Other clinical outcomes were not reported. PTRAS-related complications were not reported.

The RADAR trial (Zeller 2013) aimed to randomize 300 patients with ≥70 percent stenosis, GFR >10 mL/min, and at least mild HTN in a multicenter trial.34a, 34b However, the trial was terminated early after 89 patients were enrolled. An analysis of 67 patients randomized in Germany was presented in a conference abstract. BP and GFR were not significantly different after 12 months of followup.

The NITER trial (Scarpioni 2009) randomized 52 patients in Italy to PTRAS or medical therapy.32a, 32b Patients had ARAS with ≥70 percent stenosis diagnosed by Doppler duplex and confirmed by magnetic resonance, kidney failure, and HTN. The study results have been reported only in a conference abstract. BP and cardiovascular event-free survival were similar in both groups at a mean of 27 months of followup.

##### Nonrandomized Comparative Studies (PTRAS Vs. Medical Therapy)

Eight NRCSs compared PTRAS with medical therapy in a total of 1828 patients.9, 22, 25, 28–31, 33 The average patient age was 70 years. All NRCSs included patients with uncontrolled HTN while on two or more medications, as well as those with or without mild to moderate chronic kidney disease (CKD). Four studies included patients with decompensating conditions, such as acute flash pulmonary edema and acute kidney injury.9, 29, 30, 33 Between 30 and 80 percent of patients had coronary artery disease. NRCSs typically included more males (mean: 58% male) than females. See Appendix Table C.3.

The definitions of renal artery stenosis (RAS) varied across NRCSs. Two included patients with over 50 percent stenosis,9, 30 one with over 60 percent,22 and three with over 70 percent stenosis.28, 31, 33 ARAS was diagnosed in the preoperative period by renal angiography alone in two NRCSs,29, 33 but was diagnosed using additional diagnostic methods, such as magnetic resonance or computed tomographic angiography or duplex ultrasonography, in the remaining six NRCSs. None of the studies reported using translesional pressure gradients to diagnose RAS. The median average SBP was 155 mmHg and DBP 82 mmHg. The median average GFR or creatinine clearance (CrCl) in five NRCSs was 37.8 mL/min/1.73 m^2^. See Appendix Table C.1.

Two of eight NRCSs reported using bare-metal stents,28, 30 but the remaining studies provided no information. Preprocedural and procedural prophylaxis against thrombosis was reported in four NRCSs with varying regimens: one used combination regimens of heparin with ticlopidine, clopidogrel, or aspirin;30 two studies reported aspirin only;29, 33 and one used heparin only.31 The remaining studies provided no details of antiplatelet therapy. See Appendix Table C.2.1. However, as noted below, no studies reported acute thrombotic adverse events, regardless of periprocedural prophylaxis (or lack thereof).

These studies were evenly divided between high and low risk of bias for selection bias (4 high; 3 low), incomplete outcome data (attrition bias) (3 high; 1 unclear; 1 low), and selective reporting bias (3 unclear; 2 high; 2 low). In all studies except one, the sample representing the entire population was rated as having low risk of bias (6 low; 1 unclear) (Risk of Bias Description Appendix Table D.2).

##### Mortality (Study Duration 6 Months or Greater)

###### Randomized Trials

No study was reported to be adequately powered to detect a difference between interventions for mortality. See Appendix Table C.4.1.

Four RCTs reported mortality data for 1 to 5 years followup duration (Figure 3).19, 20, 24, 32 The number and time frame of deaths were similar in all four RCTs. The STAR trial found no difference in all-cause death (crude hazard ratio [HR] 0.99; 95% confidence interval [CI] 0.30 to 3.24) and cardiovascular death (crude HR 0.59; 95% CI 0.11to 3.25) after 2 years between 62 patients who received PTRAS intervention and 74 who were treated medically.24 Similarly, no statistically significant differences were found in the CORAL trial for the outcomes of all-cause death (adjusted HR 0.80; 95% CI 0.58 to 1.12), cardiovascular death (adjusted HR 0.89; 95% CI 0.58 to 1.36), and death due to renal causes (adjusted HR 1.89; 95% CI 0.17 to 20.85) after 3.6 years between the 459 patients who received PTRAS intervention and the 472 who were treated medically. In this RCT, there was no difference in mortality by Kaplan-Meier curve analysis up to 5 years after either PTRAS (n=459) or of medical therapy (n=472).19 (Of note, while not statistically significant, the HR estimate for all-cause death [0.80] just reaches this review’s arbitrary threshold for MCID, however, not the CORAL study’s MCID [0.75 for its primary outcome]). Of the 806 patients who were enrolled in the ASTRAL trial, 103 in the PTRAS group and 106 in the medical-therapy group died during the 5-year study period (HR 0.90; 95% CI 0.69 to 1.18).20 In the RASCAD trial, there was no significant difference between two comparison groups (2 deaths occurred in both arms; odds ratio (OR) 0.92; 95% CI 0.12 to 6.88).32

Figure 3 Death: PTRAS versus medical therapy alone

Point estimates of odds ratios (OR) or hazard ratio (HR) and 95% confidence intervals (CI) from individual studies. ES = effect size, n/N = number of events/total, nd = no data, PMID = PubMed Identifier, PTRAS = percutaneous transluminal renal angioplasty with stent placement, RCT = randomized controlled trials.

Figure 3: Forest plot (without meta-analyses) of odds (or hazard) ratio of death in studies of PTRAS versus medication, for both 4 RCTs and 5 observational studies. The plot shows a scatter of effect estimates, for both RCTs and observational studies, between 0.55 (favoring PTRAS) and 2.14 (favoring medication) but mostly with very wide confidence intervals, all but one of which cross the line of identity.

###### Nonrandomized Studies

Five NRCSs comparing PTRAS with medical therapy reported mortality data. Except for one study that found significantly reduced the risk of death by 45 percent in the combined overall groups from UK and Germany,30 none found a statistically significant difference in all-cause death (Figure 3).22, 28, 30, 31, 33 Notably, the NRCSs compared fundamentally different cohorts of patients—those for whom it was decided that PTRAS was indicated and those for whom PTRAS was not considered necessary (or an appropriate option). The NRCSs did not adequately adjust for the differences between patient cohorts. No study was reported to be adequately powered to assess mortality. Only one NRCS provided adjusted analysis, having matched patients for age and sex;31 none of the studies conducted propensity score matched analyses. Effect sizes ranged from 0.55 to 2.35, with no clear explanation for the heterogeneity. See Appendix Table C.4.1.

##### Renal Replacement Therapy

###### Randomized Trials

Four of the RCTs reported on RRT.19, 20, 24, 35 The overall rates of dialysis varied from 0.7 percent at 2 years to 10 percent at a mean of 4 years of followup (Figure 4). However, no statistically significant differences were found between PTRAS and medical therapy for all trials, with ORs ranging from 1.0 to 2.0, with wide confidence intervals. See Appendix Table C.4.6.

Figure 4 Incident renal replacement therapy: PTRAS versus medical therapy alone

Point estimates of odds ratios (OR) and 95% confidence intervals (CI) from individual studies. n/N = number of events/total, PMID = PubMed Identifier, PTRAS = percutaneous transluminal renal angioplasty with stent placement, RCT = randomized controlled trials.

Figure 4: Forest plot (without meta-analyses) of odds ratio of renal replacement therapy in studies of PTRAS versus medication, for both 4 RCTs and 5 observational studies. The plot shows a scatter of effect estimates, for both RCTs and observational studies, between 0.87 (favoring PTRAS) and 2.45 (favoring medication) but mostly with very wide confidence intervals. All studies are statistically nonsignificant.

###### Nonrandomized Studies

Five studies reported data on patients progressing to end stage renal disease (ESRD) (Figure 4).9, 22, 28, 31, 33 One study explicitly reported that no patients started dialysis. In the remaining four studies, for patients progressing to ESRD, three found no statistically significant difference between comparison groups, with ORs ranging from 1.03 to 7.94 and wide confidence intervals, across all studies. No analysis was adjusted for baseline differences or patient characteristics. See Appendix Table C.4.6.

##### Cardiovascular Outcomes

###### Randomized Trials

Four RCTs19, 20, 24, 32b reported similar cardiovascular event rates in both treatment groups, including myocardial infarction (MI); stroke; newly diagnosed coronary artery, peripheral artery, or cerebrovascular disease; cardiovascular event-free survival, and cardiovascular mortality. See Appendix Table C.4.12.

###### Nonrandomized Studies

Three NRCSs22, 31, 33 reported on different cardiovascular outcomes in each study. Stroke, angina, and abdominal aortic aneurysm rupture each occurred in no or one patient per study. In one study, myocardial infarctions occurred in 17 percent of patients 2 years after PTRAS and 4.5 percent of patients who remained on medical therapy alone, yielding a nonsignificant unadjusted hazard ratio of 3.0 (0.60, 14). In a second study, 14 percent of patients required coronary revascularization within a mean of 2.8 years after PTRAS compared with 22 percent in the medical therapy group (unadjusted OR = 0.58 [0.20, 1.64]). See Appendix Table C.4.17.

##### Pulmonary Edema

In three RCTs (STAR, CORAL, RASCAD),19, 24, 32 episodes of pulmonary edema or CHF were uncommon (1% to 6%) and did not significantly differ between treatment groups. See Appendix Tables C.4.17 and C.4.18. None of the NRCSs reported on pulmonary edema.

##### Kidney Function

###### Randomized Trials

Six RCTs reported on changes in kidney function.19, 20, 24, 32, 34b, 35 In CORAL, SCr was measured in local labs and any doubling was confirmed by the core lab; other trials did not report on SCr measurement methods. No differences were found in the CORAL trial for the outcomes of progressive renal insufficiency (adjusted HR 0.86; 95% CI 0.64 to 1.17).19 In the ASTRAL trial, the two study groups had similar rates of renal events (HR 0.97; 95% CI 0.67 to 1.40).20 In RASCAD, GFR (MDRD equation)38 remained stable for 1 year in both treatment arms and no significant difference was found.32 The STAR trial found no significant difference in SCr or creatinine clearance (Cockcroft-Gault) at 2 years.24 In ASTRAL, the mean slope of 1/SCr revealed a trend towards less decline (p=0.06) but the mean slope of SCr did not (p=0.11). In RADAR, GFR rose over 12 months after PTRAS and fell in the medical therapy arm, but the difference was not statistically significant (p=0.23).34b Only in Ziakka 2008 was a significant difference found; kidney function improved (SCr decreased >20 percent) in 30.5 percent or patients and worsened (SCr increased >20 percent) in 36.2 percent of patients in PTRAS arm, whereas in the medical therapy arm kidney function remained stable in 69.8 percent of patients and worsened in 30.2 percent (P<0.001) (Figure 5).35 See Appendix Tables C.4.2, C.4.3, C.4.5, C.4.6, and C.4.7.

Figure 5 Kidney function improvement (panel A) and worsening (panel B): PTRAS versus medical therapy alone

Point estimates of odds ratios (OR) and 95% confidence intervals (CI) from individual studies. n/N = number of events/total, PMID = PubMed Identifier, PTRAS = percutaneous transluminal renal angioplasty with stent placement, RCT = randomized controlled trials.

Figure 5: Forest plots (without meta-analyses) of odds ratio of kidney function improvement (or cure) in panel A and kidney function worsening in panel B in studies of PTRAS versus medication, for both RCTs (2 improvement, 4 worsening) and 2 observational studies. The plots shows a scatter of effect estimates, for both RCTs and observational studies, between 1.16 and 22.2 for improvement (all favoring PTRAS) and 0.28 and 1.15 (mostly favoring PTRAS). One RCT is statistically significant for improvement (favoring PTRAS) and one observational study is statistically significant for both improvement and worsening (favoring PTRAS).

###### Nonrandomized Studies

Of the five studies that reported on kidney function outcomes, none reported specific methods for measuring SCr; to measure GFR, four used the MDRD equation28, 30, 31, 33 and one iothalamate clearance.29 Three NRCSs reported ordinal outcomes for renal improvement (Figure 5, top).29–31 Kidney function improved in 7 to 25 percent of patients in PTRAS group, as compared with 6 to 8 percent improvement in the medical therapy alone group. Five NRCSs reported higher GFR in the PTRAS group, as compared with the medical therapy group in kidney function.28–31, 33 These studies reported a median 0.1 mL/min change in GFR in PTRAS, as compared with a median −0.4 mL/min change in GFR in medical therapy only group. See Appendix Tables C.4.2, C.4.3, C.4.5, C.4.6, and C.4.7.

##### Blood Pressure Control

###### Randomized Trials

The STAR trial, Ziakka 2008, and the NITER trial reported BP related events (as categorical/ordinal outcomes).24, 32b, 35 In STAR, refractory HTN continued in 0 percent in the PTRAS arm, as compared with 4 percent in medical therapy alone;24 the percentage of patients with target BP (<140/90 mmHg) was similar in both arms (32% vs. 29%, P=0.95). In Ziakka 2008, BP was cured in 11.1 percent, improved in 66.6 percent, and failed to improve in 22.3 percent of patients in PTRAS arm, whereas in the medical therapy arm HTN was cured in 0 percent of patients, improved in 71.4 percent, and failed to improve in 28.6 percent (P<0.001).35 The NITER abstract reported no BP “cures”.32b. See Appendix Tables C.4.12 and C.4.13.

Across four RCTs19, 20, 24, 32, 32b, 34b comparing PTRAS versus medical therapy with detailed BP results, there was a reduction in SBP that ranged from −6 to −17 mmHg in PTRAS arms, as compared with a range of −5.5 to −16 mmHg reduction in SBP in the medical therapy arms. In their longitudinal analysis, the CORAL trial reported a significant difference in SBP (measured in the clinic) favoring PTRAS (−2.3 mm Hg; 95% CI, −4.4 to −0.2; P = 0.03), as compared with medical therapy.19 In contrast, the other five trials (ASTRAL, RASCAD, STAR, NITER, RADAR)20, 24, 32, 32b, 34b found no significant between-group difference in SBP or DBP (measured in the clinic in STAR; not reported other trials). The CORAL trial did not report data on DBP (Figure 6). See Appendix Tables C.4.8, C.4.9, and C.4.11.

Figure 6 Blood pressure, net change: PTRAS versus medical therapy alone

Point estimates of net change blood pressure and 95% confidence intervals (CI) from individual studies. DBP = diastolic blood pressure, N = total sample size, PMID = Pubmed identifier, PTRAS = percutaneous transluminal renal angioplasty with stent placement, RCT = randomized controlled trials, SBP = systolic blood pressure, UK = study cohorts from the UK.

Figure 6: Forest plots (without meta-analyses) of net change systolic blood pressure in panel A and diastolic blood pressure in panel B in studies of PTRAS versus medication, for both RCTs (4 systolic, 5 diastolic) and observational studies (6 systolic, 5 diastolic). The plots shows a scatter of effect estimates, for both RCTs and observational studies. The RCTs are more homogeneous with net change systolic ranging from −2.3 to 3.2 mm Hg, with only the study with a net change of −2.3 mm Hg (favoring PTRAS) being statistically significant. In RCTs, net change diastolic ranged from −3.0 to 3.7 mm Hg, all nonsignificant. Observational studies were highly heterogeneous with net change systolic (at different follow-up times) ranging from −20 to 30 mm Hg, with 3 estimates significantly favoring PTRAS and 3 estimates significantly favoring medication. Similarly, observational study diastolic estimates ranged from −4 to 14 mm Hg, with one estimate significantly favoring PTRAS and two estimates significantly favoring medication.

Changes in number of antihypertensive medications were reported for the CORAL and ASTRAL trials.19, 20 Both found that after PTRAS, patients on average were prescribed 0.2 fewer antihypertensive medications than those who remained on medical therapy only; this difference was statistically significant in CORAL (difference = −0.2 [−0.397, −0.003], P=0.046), but untested (no confidence intervals reported) in ASTRAL (Appendix Table C.4.14).

###### Nonrandomized Studies

One NRCS reported ordinal outcomes for BP improvement.29 Both groups observed a significant decrease in BP, but the magnitude of effect was greater in the PTRAS, as compared with medical therapy (9% SBP decrease in PTRAS vs. 5% decrease in medical therapy only; p=0.016).29 See Appendix Table C.4.13.

The six NRCSs that reported on changes in BP were highly heterogeneous (Figure 6)22, 28–31, 33; three of these studies reported measuring clinic BP,22, 28, 31 one measured clinic BP at one center and 24 hour ambulatory BP at another center.30 Two studies found statistically significant net reductions in SBP favoring PTRAS by 7 or 19 mmHg,11, 31 and, in Kalra 2010, significant net reduction in DBP also favoring PTRAS by 4 mmHg (Kane 2010 did not report DBP).30 But Sofroniadou 2010 found significantly higher SBP (20 mmHg) and DBP (9 mmHg) in patients who had PTRAS.33 Two studies found no significant difference for either SBP or DBP.28, 29 Arthurs reported data that allowed calculations of net change BP, with highly variable differences between PTRAS and medical therapy at different time points from 6 months to 4 years (4 year data omitted from figure because sample size appeared to be about 4 or 5 individuals in each group at that time point).22 See Appendix Tables C.4.8, C.4.9, C.4.11.

Changes in number of antihypertensive medications were reported five NRCSs.22, 28, 29, 31, 33 Only one reported a statistically significant difference between groups.31 See Appendix Table C.4.14.

##### Adverse Events (Including 30-Day Mortality)

###### Randomized Trials

Five trials reported on adverse events related to PTRAS; adverse events related to medications were not reported.19, 20, 23, 24, 32 Two trials reported that 2/280 (0.7%)20 and 2/64 (3%)24 died within 30 days of the procedure due to complications following renal artery perforation or cardiac events. CORAL, the largest trial, had no periprocedural deaths.19 Across all four trials 4 of 848 patients who received PTRAS (including those assigned to medical therapy who crossed over to receive PTRAS) died (0.5%). Of note, the CORAL trial reported that 1 of 478 patients assigned to medical therapy had a fatal stroke on the day of randomization.19 Other serious adverse events reported included, in CORAL, only angiographic complications (implicitly without long-term consequence) including dissections (11/495, 2.2%), vessel occlusions (6/495, 1.2%), distal embolization (6/495, 1.2%), and in one patient each, wire perforation, vessel rupture, and pseudoaneurysm.19 In ASTRAL, 12 serious events in 11 patients occurred in 280 patients, including four with groin hematomas or hemorrhages requiring hospitalization, five with clinically significant acute kidney injury, and one with renal-artery occlusion.20 In addition to the procedure-related deaths, STAR reported two patients with femoral artery false aneurysms and one patient who eventually required permanent dialysis after cholesterol embolization.24 The only serious adverse event in RASCAD was that 1/41 patients (2.5%) required a blood transfusion and rehospitalization from a groin hematoma.32 Balzer 2009 reported 5 periprocedural events in 49 patients, including stent dislocation, local dissection, and postoperative occlusion.23 Appendix Tables C.4.19 and C.4.20.

###### Nonrandomized Studies

Four NRCSs reported periprocedural complications.9, 22, 29, 33 No study reported on medication-related adverse events. Three reported no major complications (renal failure or death in one study;29 acute thrombosis, dissection, renal failure, rapid kidney function decline, hemorrhage, or death in one study;22 undefined in one study33). In contrast, Ritchie 2014 reported a 4.8 percent major complication rate (undefined).9 No study reported episodes of acute thrombosis, regardless of use of prophylaxis. See Appendix Tables C.4.19 and C.4.20.

#### Key Question 2 Association of Patient Factors With Outcomes

The CORAL trial tested for interaction terms with their composite outcome (cardiovascular or renal death, stroke, myocardial infarction, CHF hospitalization, GFR decrease by at least 30%, or RRT).19 None of the prespecified terms (sex, black race, global kidney ischemia, or diabetes) interacted with (altered the comparative effectiveness between) the interventions (PTRAS versus medical therapy alone). They also found no interactions with other tested factors—SCr >1.6 mg/dL, GFR <45 mL/min, SBP >160 mmHg, age >70 years, or site-reported renal artery stenosis ≥80 percent.

In the ASTRAL trial, subgroup analyses were performed for the analysis of the slope of 1/SCr (a proxy for GFR) over 5 years.20 No differences in effect were reported among the prespecified subgroups (baseline SCr and GFR, percent stenosis, kidney length, and prior renal impairment progression) or bilateral versus unilateral severe (>70%) stenosis.

Ritchie 2014, in a retrospective observational study that compared PTRAS to medical therapy only, ran analyses adjusted for age, sex, kidney function, proteinuria, BP, renal artery patency, diabetes, and use of angiotensin converting enzyme inhibitor (ACEi)/angiotensin-receptor blocker (ARB) in different subgroups of patients, comparing PTRAS and medical therapy.9 In patients presenting with flash pulmonary edema, those who received PTRAS had a reduced relative rate of death (0.36; 95% CI 0.16 to 0.80) compared with those treated medically. Similarly, those presenting with both rapidly declining kidney function (SCr increased 20% or by 1.14 mg/dL in 6 months) and refractory HTN (BP >140/90 mmHg on at least three medications) who received PTRAS had a reduced relative rate of death (0.14; 95% CI 0.01 to 0.99) compared with those treated medically. In contrast, those who presented with either rapidly declining kidney function or refractory HTN alone had statistically similar rates of death regardless of treatment choice. In all risk groups, rates of cardiovascular events and RRT were similar between those who received PTRAS or medical therapy.

#### Key Question 3 Association of Treatment Factors With Outcomes

No comparative study addressed this question.

### Surgery Versus Medical Therapy

One RCT (but no NRCS) compared open surgical revascularization with medical therapy alone.

#### Key Points

- One RCT only compared surgery and medical therapy. The study was of low (or unclear) risk of bias.
- Outcomes: No statistically significant differences or MCID were found between interventions for death, dialysis-free survival, or BP control. Adverse events were not reported.
- Patient factors: Patients with baseline elevated SCr had better outcomes if surgically revascularized, in contrast with the total cohort, but no significant interactions were found.
- Treatment factors: No comparative studies addressed differences in treatment factors as a predictor of outcomes in the comparison of surgery versus medical therapy.

#### Key Question 1 Effects of Intervention on Outcomes

##### Randomized Controlled Trial (Surgery Vs. Medical Therapy)

Uzzo 2002 randomized 52 patients with bilateral ARAS (or ARAS in a solitary kidney) or unilateral disease with chronic kidney disease (SCR >1.5 mg/dL or GFR <70 mL/min).34 Patients had >75 percent stenosis; it was not reported whether translesional pressure gradients were used to define stenosis severity. Excluded were patients with SCr >4.0 mg/dL, DBP >100 despite “adequate medical management” or comorbid conditions precluding surgical revascularization. Medical management was not described (but was under the direction of a single nephrologist). Surgery included aortorenal bypass (6/25 patients), splenorenal bypass (3/25), hepatorenal bypass (8/25), ileorenal bypass (6/25), endarterectomy (1/25), and aortic replacement with renal artery reimplantation (1/25). See Appendix Tables C.1, C.2.2, C.3).

This RCT was rated as having low risk of bias for outcome assessment (detection bias), attrition bias, and selective reporting (reporting bias). For all other items, including detection bias and sample representativeness of the entire population, it was unclear. See Appendix Table D1.

Median follow-up time was 74 months. Overall, there were no statistically significant differences or MCID in outcomes or times to outcomes, including death (approximately 60% at 7 years in both groups, P=0.31), time to death (surgery 69 months vs. medical 62 months; P=0.75), dialysis-free survival (P=0.64), or BP control (undefined, P=0.20). See Appendix Tables C.4.1, C.4.6, C.4.12.

Adverse events were not reported.

#### Key Question 2 Association of Patient Factors With Outcomes

Uzzo 2002 reported that patients with baseline elevated SCr (2 to 4 mg/dL) were less likely to die or have uncontrollable HTN if surgically revascularized than if treated medically (P=0.11),34 in contrast with no significant difference in effect for the total cohort, who also included patients lower SCr. However, by multivariable analysis, no interactions were found between treatment choice and baseline demographic factors.

#### Key Question 3 Association of Treatment Factors With Outcomes

No comparative study addressed this question.

### Surgery Versus PTRAS

One RCT and three NRCSs compared surgery to PTRAS.

#### Key Points

- One RCT and three NRCSs compared surgery and PTRAS. The RCT was of low (or unclear) risk of bias. The NRCSs suffered from selection and attrition biases; they also did not adjust their analyses for differences between patient cohorts.
- Outcomes: The RCT found no difference in death, change in kidney function (SCr), BP, or antihypertensive treatment requirement. Periprocedural adverse events occurred in both groups. Two of the three NRCSs reported only limited data, reporting no differences in mortality or HTN. One NRCS found similar rates of death and RRT, long-term kidney function, and BP control; perioperative complications were significantly more common with open surgery than with PTRAS.
- Patient factors: One of two studies found that patients with HTN as their indication for intervention were more likely to have better outcomes with surgery than PTRAS, but patients with renal salvage as their indication had similar outcomes regardless of revascularization approach; but the interaction between subgroups and interventions was not analyzed. The second study found similar associations between renal resistive index and mortality regardless of revascularization approach.
- Treatment factors: No comparative studies addressed differences in treatment factors as a predictor of outcomes in the comparison of surgery versus PTRAS.

#### Key Question 1 Effects of Intervention on Outcomes

##### Randomized Controlled Trial (Surgery Vs. PTRAS)

Balzer 2009 randomized patients with >70 percent ostial ARAS with HTN to either surgical revascularization (thromboendarterectomy or aortorenal bypass) or angioplasty (with or without stent).23 It was not reported whether translesional pressure gradients were used to define stenosis severity. In 27 patients, thromboendarterectomy was performed in 45 renal arteries and aortorenal bypass grafting in four renal arteries. In the 22 patients who had angioplasty, stents were placed in 22 of 28 renal arteries receiving treatment. Among the patients, 63 percent were male, mean age was 64 years, 18 percent had diabetes, 78 percent hyperlipidemia, and 53 percent coronary artery disease. Notably, 60 percent of patients who had surgical revascularization had >20 pack-years of smoking history, in contrast with 9 percent of those who had PTRAS; analyses were not adjusted for this baseline difference.23 See Appendix C.1, C.2.3, C.3.

This RCT was rated as having low risk of bias for attrition bias and selective reporting (reporting bias). For all other items, including sample representativeness of the entire population, selection bias, performance bias, and detection bias, it was unclear. See Appendix Table D.1.

During a mean 54 months of follow-up, deaths were not statistically significantly different (surgery 26% [7/27] vs. PTRAS 18% [4/22], P=0.80); although the OR of 0.63 (95% CI 0.16, to 2.53) meets this review’s MCID threshold, ignoring statistical significance (Appendix Table C.4.1). RRT or cardiovascular events were not reported. Four years after surgery, SCr levels stabilized after surgery (no data on how SCr was measured), and there was a significant improvement in PTRAS compared to baseline levels (P=0.04). However, there was no difference between groups (Appendix Tables C.4.2, C.4.4, C.4.5). Also at 4 years, there was significant improvement in clinic-measured SBP and DBP in both groups compared to baseline levels, but the difference was not significant between the two groups (P=0.73 for SBP and P=0.49 for DBP) (Appendix Tables C.4.8, C.4.10, C.4.11).23 This RCT also reported ordinal outcomes for BP improvement or cure and found no difference between groups (P=0.72) (Appendix Table C.4.13). Two patients in each group no longer required antihypertensive treatment to control their HTN. There were no periprocedural deaths. After surgery, one patient required PTRAS due to local dissection after endarterectomy. After PTRAS, two patients required surgery due to dislocated stents (Appendix Table C.4.20)

##### Nonrandomized Comparative Studies (Surgery Vs. PTRAS)

Three retrospective NRCSs compared patients who had open surgery and those who had PTRAS.26, 27, 36 None of the studies reported whether translesional pressure gradients were used to define stenosis severity. The studies were of unclear or high risk of bias for selection bias regarding the similarity of the compared groups. Two of the studies were of high risk of bias for incomplete outcome data (attrition bias) (Risk of Bias Description Appendix Table D.2).

In de Donato 2007,^27^ patients were included with ≥80 percent stenosis and HTN requiring at least three medications. Of note, 15 percent of patients had fibromuscular dysplasia. Patients had a mean age of 62 years, and 81 percent were male. The study included 83 patients who had 97 renal arteries treated. It was not reported how many patients received each intervention, but 15 renal arteries had surgical revascularization (11 endarterectomy, 4 aortorenal bypass) and 82 arteries had angioplasty (68, 81% with stent). There were no major periprocedural complications (including death) with either procedure. After 1 year, there was no significant difference in whether patients had HTN improvement or cure (however, this was analyzed by renal artery not patient). No other outcomes were compared between interventions. See Appendix Tables C.1, C.2.3, C.3, C.4.20; Risk of bias, Appendix Table D.2.

In Crutchley 2009, 56 patients had surgical revascularization because they had HTN requiring multiple medications, a history of flash pulmonary edema or malignant HTN, or ischemic nephropathy (not defined) with bilateral disease or a solitary kidney. Among these patients, 17 had bypass, 22 had endarterectomy, and 17 had combined aortic and renal artery procedures. In contrast, 30 patients had angioplasty (26, 87% with stent) for a variety of unreported reasons. Patients’ mean age was 68 years and 46 percent were male. No outcome of interest was explicitly compared between interventions, but the article implied no significant difference in mortality during a mean of 58 months of followup.26 See Appendix Tables C.1, C.2.3, C.3, C.4.1; Risk of bias, Appendix Table D.2.

Patel 2009 retrospectively compared 203 patients who had PTRAS and 47 who had open surgery for ARAS with at least 75 percent stenosis.36 Patients were excluded if renal artery revascularization was conducted in the context of concomitant aortic reconstruction without specific indications for renal artery revascularization, but one-third (15/47) did have concomitant aortic surgery. Among the open surgeries, 21 (47%) were endarterectomies and 26 (53%) were bypasses, of which 17 were aortorenal, 6 were hepatorenal, 2 were splenorenal, and 1 was iliorenal. Few details were reported regarding the PTRAS procedures. Patients’ mean age was 71 years, and 58 percent were men. Fifty-one percent had “chronic renal insufficiency,” 13 percent acute renal failure, and for 49 percent the reason for the intervention was renal salvage. Almost all patients (94%) had HTN, and for 51 percent this was the indication for the intervention. All-cause death (28% at 3 years) and incident RRT (~30% at 3 years) rates were similar between groups (P=0.9 and 0.7, respectively) across 3 years. At 1 year, statistically significantly more patients had improved kidney function after open surgery than PTRAS (52% vs. 24%, P=0.009); this difference persisted beyond 1 year but was not statistically significant (43% vs. 19%, P=0.1). At all time points, nonsignificantly more patients had cure or improvement in BP control (e.g., open 89% vs. PTRAS 74% at 1 year, P=0.2). SCr, SBP, and DBP were all similar at and after 1 year of followup (P>0.6); details about how SCr and BP were measured were not reported. Perioperative complications were significantly more common with open surgery (23%) than with PTRAS (12%, P=0.001), including death (1/47 vs. 1/203).

#### Key Question 2 Association of Patient Factors With Outcomes

Crutchley 2009 found that a renal resistive index ≥0.8 (vs. <0.8) predicted all-cause mortality among patients who had PTRAS (HR 5.7, 95% CI 1.1 to 28) or surgical revascularization (HR 4.8; 95% CI 1.6 to 14).26 However, no statistical analysis of an interaction between renal resistive index and revascularization approach was reported.

Patel 2009 found that patients with HTN as their indication for intervention were significantly more likely to have BP control cure or improvement and kidney function improvement at 1 year after open surgery than PTRAS patients (100% vs. 73%, P=0.04; 50% vs. 8%, P=0.01, respectively), but no significant differences by intervention if renal salvage was their indication.36 However, the differences in effects between indication subgroups and revascularization approach were not statistically analyzed.

#### Key Question 3 Association of Treatment Factors With Outcomes

No comparative study addressed this question.

## Single-Group Studies

Eligibility criteria for single-group studies varied based on the expected volume of evidence for each intervention. For PTRAS, we include prospective studies with at least 100 patients. For medical therapy, we include prospective studies with at least 10 patients. For surgery, we include both prospective studies with at least 10 patients and retrospective studies with at least 100 patients. These studies include both true single-group studies (in which the whole study comprised a cohort of patients receiving a single intervention), comparisons of different cohorts of patients all receiving the same overarching intervention (PTRAS, medical therapy alone, or surgery), and relevant cohorts from RCTs and NRCSs. Note that not all cohorts from the comparative studies are included here. For example, the single groups from a retrospective comparison of PTRAS versus medical therapy do not meet criteria for analysis of single-group studies.

### Angioplasty With Stenting

#### Key Points

- 67 cohorts of patients (in 63 prospective studies) reported outcomes after PTRAS. The studies were highly heterogeneous in both their included patients, indications for PTRAS, and specific PTRAS techniques. Many of the studies were deemed to be at high risk of bias for failure to adjust for different lengths of followup, attrition bias, and selective outcome reporting.
- Mortality: In 31 studies, mortality ranged from 0 to 53 percent after 6 months to 5 years of followup (one study reported at 15 years). Other than a general trend toward increased death with longer-term followup, there was no clear explanation across studies for the difference in mortality.
- RRT: In seven studies, incident RRT occurred in 2.3 to 23 percent of patients between 1.25 and 5 years, but with no clear explanation of the heterogeneity across studies, including length of followup.
- Cardiovascular outcomes: In 12 studies, various cardiovascular outcomes were reported to occur, but with highly heterogeneous percentages of patients (including CHF 0–83%, MI 1–82%, stroke 1–19%).
- Kidney function: In four studies 2 to 82 percent of patients had episodes of acute kidney injury. In 21 studies, kidney function improved in 12 to 82 percent and worsened in 4 to 37 percent of patients. 21 studies had a median change in GFR of 0 mL/min (range −9 to 10 mL/mL). There was no clear explanation across studies for the wide heterogeneity in change in kidney function.
- BP control: In two studies 0 and 4 percent of patients had new-onset HTN. In 19 studies, BP improved in 4 to 69 percent and stabilized or worsened in 7 to 67 percent of patients. In 36 studies, median changes in SBP were −17 mmHg (range −51 to 28) and in DBP were −6 mmHg (range −30 to 5). In 30 studies, the median change in number of antihypertensive medications was −0.3 (−1.4 to 1.2). There was no clear explanation across studies for the wide heterogeneity in change in BP control.
- Adverse events: In 19 studies, adverse events included post-operative death, RRT, and acute renal failure; and severe bleeding, dissection, unplanned surgery, and thrombosis.
- Patient factors: 20 studies reported on analyses of patient factors as predictors of outcomes after PTRAS. Overall, the studies were heterogeneous in their analyses and findings. Among predictors analyzed by at least three studies, those with some indication of an association with favorable kidney and BP outcomes included worse pre-PTRAS kidney function (in 6 of 13 studies), bilateral stenosis (in 3 of 9 studies), higher pre-PTRAS BP (in 3 of 5 studies), higher grade of stenosis (in 2 of 5 studies). Absence of cardiovascular disease, female sex, and younger age were found to be significantly associated with better outcomes in only one of four or five studies. However, in contradistinction to their associations with intermediate outcomes, death, RRT, and composite clinical outcomes were associated with worse pre-PTRAS kidney function (in 3 of 5 studies), bilateral stenosis (in 2 of 5 studies), cardiovascular disease (in 2 of 4 studies), and CHF (in 3 of 5 studies). In addition, smoking and diabetes were associated with clinical events in only one of either three or four studies.
- Treatment factors: Three studies addressed differences in treatment factors as predictors of outcomes. No differences in outcomes were found with or without gold-coated stents, sirolimus eluting stents, embolic protection devices, or intraluminal brachytherapy.

#### Key Question 1 Effects of Intervention on Outcomes

In 63 articles,9, 19, 20, 23–25, 27, 29, 30, 32, 33, 35, 39–89 we identified 67 cohorts of patients who were treated with PTRAS (a total of 8286 patients) in prospective studies. Among the studies, 48 cohorts41–45, 47–66, 70–75, 77–82, 84–88 assessed the effectiveness of PTRAS on outcomes in single cohorts of patients (or compared different cohorts of patients receiving PTRAS), and 19 cohorts9, 19, 20, 23–25, 27, 29, 30, 32, 33, 35, 46, 67–69, 76, 83 were from studies comparing PTRAS to medical therapy or surgery.

Analyzed studies typically included more males than females (the median study population was 57% male [range 36–83%]). Three-quarters of included studies included patients with a mean age of 70 years and above (range 59–77 years). Two studies reported a mean HTN duration of 13.5 years. 61, 87 See Appendix Table C.3.

The most common reason for angioplasty was HTN or renal insufficiency without prior treatment (42 studies).19, 20, 24, 25, 27, 29, 30, 35, 42, 44–49, 52, 54, 56–58, 64–68, 70–73, 76–85, 87 Uncontrolled HTN while on two or more medications was another common indication for angioplasty (9 studies)19, 42, 49, 64, 72, 79, 84, 85, 89.^53, 64, 70, 73, 77^ Seventeen of the studies used translesional pressure gradient measurements to determine eligibility for PTRAS, mostly using a threshold of 20 mmHg (10 studies19, 39, 42, 47, 53, 55, 57, 78, 79, 89); one study used a threshold of 15 mmHg,75 two studies used 30 mmHg,45, 51 one 40 mmHg,41 and three did not report their threshold.58, 72, 85 Five studies included only patients with cardiovascular disease or flash pulmonary edema.53, 64, 70, 73, 77 Across studies, the median average BP was 162/83 mmHg (range 110–196/73–105 mmHg); the median average GFR was 52 mL/min (range 31.5–67.2 mL/min), and median average SCr was 1.5 mg/dL (range 1.1–3 mg/dL) before PTRAS. See Appendix Table C.1.

Forty-five included studies reported on patients with a history or current cardiovascular disease. 9, 19, 20, 23, 24, 30, 32, 33, 41, 43, 45–49, 52–58, 61, 64, 66–68, 70–73, 75–81, 85–88 These 45 studies reported medians of 63 percent of patients who had coronary artery disease, 32 percent myocardial infarction, and 32 percent coronary revascularization. Medians of 22.5 percent of patients had CHF, and 29 percent left ventricular hypertrophy. Medians of 7 percent of patients had an abdominal aortic aneurysm, 39 percent cerebrovascular disease, and 16.5 percent a history of stroke. Lastly, a median of 44 percent of patients had a history of peripheral artery disease. See Appendix Table C.3.

The definitions of RAS varied across studies. Two studies included patients with over 80 percent stenosis,19, 27 23 over 70 percent stenosis,19, 23, 29, 32, 33, 41, 43, 45, 46, 51, 53, 56, 59–61, 63, 65, 66, 70, 71, 73, 76–81, 85–87 10 over 60 percent,19, 30, 41, 46, 55, 75, 80, 85, 87, 89 and 21 over 50 percent. 9, 24, 30, 32, 42–46, 50, 52, 54, 58, 67–69, 72, 74, 78, 81, 85 The minimum percent stenosis was not stated in 9 studies.20, 25, 35, 48, 49, 57, 62, 64, 79

In 43 studies that reported data, bilateral stenting was present among a median of 28 (range 0–100%) percent of patients.19, 23–25, 29, 33, 41–46, 51–55, 57, 59–62, 64, 66, 70–80, 82–84, 86–88

Palmaz stents were used in 25 studies,23, 24, 41–44, 46–53, 55, 57–60, 63, 67, 78, 79, 81, 88 20 studies (21 cohorts) used non-Palmaz stents or did not report stent brand information,19, 25, 30, 39, 54, 56, 62, 66, 68, 70, 71, 73–76, 83, 85–87, 89 and 18 studies (19 cohorts) did not report data on the type of stent used.9, 20, 27, 29, 32, 33, 35, 39, 45, 61, 64, 65, 69, 72, 77, 80, 82, 84 Twenty-five studies (26 cohorts) reported utilizing a distal protection device.19, 20, 24, 25, 30, 42, 44, 48, 49, 54, 57, 58, 61–63, 67, 68, 70, 74–76, 85–88 See Appendix Tables C.2.1, C.2.3 C.2.4

In general, across risk of bias questions, between 10 and 43 percent of studies were considered to be of high risk of bias, and between 57 and 90 percent were considered low risk of bias (Appendix Figure D.3). Twenty-five studies were judged high risk of bias for failing to adjust for different lengths of followup, 21 high risk of bias for incomplete outcome data (attrition bias), and 14 for selective outcome reporting. The samples were considered to be representative of the entire population from which they were recruited in 48 studies.

##### Mortality (Study Duration 6 Months or Greater)

Data on mortality long-term mortality after PTRAS was reported in 31 studies (Figure 7).9, 19, 20, 24, 39, 41–43, 45, 47–50, 52, 55–57, 64, 67, 70–76, 78, 82, 83, 86, 88 The mean followup time for reporting mortality was 2.4 years, with the longest followup at 15 years. The mortality rates ranged from 0 to 53 percent, with a median of 10 percent. Most studies reported mortality between 0 and 31 percent, but there are four included studies that reported mortality above 40 percent. These four studies reported that the intervention did not significantly reduce the risk of kidney failure and cardiac events. At 1 year, in about a third of the studies (10 of 31), 2.6 percent of patients had died (range 0% to 23%); at 2 years, in most studies (7 of 31), 8.1 percent of patients had died (range 0.5% to 44%). Other than a general trend toward increased death with longer-term followup, there was no clear explanation across studies for the difference in mortality. The most common cause of mortality reported was cardiovascular-related deaths (12 studies).19, 20, 24, 44, 53, 54, 60, 64, 73, 74, 76, 80 Renal- and stroke-related deaths were reported in four19, 20, 64, 74 and two19, 24 studies, respectively. See Appendix Table C.4.1.

Figure 7 Death after PTRAS, percent of patients

Point estimates and 95% confidence intervals from individual studies. Lines connecting points indicate data coming from the same study (or cohort) at different time points. PTRAS= percutaneous transluminal renal angioplasty with stent.

Figure 7: depicts a longitudinal scatter plot of death after PTRAS. On the x-axis we display years of followup; followup times range from roughly 0.5 to 16 years. On the y-axis we display the death as a percent of the entire study sample; death percentage ranges from approximately 0 to 55 percent. Most studies only report on one time point after PTRAS; studies that report results for multiple followup points tend to exhibit 5 to 10 percent increase in death per year.

##### Renal Replacement Therapy

Seven studies9, 19, 20, 48, 76, 82, 83 reported that RRT occurred in 2.3 to 23 percent of patients between 1.25 and 5 years (Figure 8). In three of the studies, RRT occurred in at least 15 percent of patients. Additionally, three studies reported RRT occurred in less than 5 percent of patients. There was no clear explanation across studies for the wide heterogeneity in RRT occurrence, including length of followup. See Appendix Table C.4.6.

Figure 8 Renal replacement therapy after PTRAS, percent of patients

Point estimates and 95% confidence intervals from individual studies. Lines connecting points indicate data coming from the same study (or cohort) at different time points. PTRAS= percutaneous transluminal renal angioplasty with stent, RRT = renal replacement therapy.

Figure 8: depicts a longitudinal scatter plot of renal replacement therapy after PTRAS. On the x-axis we display years of followup; followup times range from roughly 1 to 5 years. On the y-axis we display renal replacement therapy as a percent of the entire study sample; renal replacement therapy percentage ranges from approximately 1 to 22 percent. All but one study reports on one time point after PTRAS. The one study that reports results for multiple followup points exhibits a 0 percent increase in renal replacement therapy per year.

##### Cardiovascular Outcomes

Twelve studies9, 19, 20, 24, 39, 48, 55, 65, 67, 76, 78, 80 reported cardiovascular event rates, indicating that patients remain at increased risk of cardiovascular disease after PTRAS. CHF was reported in four studies (0 to 83%). Other cardiovascular events included angina in 7.5 percent (one study)20, MI in 1 to 82 percent (eight studies)19, 20, 48, 55, 67, 76, 78, 80, stroke in 1.2 to 19 percent (six studies),19, 20, 39, 55, 76, 80 coronary revascularization in 3.8 to 3.9 percent (two studies),20, 48 and composite cardiovascular events in 0 to 37 percent (four studies).9, 20, 65, 80 See Appendix Tables C.4.17 and C.4.18.

##### Kidney Function

The studies were highly heterogeneous regarding which kidney function measures were analyzed, in particular for definitions of ordinal (categorical) outcomes such as kidney function improvement. The definitions used by studies are in the summary tables in Appendix Table C.4. Among 20 studies that reported CKD at baseline, some included only patients without CKD, some only those with CKD. A median of 47.5 percent had CKD.

Four studies20, 80, 86, 88 reported that between 1.9 and 82 percent of patients had episodes of acute kidney injury at 1 to 3 years. Twenty-two studies reported ordinal outcomes for kidney function improvement (Figure 9).19, 20, 30, 43, 46, 48, 53, 54, 58, 60–62, 65, 67, 71, 74, 75, 82–84, 86, 88 Kidney function improved in 12 to 82 percent of patients (14 studies),20, 30, 46, 48, 54, 61, 62, 65, 71, 74, 83, 86, 88; did not change in 3.2 to 72 percent (11 studies),20, 30, 46, 48, 54, 61, 62, 71, 83, 88 stabilized in 33 to 59 percent (two studies),62, 74 and worsened in 3.8 to 37 percent (15 studies).20, 30, 40, 46, 48, 54, 58, 61, 65, 71, 74, 83, 86, 88 Twenty-one studies reported a median 0 mL/min change in GFR (range −9 to 10 mL/mL); eight estimated GFR with the MDRD equation, five used Cockcroft-Gault, and the rest did not report how kidney function was estimated (Figure 10).20, 30, 32, 51, 60, 61, 63, 64, 69–71, 74, 76, 78, 80, 82, 85–87, 89 Twenty-seven studies reported a median −0.1 mg/dL change in SCr (range −0.8 to 1.7 mg/dL).20, 25, 42, 45–47, 49, 51, 52, 54, 57, 58, 61–65, 67, 69–72, 76, 77, 81, 84, 86 There was no clear explanation across studies for the wide heterogeneity in change in kidney function. For details, see Appendix Tables C.4.2, C.4.6, and C.4.7.

Figure 9 Kidney function improvement after PTRAS, percent of patients

Point estimates and 95% confidence intervals from individual studies. Lines connecting points indicate data coming from the same study (or cohort) at different time points. PTRAS= percutaneous transluminal renal angioplasty with stent.

Figure 9: depicts a longitudinal scatter plot of kidney function improvement after PTRAS. On the x-axis we display years of followup; followup times range from roughly 0.5 to 4 years. On the y-axis we display the kidney function improvement as a percent of the entire study sample; kidney function improvement percentage ranges from approximately 10 to 82 percent. All but two studies report on one time point after PTRAS. The two studies that report results for multiple followup points, exhibit 10 percent decrease and a 5 percent increase in kidney function improvement per year.

Figure 10 GFR change (in mL/min) after PTRAS

Point estimates and 95% confidence intervals from individual studies. Lines connecting points indicate data coming from the same study (or cohort) at different time points. GFR = glomerular filtration rate, PTRAS= percutaneous transluminal renal angioplasty with stent.

Figure 10: depicts a longitudinal scatter plot of GFR change after PTRAS. On the x-axis we display years of followup; followup times range from roughly 0.5 to 6.5 years. On the y-axis we display the GFR change as a difference in mL/min; GFR change ranges from approximately −5 to 10 unit change. Studies that report results for multiple followup points tend to exhibit 5 to 10 unit increase or decrease in GFR change per year after PTRAS.

##### Blood Pressure Control

The studies were highly heterogeneous regarding which BP measures were analyzed, in particular for definitions of ordinal (categorical) outcomes such as BP improvement. The definitions used by studies are in the summary tables in Appendix Table C.4.

New-onset HTN was reported in 0 to 3.9 percent (two studies).24, 55 Ordinal outcomes for BP improvement were reported in 19 studies (Figure 11). In these studies, BP improved in 4.2 to 69 percent (15 studies),41, 42, 45, 46, 58, 65, 67, 71, 72, 74, 75, 77, 80 did not change in 9.1 to 54 percent (10 studies),41, 42, 45, 65, 67, 71, 77, 80 and stabilized or worsened in 7.4 to 67 percent (5 studies).40, 41, 46, 58, 80

Figure 11 Blood pressure improvement after PTRAS, percent of patients

Point estimates and 95% confidence intervals from individual studies. Lines connecting points indicate data coming from the same study (or cohort) at different time points. PTRAS= percutaneous transluminal renal angioplasty with stent.

Figure 11: depicts a longitudinal scatter plot of blood pressure improvement after PTRAS. On the x-axis we display years of followup; followup times range from roughly 0.25 to 4 years. On the y-axis we display the blood pressure improvement as a percent of the entire study sample; blood pressure improvement percentage ranges from approximately 5 to 80 percent. Most studies only report on one time point after PTRAS; studies that report results for multiple followup points tend to exhibit 5 percent decrease or a 10 percent increase in blood pressure improvement per year.

Changes in BP were reported in 36 studies19, 20, 25, 30, 32, 41, 42, 44–47, 49–52, 56–58, 60, 61, 63–65, 67, 70–72, 74, 76–78, 80, 81, 85–87, 89 (Figure 12); BP was measured in the clinic in 15 studies, by 24 hour ambulatory measurements in 4 studies, by self-measured BP in one study, and extracted from the medical record in 2 studies; other studies did not explicitly define BP measurement. Of these, 33 studies reported a −17 mmHg median change in SBP (range −51 to 28 mmHg),19, 20, 30, 32, 41, 44–46, 49–52, 57, 58, 60, 61, 63–65, 67, 70–72, 74, 76–78, 80, 81, 85–87, 89 31 studies reported a −6 mmHg median change in DBP (range −30 to 5 mmHg),20, 30, 32, 41, 44–46, 49–52, 57, 58, 60, 61, 63–65, 67, 70–72, 74, 77, 78, 80, 81, 85–87, 89 and five studies reported a −13.7 mmHg median change in mean arterial pressure (range −29 to 6 mmHg).42, 45, 47, 56, 78 See Appendix Tables C.4.8, C.4.10, and C.4.11.

Figure 12 Blood pressure change (in mmHg) after PTRAS

Point estimates and 95% confidence intervals from individual studies. Blue circles = systolic blood pressure; red triangles = diastolic blood pressure; green squares = mean arterial pressure. Lines connecting points indicate data coming from the same study (or cohort) at different time points. PTRAS= percutaneous transluminal renal angioplasty with stent.

Figure 12: depicts a longitudinal scatter plot of blood pressure change after PTRAS. On the x-axis we display years of followup; followup times range from roughly 0.25 to 6.25 years. On the y-axis we display the blood pressure change as a difference in mmHg; blood pressure change percentage ranges from approximately −50 to 30 unit change. Most studies tend to exhibit 5 to 10 unit decrease in blood pressure change per year after PTRAS.

Changes in number of antihypertensive medications were reported in 30 studies (Figure 13). 19, 41, 43, 44, 46–50, 53–57, 60, 61, 63–65, 67, 71, 72, 75–80, 86, 87 These studies reported a median −0.3 change in the number of antihypertensive medications (1.4 decrease to 1.2 increase). For details, see Appendix Tables C.4.8, C.4.14.

Figure 13 Change in number of antihypertensive medications after PTRAS

Point estimates and 95% confidence intervals from individual studies. Lines connecting points indicate data coming from the same study (or cohort) at different time points. PTRAS= percutaneous transluminal renal angioplasty with stent.

Figure 13: depicts a longitudinal scatter plot of number of antihypertensives change after PTRAS. On the x-axis we display years of followup; followup times range from roughly 0.5 to 6.25 years. On the y-axis we display the number of antihypertensives; the number of antihypertensives change ranges from approximately −1.5 to 1 unit change. Most studies only report on one time point after PTRAS; studies that report results for multiple followup points tend to exhibit no change or 1 unit increase in the number of antihypertensives change per year.

For all BP outcomes, there were no clear explanations for the wide heterogeneity across studies in outcomes after stent.

##### Adverse Events (Including 30-Day Mortality)

A total of 19 studies reported adverse events immediately following PTRAS.20, 42–46, 48, 51, 52, 54, 58, 59, 61, 62, 67, 72, 75, 76, 80 The 30-day mortality was reported in 9 studies and ranged from 0 to 15 percent.39, 41, 45, 50, 71–73, 86, 88 Other reported adverse events included RRT 1.5 to 3.1 percent (two studies),48, 82 acute renal failure 2.3 to 11 percent (two studies),20, 75 severe bleeding 1.6 to 31 percent (nine studies),41, 43, 51, 59, 64, 68, 72, 75, 80 dissection 2.2 to 3.9 percent (two studies),65, 75 unplanned surgery 0 to 6 percent (one study),48 and thrombosis 0 to 12 percent (three studies).20, 46, 75 See Appendix Tables C.4.19 and C.4.20.

#### Key Question 2 Association of Patient Factors With Outcomes

Twenty studies of PTRAS22, 26, 31, 47, 50, 51, 55, 56, 60–62, 72, 74–76, 78, 80, 82–84 reported analyses of patient-level (or disease characteristic) factors associated with outcomes of interest (Tables 1 and 2). An additional study pooled data from three eligible studies, 57, 70, 85 together with two ineligible studies.90

Table 1 Independent predictors of kidney and blood pressure outcomes after angioplasty with stent

Outcome Study | Mean F/up (Metric) | CKD | Pre-Stent ΔGFR | Bilat | Stenosis Grade | CAD | Sex | BP | Age | Misc | Other NS
RRT
Kane 2010^**^ | 5 y (RR) | | | | | | | | | CHF: 2.3 (1.1, 5.0)
Mannarino 2012 | 2.75 y (%) | | | NS^*^
Valluri 2012 | 2.9 y (%) | | Fast vs. Slow: NS^*^ | NS^*^
Kidney Function
Arthurs 2007 | 1.25 y (SCr slope) | SCr ≥1.5: −0.03/mo SCr <1.5: 0.03/mo P<0.05^*^ | | NS^*^ | | | | | | | RI >0.8^*^
Holden 2006 | 1.3 y (Imp) | Stage NS^*^
Leesar 2009 | 1 y (SCr) | | | | | | | | | | HSG^*^
Mannarino 2012 | 2.75 y (GFR/mo) | | Fast: 0.01 Slow: −0.14 P=0.04^*^ | Bilat: 0.02 Unilat: −0.16 P=0.02^*^ | | | | | | | Proteinuria^*^
Mannarino 2012 | 2.75 y (GFR imp, OR) | | 16 (1.5, 166) | NS
Ramos 2003 | 1 y (GFR) | GFR<50: 20.7 GFR≥50: −4.8 P sig, implied^*^
Rivolta 2005 | 1.67 y (1/SCr slope) | SCr NS | | | | | | | | | Kidney diameter
Sapoval 2010 | 1 y (GFR imp, %) | CKD 1/2: 3.5% CKD 3: 23% CKD 4: 50% P nd^*^
Sapoval 2010 | 1 y (GFR) | CKD 1/2: −25 CKD 3: 1 CKD 4: 13 CKD 5: 24 P nd^*^
Trani 2013 | 6 mo (SCr imp, OR) | SCr, per quartile 2.5 (1.3, 4.7) | | NS | NS^†^ | | NS | | NS | CRP per quartile 0.39 (0.19, 0.82) | LVEF, Statins, ACEi/ARB, DM
Tsao 2005 | 6 mo (GFR) | NS^*^ | | Bilat: 5 Unilat: −10 P<0.001^*^
Tsao 2005 | 6 mo (SCr imp, %) | SCr >1.5: 24% SCr ≤1.5: 0% P nd^*^ | | | NS (≥90%)^*^ | | | | | | HTN duration^*^
Valluri 2012 | 2.9 y (GFR slope imp) | | | NS^*^ | | | NS^*^
Zeller 2004 | 2.67 y (SCr) | SCr (>3.0 vs. <1.2 mg/dL): −0.9 (−1.3, −0.6) P<0.001 SCr (1.21–3.0 vs <1.2 mg/dL): −0.2 (−0.3, 0) P<0.009^*,‡^ | | NS^*,‡^ | | | | | | | RI^*,‡^, DM^*,‡^
Zeller 2004 | 2.67 y (SCr imp, OR) | SCr^†^ 2.57 (1.55, 4.25) | | 2.04 (1.01, 4.21) | 1.05 (1.04, 1.09)^†^ | 3v: 0.39 (0.17, 0.91)
Blood Pressure
Beck 2010 | 1.5 y (no imp, OR) | GFR<40: 1.6 (1.0, 2.9) | | NS | | NS | F: 1.3 (1.0, 2.1) | SBP>180 NS DBP>90 NS | >70 NS | | AAA, DM, COPD, Dyslipidemia, Smoking
Leesar 2009 | 1 y (imp, OR) | | | | | | | NS | | HSG ≥21 mmHg: 1.32 (1.05, 1.65) | Other renal artery measures^§^
Ramos 2003 | 1 y (mmHg) | GFR<50: −10/−4 GFR ≥50: −21/−10 P nd^*^
Rocha-Singh 1999 | 13 mo (response^#^, OR) | SCr>1.4 NS | | 4.6, P=0.009 | | NS | NS | MAP >110: 2.9, P=0.003 | NS | | DM, Ostial lesion, Solitary kidney
Rzeznik 2011 | 1 y (imp, RR) | NS | | NS | 1.28 (1.08, 1.51)^†^ | NS | | DBP: 1.74 (1.47, 2.06)^†^ SBP NS | | | Echocardiography measures
Staub 2010 | 6 mo (imp, OR) | NS | | | | | NS | MAP per mmHg 1.05 (1.01, 1.20) | Per y, 0.95 (0.89, 0.99) | BNP >50: 4.0 (1.2, 13.2) | RI
Tsao 2005 | 6 mo (mmHg) | NS
Zeller 2004 | 2.67 y (imp, OR) | | | NS | | | | | | No. Rx^†^ 1.81 (1.38, 2.36) | DM, RI
Weinberg 2014^††^ | 9 mo (imp, OR) | SCr>1.5 NS | | | | NS | NS | SBP per 10 mmHg: 1.76 (1.53, 2.03) DBP per 10 mmHg: NS | NS | | No. Rx, DM, Smoking
BP or SCr^¶^
Gill-Leertouwer, 2002 | 1 y (imp, OR) | GFR per mL/min 0.92 (0.85, 0.998) | | | NS | | | | | | Other renal artery measures\|\|
No. Rx
Leesar 2009 | 1 y (mean number) | | | | | | | | | HSG ≥21: 2.3 HSG <21: 3.4 P<0.01^*^
Tsao 2005 | 6 mo (mean number) | NS^*^

* Univariate

† Categorization not defined; implied that worse severity associated with improvement.

‡ Estimated based on reported data.

§ Intravascular ultrasound measures (mean lumen area, area stenosis, minimum lumen diameter, plaque plus media area), pressure guidewire measures (fractional flow reserve, hyperemic mean gradient, resting systolic gradient, renal angiography measures (minimum lumen diameter, diameter stenosis).

# DBP ≤90 mmHg with no change in medications or decrease in ≥1 medications; or DBP 90–100 mmHg and decrease in MAP ≥5 mmHg and no change in medications.

¶ DBP decrease ≥10 mmHg or SCr decrease ≥20% depending on indication

|| Intravascular ultrasound measures, renal scintigraphy measure.

** Kane 2010 was a retrospective comparative study of angioplasty with stent to medical therapy.31 Therefore, this studies did not meet eligibility criteria for Key Question 1 for PTRAS cohorts and was not included there.

†† Weinberg 2014.^90^ Pooled meta-analysis of Rocha Singh 2005,^57^ Rocha Singh 2008,^70^ Jaff 2012,^85^ a study that did not meet eligibility criteria because it included patients with ostial restenosis requiring repeat angioplasty,91 and an unpublished study whose data are not available.

3v = 3 vessel coronary artery disease, AAA = abdominal aortic aneurysm, ACEi/ARB = angiotensin converting enzyme inhibitor or angiotensin receptor blockers, Bilat = bilateral stenosis, BNP = brain natriuretic protein (in pg/mL), BP = blood pressure, CAD = coronary artery disease, CHF = congestive heart failure, CKD = chronic kidney disease, COPD = chronic obstructive pulmonary disease, CRP = C reactive protein, DBP = diastolic blood pressure (in mmHg), DM = diabetes mellitus, F = female, F/up = followup, Fast = fast progressor (more than −0.25 mL/mo preprocedure), GFR = glomerular filtration rate (unit used in regression not reported), HSG = Pressure guidewire-measured hyperemic systolic gradient, HTN = hypertension, imp = improvement, LVEF = left ventricular ejection fraction, MAP = mean arterial pressure, Misc = miscellaneous, nd = no data, No. Rx = number of antihypertensive medications, NS = no significant association, OR = odds ratio, Other NS = nonsignificant predictors not otherwise listed, RI = resistance index, RR = risk ratio, SBP = systolic blood pressure, SCr = serum creatinine (in mg/dL), sig = significant, Slow = slow progressor (less than −0.25 mL/mo preprocedure), Unilat = unilateral stenosis, ΔGFR = rapid kidney function decline (>80th percentile preprocedure) or fast progressor (more than −0.25 mL/mo preprocedure).

Table 2 Independent predictors of clinical event outcomes after angioplasty with stent

Outcome Study | Mean F/up (Metric) | CKD | BP | Bilat | CVD | CHF | Age | DM | Smoking | Misc | Other NS
Death
Crutchley 2009^*^ | 4.8 y (HR) | | | | | | | | | RI>0.8: 6.7^†^ (2.6, 17)
Kane 2010^**^ | 5 y (RR) | SCr, per mg/dL: 2.7 (1.1, 6.6) | | | CAD NS | 3.4 (2.0, 5.7) | | NS | | | HTN
Kennedy 2003 | 1.75 y (%) | SCr (higher) P=0.001 | | 32% v 25% P<0.01 | MI 36% v 24% P<0.05^‡^ CAD NS | 56% v 15% P<0.001^‡^ | | NS | NS | | Sex, Race
Mannarino 2012 | 2.75 y (%) | | | NS^‡^
Valluri 2012 | 2.9 y (%) | Rapid decline NS^‡^ | | NS^‡^
Death, CV or Renal
Kennedy 2003 | 1.75 y (%) | SCr (higher) P=0.001 | | | CAD NS
Composite
CV death, RRT or SCr increase >30%, MI, Stroke, CHF, Uncontrolled HTN
Kennedy 2003 | 1.75 y (%) | | | 48% v 30% P<0.01^‡^ | CAD NS^‡^ MI NS^‡^ | 53% v 30% P<0.01^‡^ | | 51% v 31% P<0.01^‡^ | NS | | Sex, Race
CV death, MI, Stroke, Revascularization
Rzeznik 2011 | 1 y (RR) | GFR NS | | NS | CAD severity^§^ 1.27 (1.04, 1.56) | LVM NS | | | 1.29 (1.05, 1.57) | | BP, Stenosis grade
CV death, RRT, MI, Stroke
Trani 2010 | 2 y (OR) | SCr per mg/dL 2.20 (1.11, 4.38) | | 7.32 (1.53, 35.1) | PVD NS | LVEF NS | NS | NS | | | Sex, Stenosis grade
Myocardial Infarction
Kennedy 2003 | 1.75 y (%) | SCr (higher) P=0.001 | | | CAD NS
Congestive Heart Failure
Kennedy 2003 | 1.75 y (%) | SCr (higher) P=0.001 | | | CAD NS

* Crutchley 2004 was a retrospective comparative study of surgery vs. angioplasty with stent with <100 participants in the surgical arm.26 Therefore, this studies did not meet eligibility criteria for Key Question 1 for surgical cohorts and was not included there.

† HR for combined surgery and angioplasty with stent groups, described in text and graphically as similar results for both intervention groups.

‡ Univariate analysis.

§ Categorization not defined

** Kane 2010 was a retrospective comparative study of angioplasty with stent to medical therapy.31 Therefore, this studies did not meet eligibility criteria for Key Question 1 for PTRAS cohorts and was not included there.

Bilat = bilateral stenosis, BP = blood pressure, CAD = coronary artery disease, CHF = congestive heart failure, CKD = chronic kidney disease, CV = cardiovascular, CVD = cardiovascular diseases, DM = diabetes mellitus, F/up = followup, GFR = glomerular filtration rate (in mL/min), HR = hazard ratio, HTN = hypertension, LVEF = left ventricular ejection fraction, LVM = left ventricle mass, MI = myocardial infarction, Misc = miscellaneous, NS = nonsignificant association, OR = odds ratio, Other NS = nonsignificant predictors not otherwise listed, PVD = peripheral vascular disease, RI = resistance index, RR = risk ratio, RRT = renal replacement therapy, SCr = serum creatinine (in mg/dL).

Three studies evaluated subgroups of patients as predictors of requiring RRT (Table 1). Kane 2010 found that patients with CHF were significantly more likely to develop RRT (risk ratio [RR] 2.3; 95% CI 1.1 to 5.0), adjusted for sex, age, and SCr.31 Both Mannarino 2012 and Valluri 2012 found no difference between patients with bilateral or unilateral stenosis.82, 83 Valluri 2012 also found no difference between those patients with relatively rapid kidney function decline prior to PTRAS compared to other patients.82

Eleven studies evaluated a variety of potential predictors for long-term kidney function (Table 1). Six of eight studies found that patients with worse pre-PTRAS kidney function were more likely to have improved kidney function after PTRAS than other patients; the other two found no significant association. Three studies each found that patients with bilateral stenosis either had greater improvement than those with unilateral stenosis or there was no significant association. No other factors potentially predicting kidney function were evaluated by more than three studies.

Eight studies evaluated predictors of long-term BP outcomes (Table 1); an additional pooled meta-analysis of three eligible studies (and two ineligible studies) also evaluated predictors of BP response.90 Four of six studies found that patients with higher pre-PTRAS BP were more likely to have BP improvement than other patients; the other two studies found no association. Five found no association between pre-PTRAS kidney function and BP, but two found that patients with worse kidney function (GFR <40 or 50 mL/min) were significantly less likely to have BP improvement. Only one of four studies found that patients with bilateral disease were more likely to have BP improvement; the other three found no association. Four studies found no association with diabetes. No other factors potentially predicting kidney function were evaluated by more than three studies.

Five studies evaluated predictors of all-cause death (Table 2). Three of four studies found that patients with worse pre-PTRAS kidney function were significantly more likely to die; the fourth found no association. Three found no association with a history of coronary artery disease, but one of these did find that significantly more patients who had had a myocardial infarction died. This study also found that patients with bilateral stenosis were more likely to die, but two other studies found no association.

Three studies evaluated composite outcomes that included all-cause or cardiovascular death, various cardiovascular events, and in some instances RRT, acute kidney injury, CHF, uncontrolled HTN, or revascularization (Table 2). All three tested histories of various cardiovascular diseases. Rzeznik 2011 found that coronary artery disease severity (which was not defined) increased the risk of the composite outcome. However, Kennedy 2003 and Trani 2010 found that coronary artery disease, myocardial infarction, and peripheral vascular disease were not associated with outcomes. All four also evaluated pre-PTRAS left ventricular function; two studies found increase risk of outcomes with a history of CHF, but two found no associations with left ventricular mass or ejection fraction.

#### Key Question 3 Association of Treatment Factors With Outcomes

In a subgroup analysis of a retrospective study, Beck 2010 found that neither use of gold-coated stents or embolic protection were associated with BP at 1.5 years.75

In an observational comparative study, Zahringer 2007 found no differences at 2 years in BP, HTN cure, the number of antihypertensive medications, SCr, or kidney function worsening between patients who had angioplasty with either sirolimus eluting or bare stents.67

In a RCT, Lekston 2008 found no difference in 10 month SCr between those who received or did not receive intraluminal brachytherapy during stenting.69

### Medical Therapy Only

#### Key Points

- 20 cohorts of patients (in 17 prospective studies) reported outcomes in patients receiving medical therapy alone. The studies were highly heterogeneous in both their included patients and specific medical treatments (both within and across studies). Many of the studies were deemed to be at high risk of bias for failure to adjust for different lengths of followup and attrition bias.
- Mortality: In 10 studies, mortality ranged from 9 to 56 percent after 2 to 9 years of followup. Other than a general trend toward increased death with longer-term followup, there was no clear explanation across studies for the difference in mortality.
- RRT: In seven studies, incident RRT occurred in 2 to 18 percent of patients between 3 and 5 years, but with no clear explanation of the heterogeneity across studies, including length of followup.
- Cardiovascular outcomes: In nine studies, various cardiovascular outcomes were reported to occur, but with highly heterogeneous percentages of patients (including CHF 1.4–13%, MI 2.5–83%, stroke 2.5–23%).
- Kidney function: 10 studies reported on kidney function outcomes. Kidney function improvement occurred in 0 to 26 percent of patients and deteriorated in 19 to 38 percent of patients (4 studies). In three studies, GFR changed by −0.7 to 8 mL/min between 1 and 6 years of followup and SCr changed by −0.1 and 1.3 mg/dL at between 1 and 5 years of followup
  In four studies 2 to 82 percent of patients had episodes of acute kidney injury. In 21 studies, kidney function improved in 12 to 82 percent and worsened in 4 to 37 percent of patients. 21 studies had a median change in GFR of 0 mL/min (range −9 to 10 mL/mL). There was no clear explanation across studies for the wide heterogeneity in change in kidney function.
- BP control: 12 studies reported on BP outcomes. In one study 4 percent of patients became newly hypertensive and none had a hypertensive crisis. In 10 studies, SBP changed by −6 to −22 mmHg and DBP by −1 to −13 mmHg. In 2 studies, the number of antihypertensive medications was unchanged after 1.75 years of followup and increased by 1.4 medications after 3.6 years.
- ACEi/ARB use: Two studies found increases in the percentage of patients on ACEi or ARB after 1 year from 79 to 83 percent 1 year in one study and from 38 to 43 percent in the other.
- Adverse events: No study reported on adverse events related to medication use.
- Patient factors: Two studies reported on patient-level predictors of clinical outcomes. In one study each, statistically significant associations were found between flash pulmonary edema and both death and cardiovascular events, between lower GFR and RRT, and a near significant association between proteinuria and RRT. No associations were found between flash pulmonary edema and RRT, lower GFR and death, or between rapid kidney function deterioration, refractory HTN, sex, or history of coronary artery disease and clinical outcomes.
- Treatment factors: 2 studies addressed differences in treatment factors as predictors of outcomes. One study found no association between beta blockers or angiotensin inhibitors and death or RRT, but the second study found that angiotensin inhibitor use was associated with reduced cardiovascular events and statin use was associated with reduced cardiorenal events, death and RRT.

#### Key Question 1 Effects of Intervention on Outcomes

In 17 articles, 7, 9, 19, 20, 24, 25, 29, 30, 32, 33, 35, 50, 92–97 we identified 20 cohorts of patients who were treated with medical therapy only (a total of 7778 patients) in prospective studies. Among the studies, nine cohorts assessed the effectiveness of medical therapy on outcomes in single cohorts of patients (or compared different cohorts of patients receiving medical therapy) and 12 cohorts were from studies comparing medical therapy to PTRAS; one study provided analyses relevant only to Key Question 3.^96, 97^

Only Hackam 2011 explicitly reported consecutive enrollment of patients.97 Four studies reported the presence of HTN as an additional inclusion criterion.19, 25, 93, 95 One study required that patients be over 65 years of age.97 One study specifically included patients with chronic kidney disease.19 The studies mostly included men, with a median average of 64 percent male (range 43–96%). The median average age across the studies was 69.5 years old (range 60.9–78 years). The percentage of patients with bilateral ARAS ranged from 18 to 55 percent. The median average baseline BP across studies was 154/79 mmHg (range 131–175.4/74–95 mmHg). The median average baseline GFR was 40 mL/min (range 33–66.2 mL/min), and SCr was 1.8 mg/dL (range 1–2.29 mg/dL).

The definitions of ARAS varied across studies. Six studies included patients with over 50 percent stenosis9, 24, 32, 92, 93, 95 (one of which required that patients had less than 80% stenosis 32), one with over 60 percent stenosis,7 three with over 70 percent or 75 percent stenosis,29, 33, 34 and two with over 80 percent stenosis.19, 94 The percent stenosis was not reported in four studies. One study was multicenter and had different definitions at the two centers. 30 None of the studies reported using translesional pressure gradients to define stenosis severity. See Appendix Table C.1 for eligibility criteria and Table C.2.2 for arm details.

None of the studies reported on the patients’ history of coronary artery revascularization or concomitant aortic disease; however, one study reported that 26.5 percent of patients had concomitant cerebrovascular disease.30 In four studies, between 36 and 60 percent of patients had concomitant peripheral vascular disease,9, 20, 33, 94 and in two studies 19 and 40 percent of patients had a history of stroke.20, 33 One study reported that 36 percent of patients had peripheral artery disease,93 and another reported 50 percent of patients had carotid stenosis.33 See Appendix Table C.3 for full baseline data.

Among the 17 studies, only three are newly published since the 2006 and 2007 reports. The risk of bias for all studies is summarized in Appendix Figure D.4. About half the studies were of high risk of bias for adjusting for different lengths of patient followup and for incomplete outcome data (attrition bias). All studies were of low risk of bias for sample representing the entire population. About half the studies were deemed to be at low risk of selective reporting bias and the other half unclear risk of bias.

##### Mortality (Study Duration 6 Months or Greater)

Data on long-term mortality was reported in ten studies (Figure 14). All-cause death was reported in 9 to 56 percent of patients (seven studies)7, 9, 19, 20, 24, 33, 93 followed for 2 to 9 years; higher death rates were generally found in longer followup studies. Death as a result of stroke occurred in 5.4 to 85 percent of patients (two studies)19, 24 followed for 2 to 5 years, cardiovascular related deaths occurred in 5.4 to 16 percent of patients (four studies)19, 24, 33, 94 followed for 2 to 7 years, and renal related deaths occurred in 4.2 percent of patients (one study)20 followed for 5 years. For details, see Appendix Table C.4.1.

Figure 14 Death while on medical therapy, percent of patients

Point estimates and 95% confidence intervals from individual studies.

Figure 14: depicts a longitudinal scatter plot of death while on medical therapy. On the x-axis we display years of followup; followup times range from roughly 1 to 9 years. On the y-axis we display the death as a percent of the entire study sample; death percentage ranges from approximately 0 to 55 percent. All studies only report on one time point while on medical therapy.

##### Renal Replacement Therapy

Among seven studies that reported 3 to 5 year followup, between 2 and 18 percent of patients required RRT, with a median of 10 percent (Figure 15).9, 19, 20, 33, 92, 94, 95 There is no clear explanation for the wide range of rates of RRT. See Appendix Table C.4.6.

Figure 15 Renal replacement therapy while on medical therapy, percent of patients

Point estimates and 95% confidence intervals from individual studies. RRT = renal replacement therapy

Figure 15: depicts a longitudinal scatter plot of renal replacement therapy while on medical therapy. On the x-axis we display years of followup; followup times range from roughly 0 to 5 years. On the y-axis we display the renal replacement therapy as a percent of the entire study sample; renal replacement therapy percentage ranges from approximately 0 to 18 percent. All studies only report on one time point while on medical therapy.

##### Cardiovascular Outcomes

Overall, nine studies reported on cardiovascular outcomes. Three studies reported data on CHF events.20, 24, 33 Followup times ranged from 3 months to 7.4 years, and incidence ranged from 1.4 to 13 percent. One study reported a 1.4 percent incidence of flash pulmonary edema at 2-year followup.24 A second study reported a 10 percent incidence of abdominal aortic aneurysm rupture at 7.4-year followup.33 The third study reported an incidence of 8.6 percent of angina resulting in hospitalization at 5-year followup.20 This latter study reported that 4.1 percent of patients followed for 5 years required a coronary artery procedure.20

Four studies reported on incidence of MI, one of which reported that no patients experienced MI during followup.33 Incidence in the other three studies ranged from 2.5 to 83 percent in patients who were observed from 1.75 to 5 years.19, 20, 29 Data on incidence of stroke was reported in 5 studies, one of which reported that no patients had a stroke during followup.22 Incidence of stroke in the other four studies ranged from 2.5 to 23 percent in patients who were observed from 1.75 to 5 years.19, 20, 29, 95

One study reported that 12 percent of patients had a new cardiovascular event (new onset angina, ischemic heart disease, myocardial infarction, revascularization, CHF hospitalization, peripheral vascular disease, or stroke or transient ischemic attack) at a median of 3.1 years.7 In addition, 42 percent had a composite outcome that also included death and RRT. Another study reported that 57 percent had a composite cardiorenal outcome that included death, cardiovascular event (myocardial infarction, stroke, CHF), and RRT or acute kidney injury at a mean of 3.3 years.97 See Appendix Tables C.4.17 and C.4.18.

##### Kidney Function

Overall, 10 studies reported on kidney function outcomes; none reported on the percent of patients with CKD at baseline. Three studies reported data on improvement of kidney function. In two of the studies, improvements occurred in 19 and 26 percent of patients who were observed for 1 year;20, 30 in one study no patients improved at 4-year followup.35 The studies reported no change in kidney function in 35 to 65 percent of patients. A fourth study only reported on the percentage of patients whose kidney function deteriorated.19 Across the four studies, 19 to 38 percent of patients experienced deterioration in kidney function. In one study, at 5-year followup, 5.9 percent of patients had experienced acute kidney injury.20

Four studies reported a decrease of between 0.7 and 8 mL/min in MDRD-estimated GFR at between 1 and 6 years of followup (Figure 16).30, 32, 33, 94 One study reported an average decrease in 1/SCr of 0.012 dL/mg per year over 5 years.20 Four studies reported a change in SCr of between −0.1 and 1.3 mg/dL at between 1 and 5 years of followup.20, 25, 29, 92 For details, see Appendix Tables C.4.3, C.4.6, and C.4.7.

Figure 16 GFR change (in mL/min) while on medical therapy

Point estimates and 95% confidence intervals from individual studies. The line connecting points indicate data coming from the same study (or cohort) at different time points. GFR = glomerular filtration rate.

Figure 16: depicts a longitudinal scatter plot of GFR change while on medical therapy. On the x-axis we display years of followup; followup times range from roughly 1 to 6 years. On the y-axis we display the GFR change as a difference in mL/min; GFR change ranges from approximately −10 to 2 unit change. Studies that report results for multiple followup points tend to exhibit slight changes in GFR change per year while on medical therapy.

##### Blood Pressure Control

Only one study reported data on incidence of HTN and hypertensive crises.24 At 2-year followup, 4.1 percent of patients became newly hypertensive, while none experienced a hypertensive crisis.24 Data on change in SBP was reported in 11 studies (Figure 17), which found decreases in SBP between 6 and 22 mmHg in patients who were observed from 1 to 9 years (one cohort in one study measured 24 hour ambulatory BP; other studies reported clinic BP or did not define how BP was measured).19, 20, 25, 29, 30, 32, 33, 92–95 Nine studies reported data on change in DBP, with decreases ranging from 1 to 13 mmHg in patients who were observed from 1 to 9 years. 20, 29, 30, 32, 33, 92–95

Figure 17 Blood pressure change (in mmHg) while on medical therapy

Point estimates and 95% confidence intervals from individual studies. Blue circles = systolic blood pressure; red triangles = diastolic blood pressure; green squares = mean arterial pressure. The line connecting points indicate data coming from the same study (or cohort) at different time points.

Figure 17: depicts a longitudinal scatter plot of blood pressure change while on medical therapy. On the x-axis we display years of followup; followup times range from roughly 0.5 to 9 years. On the y-axis we display the blood pressure change as a difference in mmHg; blood pressure change percentage ranges from approximately −25 to 10 unit change. Most studies only report on one time point while on medical therapy; studies that report results for multiple followup points tend to exhibit slight changes in blood pressure change per year while on medical therapy.

Two studies reported data on the change in number of antihypertensive medications from baseline to maximum followup (Figure 18). One study reported no change in the average number of medications at 1.75-year followup,29 while the other reported an increase of 1.4 medications for patients who were observed for 3.6 years.19 For details, see Appendix Tables C.4.9, C.4.12, and C.4.14.

Figure 18 Change in number of antihypertensive medications while on medical therapy

Point estimates and 95% confidence intervals from individual studies.

Figure 18: depicts a longitudinal scatter plot of number of antihypertensives change while on medical therapy. On the x-axis we display years of followup; followup times range from roughly 1 to 4 years. On the y-axis we display the number of antihypertensives; the number of antihypertensives change ranges from approximately −0.75 to 1.5 unit change. Most studies only report on one time point while on medical therapy.

##### ACEi/ARB Use

Two studies reported data on ACEi/ARB use. Both found an increase in the percentage of patients on the drugs from baseline to 1 year. RASCAD reported that 79 percent of patients were using ACEi/ARBs at baseline compared to 83 percent at 1 year.32 Wheatley 2009 reported that 38 percent of patients were using ACEi/ARBs at baseline, while 43 percent were using the drugs at 1 year.20 See Appendix Tables C.4.14, C.4.15 and C.4.16.

##### Adverse Events

No study reported adverse events related to medication use.

#### Key Question 2 Association of Patient Factors With Outcomes

Three studies reported analyses of patient-level predictors of clinical outcomes (Table 3). Ritchie 2014,^9^ in univariate analyses, found that patients with flash pulmonary edema were significantly more likely to die or, in a separate analysis, to have a cardiovascular event (see Table 3 for list of events), but were not likely to require RRT. Neither rapid kidney function deterioration nor refractory HTN predicted outcomes (see Table 3 for definitions of predictors).

Table 3 Independent predictors of selected clinical outcomes in patients receiving medical therapy only

Outcome Study | Mean F/up (Metric) | GFR | FPE | Prot | Statins | ACEi/ARB | Other NS
Death
Ritchie 2014 | 3.8 y (HR) | | 2.19^*^ (1.39, 3.47) | | | | Rapid ΔGFR^*^, Refractory HTN^*^
Silva 2008 | 3 y (HR) | 0.97 (0.94, 1.002) | | NS | 0.13 (0.04, 0.44) | NS | Sex, CAD, BB
RRT
Ritchie 2014^†^ | 3.8 y (HR) | | NS^*^ | | | | Rapid ΔGFR^*^, Refractory HTN^*^
Silva 2008 | 3 y (HR) | 0.92 (0.88, 0.97) | | 1.16 (0.99, 1.37) | 0.21 (0.07, 0.64) | NS | Sex, CAD, BB
CV Event^‡^
Ritchie 2014 | 3.8 y (HR) | | 3.07^*^ (1.71, 5.51) | | | | Rapid ΔGFR^*^, Refractory HTN^*^
Hackam 2008^§^ | | | | | | 0.75 (0.62, 0.91)
Cardiorenal Event^¶^
Hackam 2008/2011^§^ | 3.3 y (HR) | | | | 0.60 (0.53, 0.69)

* Univariate

† or serum creatinine doubling

‡ Ritchie 2014: Myocardial infarction, acute coronary syndrome, flash pulmonary edema hospitalization, arrhythmia hospitalization, stroke, transient ischemic attack, new onset angina, or coronary revascularization

§ Hackam 2008: Death, myocardial infarction, or stroke

Overlapping studies with data from four (Hackam 2008) or six (Hackam 2011) administrative databases

¶ Myocardial infarction, stroke, heart failure, acute renal failure, dialysis or death

ACEi/ARB = angiotensin converting enzyme inhibitor or angiotensin receptor blockers, BB = beta blocker, CAD = coronary artery disease, CV = cardiovascular, F/up = followup, FPE = flash pulmonary edema, GFR = glomerular filtration rate, HR = hazard ratio, HTN = hypertension, NS = no significant association, Other NS = nonsignificant predictors not otherwise listed, Prot = proteinuria, Rapid ΔGFR = rapid kidney function decline (serum creatinine increase by 20% or 1.14 mg/dL increase in 6 months), Refractory HTN = refractory hypertension (BP >140/90 mmHg on ≥3 medications), RRT = renal replacement therapy.

Silva 2008 found that lower GFR was significantly associated with RRT but not death.94 Proteinuria was a near-significant predictor of RRT, but not death. Sex and history of coronary artery disease were not associated with outcomes.

#### Key Question 3 Association of Treatment Factors With Outcomes

Three analyses in two studies examined the association between specific medication treatments and clinical outcomes (Table 3). Silva 2008, in multivariable analyses, found that use of beta blockers or angiotensin inhibitors (ACEi or ARB) were not associated with likelihood of death or RRT.94 In contrast, Hackam et al. in two overlapping analyses of four (Hackam 2008)96 or six (Hackam 2011)97 administrative databases, found that angiotensin inhibitor use was associated with reduced cardiovascular events and statin use was associated with reduced cardiorenal events, death and RRT.

### Surgical Revascularization

#### Key Points

- Four studies (3 retrospective, 1 prospective) reported outcomes in patients receiving surgical revascularization. The studies were highly heterogeneous in both their included patients and specific surgical techniques (both within and across studies). The retrospective studies were subject to high risk of bias related to attrition, selective reporting, and lack of adjustment for different lengths of followup. The prospective study was deemed low risk of bias.
- Mortality: In four studies, mortality ranged from 26 to 36 percent after about 5 years of followup.
- RRT: In two studies, incident RRT (or combined renal failure outcomes) occurred in 38 and 74 percent of patients at about 5 years of followup.
- Cardiovascular outcomes: One study reported new-onset angina in 10 percent of patients and coronary revascularization in 8 percent after a mean of 10 years; 6 percent of patients suffered an MI and 4 percent a stroke.
- Kidney function: Two studies reported on kidney function; in one, 43 percent of patients had improved kidney function, 10 percent had worsened kidney function, and 70% of those who were on RRT prior to surgery discontinued dialysis. Mean GFR increased by 7 mL/min after about 5 years (1 study), but mean SCr increased by 0.1 mg/dL at 4 years (in the second study).
- BP control: In four studies, improved or cured HTN occurred in 53 to 82 percent of patients. Two studies found large improvements in SBP (−53 and −31 mmHg) at 4 to 5 years, but one found a large improvement in DBP (−23 mmHg) and the other study a small, not statistically-significant improvement (−8 mmHg).
- Adverse events: Three studies reported surgery-related adverse events, including postoperative mortality, bleeding, arterial occlusion or thrombosis, infection, and distal embolization.
- Patient factors: Two studies reported on patient-level predictors of clinical outcomes. Both studies found that found that patients with a history of cardiovascular disease, diabetes, worse kidney function, or who were older were at increased risk of all-cause death, cardiovascular death, or either death or RRT. In one study each, higher SBP were at lower risk of combined death or RRT but not all-cause death alone, preoperative angina was associated with cardiovascular mortality, and resistive index >0.8 was associated with all-cause death. Race, sex, DBP, and number of antihypertensive medications were not associated with outcomes.
- Treatment factors: One study addressed differences in treatment factors as predictors of outcomes. Bilateral repair and whether renal artery repair was combined with aortic repair were not associated with death in adjusted analyses.

#### Key Question 1 Effects of Intervention on Outcomes

Four studies reported on primary surgical revascularization for ARAS,23, 98–100 three of which were used in the previous update. There were three retrospective, nonrandomized comparative studies of surgery with PTRAS98–100 and one RCT (versus PTRAS).23 In total, 880 patients were included. The mean durations of followup ranged from 3.1 to 4.7 years (or up to 5 or 10 years). An additional study reported only significance of differences in outcomes between surgical revascularization and PTRAS and is not included in this section.34

Study inclusion criteria incorporated patients with at least 60 percent ARAS,100 but frequently participants had 70 to 80 percent stenosis or more, by ultrasound or angiography imaging. Inclusion criteria based on degree of stenosis were incomplete or not reported in two studies.26, 98 No study reported using translesional pressure gradients to define stenosis severity. The sex distribution varied widely from 43 percent males in Galaria 2005 to 65 percent males in Alhadad 2004. The mean age of the surgical cohorts ranged from 62 to 76 years. Patients with fibromuscular dysplasia were either specifically excluded or accounted for a small fraction (<10%) of the total study population. See Appendix Table C.1 for study eligibility criteria and designs.

The indications for operative intervention were to treat ARAS that was causing derangements in BP or kidney function. cardiovascular disease was present in 53 and 90 percent of patients in the two studies that reported it.99, 100 All baseline SBP measurements were elevated and ranged from a mean of 171 to 200 mmHg. Mean DBP measurements were between 82 and 104 mmHg. The mean serum Cr values were between 1.3 and 2.6 mg/dL See Appendix Tables C.1 and C.3.

Surgical approaches varied according to revascularization needs and available vessels or conduits. Procedures included renal endarterectomy, renal and aortic endarterectomy, and mesenteric (i.e., splenorenal, hepatorenal, iliorenal) or aortorenal bypass procedures. Bypass procedures used native saphenous vein, PTFE (polytetrefluoroethylene), and Dacron grafts to construct the conduits when the native renal artery was not reimplanted. The choice and use of prosthetic grafts were at the surgeon’s discretion. In all studies, some patients (9 to 56%) required combined aortic procedures, some of which were done to facilitate the renal bypass, and others were due to concomitant aortoiliac atherosclerotic disease. In one study, secondary operations performed for prior failed endoluminal repairs were included and comprised 10 percent of the total cohort.100 Specific medication adjuncts used during operative procedures included alprostadil23 when mentioned. See Appendix Table C.2.6.

The one RCT (Balzer 2009)23 was of low risk of bias for all Cochrane risk of bias questions. The two retrospective NRCSs (Alhadad 2004 and Galaria 2005)98, 99 were both adequately representative, but one each were high risk of bias for high attrition, selective outcome reporting, and different lengths of follow-up for different study arms. The prospective study (Cherr 2002)99 was low risk of bias for all items;

##### Mortality (Study Duration 6 Months or Greater)

In four studies, mortality and long-term survival rates were described after open revascularization.23, 98–100 In one study, a mortality rate of 26 percent was reported after a mean followup period of 4.5 years.23 In the other three studies, mortality rates ranged from 26 to 36 percent after a mean followup of 5 years. The majority of late deaths were related to cardiovascular disease in two studies.98, 99 For details, see Appendix Table C.4.1.

##### Renal Replacement Therapy

Progression to ESRD or new requirement for hemodialysis was defined as an endpoint in 2 studies.99, 100 After a mean follow-up of 4.7 years in one study, 38 percent of survivors required RRT.99 At 5 years in the second study, the cumulative freedom from RRT or recurrent renal insufficiency (Cr > 1.5 mg/dL), reported as renal disease-related mortality, was 74 percent (SD 7 percent). 100 See Appendix Table C.4.6.

##### Cardiovascular Outcomes

Only a single study reported long-term cardiovascular outcomes. Cherr 2002 reported new-onset angina in 9.8 percent of patients and coronary revascularization in 8.3 percent after a mean of 10 years; 5.8 percent of patients suffered an MI and 4.4 percent a stroke.99 See Appendix Table C.4.17.

##### Kidney Function

In the two studies reporting kidney function outcomes, 4 and 12 percent had CKD at baseline.26, 100 In one study, 43 percent of patients had improved kidney function (including 28 of 40, 70%, who discontinued dialysis), 47 percent had no clinically significant change, and 10 percent had worsened kidney function.99 In this same study, mean CrCl (estimated by Cockcroft-Gault) increased by 7 mL/min (95% CI 3.5 to 10.7) at a mean of 4.7 years. In another study, mean SCr increased by 0.1 mg/dL (95% CI −0.2 to 0.35) at both 1 and 4 years of followup.23 See Appendix Tables C.4.4, C.4.6, and C.4.7.

##### Blood Pressure Control

Improved or cured HTN was reported in four studies and occurred in 53 to 82 percent of patients.23, 98–100 Cherr 2002 found decreases in SBP/DBP at a mean of 4.7 years of −53 mmHg (95% CI −80 to −26)/−23 mmHg (−35 to −11).99 Balzer 2009 found statistically significant decreases in clinic SBP at 1 and 4 years: at 1 year −21 mmHg (95% CI −38 to −4); at 4 years −31 mmHg (95% CI −49 to −13). But they found nonsignificant changes in DBP at 1 year (−4 mmHg; 95% CI −14 to 6) and 4 years (−8 mmHg; 95% CI −18 to 2).23 See Appendix Tables C.4.10, C.4.12, and C.4.13.

##### Adverse Events (Including 30-Day Mortality)

In three studies, 30-day or in-hospital median mortality was 7 percent (range 0% to 9%).98–100 Major reported adverse operative events at 30 days included bleeding (8%),98 arterial occlusion or thrombosis (3.7% and 6.0%),23, 98 infection (3%),98 and distal embolization (2%).98 Immediate reoperations occurred in 4 and 28 percent in two studies.98, 100 Major nontechnical morbidity events were acute kidney injury (1% to 12%),98, 99 cerebrovascular events (1%),98, 99 cardiovascular events (4% to 14%),98–100 and septicemia (1%).98, 100 See Appendix Tables C.4.19 and C.4.20.

#### Key Question 2 Association of Patient Factors With Outcomes

Two studies reported analyses of patient-level predictors of clinical outcomes.26, 99 Between the two studies, they found that patients with a history of cardiovascular disease, diabetes, and those with worse kidney function or who were older were at increased risk of all-cause death, cardiovascular death, or either death or RRT (Table 4). Specifically, Cherr 2002 found that the HRs for both all-cause death and combined death or RRT were increased independently in patients with lower GFR, and histories of diabetes, myocardial infarction, stroke, and severe aortic occlusive disease.99 For both outcomes, patients with prior myocardial revascularization were at significantly decreased risk. Older patients were at increased risk of all-cause death, but not combined death or RRT. Those with higher SBP were at lower risk of combined death or RRT, but not all-cause death alone. Race, sex, DBP, and number of antihypertensive medications were not independently associated with these outcomes. In this study, only the presence of preoperative angina was associated with the risk of cardiovascular mortality (HR 2.18; 95% CI 1.25 to 3.84). Crutchley 2009 found that resistive index >0.8 was an independent predictor of all-cause death.26

Table 4 Independent predictors of selected clinical outcomes after surgical renal artery repair

Outcome Study | Mean F/up (Metric) | Age | GFR | RI ≥0.8 | SBP | DM | CorRevasc | Stroke | MI | Aortic Dz | Other NS
Death
Cherr 2002 | 4.7 y (HR) | 1.22 (1.02, 1.46) | 0.60 (0.49, 0.74) | | NS | 1.75 (1.18, 2.60) | 0.60 (0.38, 0.96) | 1.52 (1.00, 2.29) | 1.48 (1.06, 2.07) | 1.49 (1.06, 2.10) | Race, Sex, DBP, Rx
Crutchley 2009^*^ | 4.8 y (HR) | | | 6.7^†^ (2.6, 17)
Death or RRT
Cherr 2002 | 4.7 y (HR) | NS | 0.43 (0.34, 0.54) | | 0.79 (0.67, 0.94) | 2.14 (1.15, 3.97) | 0.69 (0.45, 1.06) | 1.50 (1.02, 2.22) | 1.36 (0.99, 1.88) | 1.66 (1.19, 2.31) | Race, Sex, DBP, Rx

* Crutchley 2004 was a retrospective comparative study of surgery vs. angioplasty with stent with <100 participants in the surgical arm.26 Therefore, this studies did not meet eligibility criteria for Key Question 1 for surgical cohorts and was not included there.

† HR for combined surgery and angioplasty with stent groups, described in text and graphically as similar results for both intervention groups.

Aortic Dz = Severe aortic occlusive disease, CHF = congestive heart failure, CorRevasc = coronary revascularization, DBP = diastolic blood pressure, DM = diabetes mellitus, F/up = followup, GFR = glomerular filtration rate (unit used in regression not reported), HR = hazard ratio, LVEF = left ventricular ejection fraction, MI = myocardial infarction, NS = no significant association, Other NS = nonsignificant predictors not otherwise listed, RI = resistance index, RRT = renal replacement therapy, Rx = number of antihypertensive medications, SBP = systolic blood pressure (unit used in regression not reported).

#### Key Question 3 Association of Treatment Factors With Outcomes

Cherr 2002 found that bilateral repair did not independently predict death and that perioperative mortality was higher in patients with combined aortic and bilateral repair (6.9%) compared to isolated renal artery repair (0.8%; P=0.01, univariate), but after adjustment for age and clinical CHF, this difference was not statistically significant. 99

## Acute Decompensation Case Reports

### Key Points

- 20 case reports of patients with acute decompensation of their RAS universally presented patients who, after revascularization (by PTRAS or surgery) improved symptomatically and with improved kidney function and/or BP control. Two case reports presented patients who, after an episode of acute decompensation, continued medical therapy alone for 10 months in one case and 5 year in the other, but who subsequently had a second episode of decompensation that resulted in clinical improvement. All eight cases who required acute hemodialysis no longer required RRT after revascularization.

### Key Question 1 Effects of Intervention on Outcomes

None of the comparative or single group studies focused on or explicitly included patients with acute decompensation who have rapidly declining kidney function with possible oliguria or anuria, flash pulmonary edema, and/or intractable malignant HTN. To partially overcome this deficiency, we summarized the 20 most recent case reports of such patients, published between 2006 and 2014 (Table 5).101–120

Table 5 Case reports

Each row = individual patient

Study, Year PMID | Decompensation Description | Comorbidities | Acuity (Time) | ○ Age, y (Sex) • % Stenosis | [underlined: Pre-Tx] ▪ GFR [SCr] ❖ Pulm Ed? | [underlined: Pre-Tx] ➢ BP ● No. Rx | Intervention | Followup Time | [underlined: Response] ▪ GFR [SCr] ❖ Pulm Ed? | [underlined: Response] ➢ BP ● No. Rx
Komatsu, 2014 None | RI, HTN | DM, PVD | | ○ 65 y (M) • L 90% | ▪ [1.10] ❖ | ➢ 156/98 ● | PTRAS L | In-hospital | ▪ [0.97] ❖ | ➢ 122/73 ●
Demming, 2013 23673780 | Acute chest pain and progressive dyspnea | DCM, MR, MetS, COLD | 7 d | ○ 83 y (F) • L “high-grade”; R hypoplasia | ▪ 23 [2.2] ❖ Yes | ➢ 220/100 ● 11 Rx | PTRAS L | 1.5 y | ▪ 34 [1.55] ❖ | ➢ ● 5 Rx
Ishida, 2013 23473081 | Severe HTN, rapidly worsening RI | CRF | | ○ 69 y (M) • R 99% | ▪ [6.94] ❖ Severe LE edema | ➢ 180/90 ● 5 Rx | PTRAS R | 1 mo | ▪ [4.0] ❖ Edema ameliorated | ➢ 135/70 ● 3 Rx
Ishida, 2013 23473081 | Severe HTN, rapidly worsening RI | CRF | | ○ 69 y (M) • R 99% | ▪ [6.94] ❖ Severe LE edema | ➢ 180/90 ● 5 Rx | PTRAS R | 1 y | ▪ [3.8] ❖ | ➢ 135/65 ● 1 Rx
Alonso, 2013 22944546 | Sudden acute dyspnea | HTN, DM, no CAD | 2 (FPE × 3 in 6 mo) | ○ 73 y (F) • B critical | ▪ Yes ❖ | ➢ 194/115 ● 4 Rx | PTRAS B | 3 mo | ▪ None ❖ | ➢ ●
Chrysochou, 2013 22262735 | FPE × 3, poorly controlled HTN | LVH, claudication, no CAD | 12 mo | ○ 65 y (F) • B 85% | ▪ 26 [] ❖ Yes (NYHA II) | ➢ 161/80 (ABPM) ● 6 Rx | PTRAS | 2 wk | ▪ ❖ No (2 flights^*^) | ➢ 101/57 ● 4 Rx
Chrysochou, 2013 22262735 | FPE × 3, poorly controlled HTN | LVH, claudication, no CAD | 12 mo | ○ 65 y (F) • B 85% | ▪ 26 [] ❖ Yes (NYHA II) | ➢ 161/80 (ABPM) ● 6 Rx | PTRAS | 4 mo | ▪ 34 ❖ | ➢ ● 1 Rx
Chrysochou, 2013 22262735 | FPE × 3, poorly controlled HTN | LVH, claudication, no CAD | 12 mo | ○ 65 y (F) • B 85% | ▪ 26 [] ❖ Yes (NYHA II) | ➢ 161/80 (ABPM) ● 6 Rx | PTRAS | 1 y | ▪ ❖ | ➢ 129/71 ● 3 Rx
Noce 2012 23427756 | Refractory HTN, ARF | No HTN | Recent () | ○ 51 y (M) • R 85%; L 75% | ▪ 28 [5.78] ❖ No (LVH, no edema) | ➢ 190–220 / 100–130 ● 2 Rx | PTRAS B | 30 d | ▪ [2.8] ❖ | ➢ 150/85 ● 2 Rx
Noce 2012 23427756 | Refractory HTN, ARF | No HTN | Recent () | ○ 51 y (M) • R 85%; L 75% | ▪ 28 [5.78] ❖ No (LVH, no edema) | ➢ 190–220 / 100–130 ● 2 Rx | PTRAS B | 5 y | ▪ 65 [1.5] ❖ | ➢ 120/80 ● 1 Rx
Li, 2012 21558176 | FPE, ACS (in 2002) | | | ○ 73 y (F) • R 82% L 87% | ▪ 17 [2.9] ❖ Yes | ➢ ● 0 Rx (implied) | Medical (refused PTRAS) | 4 y | ▪ [1.8–2.0] ❖ No | ➢ 154/69 ● 3 Rx
Li, 2012 21558176 | FPE, ARF (in 2007), RRT † | | | ○ ~78 • B “tight” | ▪ HD ❖ Yes | ➢ 120/70 ● 3 Rx (implied) | PTRAS B | 3.5 y | ▪ 30 [1.7] Off RRT ❖ AFib/CHF | ➢ 140/72 ●
Navaravong, 2011 21855421 | CHF Sx, ARF, Uncontrolled HTN | L occluded, R 70%, CAD, CKD IV (SCr 1.6), HTN, AAA | | ○ 79 y (M) • R 99%; L 100% | ▪ [5.4], anuric ❖ Yes | ➢ 170/90 ● 1 Rx | PTRAS R | 4 d | ▪ [1.5] ❖ Yes | ➢ Improved ●
George, 2011 21566313 | Rest angina, acute LVF & FPE, uncontrolled HTN | | >2 d | ○ 70 y (F) • (bilat) | ▪ 45 [3.0] ❖ Yes | ➢ 210/110 ● 4 Rx | PTRAS R | D/C | ▪ 63 [1.6] ❖ | ➢ “well-controlled ● 2 Rx
George, 2011 21566313 | Rest angina, acute LVF & FPE, uncontrolled HTN | | >2 d | ○ 70 y (F) • (bilat) | ▪ 45 [3.0] ❖ Yes | ➢ 210/110 ● 4 Rx | PTRAS R | 2 mo | ▪ [ 1.3] ❖ | ➢ ●
Kindo 2011 21118836 | FPE | CHF, PAD, Heart transplant, HTN | | ○ 60 y (M) • (L no function) | ▪ [2.5] ❖ Yes | ➢ 190/100 ● | Hepatorenal bypass R | 5 d | ▪ [2.0] ❖ | ➢ Controlled ●
Kindo 2011 21118836 | FPE | CHF, PAD, Heart transplant, HTN | | ○ 60 y (M) • (L no function) | ▪ [2.5] ❖ Yes | ➢ 190/100 ● | Hepatorenal bypass R | 3 y | ▪ [1.6] ❖ No | ➢ ●
Islam, 2009 19808722 | SCr rise on ramipril | (SCr 1.2) | Acute | ○ ~59 (F) • B Severe | ▪ [2.0] ❖ | ➢ ● | Medical (refused PTRAS) | 10 mo | ▪ (1.5–2.5) ❖ Yes | ➢ ●
Islam, 2009 19808722 | SOB, FPE, AMI, RRT (10 mo later)^‡^ | Uncontrolled HTN, Acute CHF^‡^ | 10 d | ○ 60 y • 100% (bilat) | ▪ [4.0→7.6, HD] ❖ Yes | ➢ 180/92 ● 5 Rx | PTRAS B | 3 d | ▪ [2.1] Off RRT ❖ “no recurrence in followup” | ➢ ●
Kanamori, 2009 19726830 | Dizziness, Severe HTN, ARF, RRT | | 30 d | ○ 72 y (F) • R 100%; L 90% | ▪ [1.2→6.7, HD] ❖ Yes | ➢ 190/100 ● 1 Rx (implied) | PTRAS B | | ▪ [0.8] Off RRT ❖ No | ➢ 140/90 ●
Dippel, 2009 19652259 | Accelerated HTN | CAD, TIA | | ○ 74 (F) • R 40–50% L 80% | ▪ 30 [1.3] ❖ No | ➢ 200/100 ● 3 Rx | PTRAS L (with DEP) | 30 d | ▪ ❖ | ➢ 90/46 ● 2 Rx
Dippel, 2009 19652259 | Accelerated HTN | CAD, TIA | | ○ 74 (F) • R 40–50% L 80% | ▪ 30 [1.3] ❖ No | ➢ 200/100 ● 3 Rx | PTRAS L (with DEP) | 1 y | ▪ ❖ | ➢ 100/60 ● 2 Rx
Dziemianko, 2009 19379457 | ARF, RRT, HTN crisis, Dyspnea, LE edema | None | | ○ 53 y (M) • R 75%; L 95% | ▪ [3.6→HD] ❖ Yes | ➢ 260/150 ● 0 Rx (implied) | PTRAS L^#^ | 6 mo^#^ | ▪ [1.5] Off RRT ❖ No | ➢ 144/91 (ABPM) ●
Chrysochou, 2009 18045711 | Oligoanuria, RRT, malaise, breathlessness | RAS (50–75% L), DM, HTN (199/89) | 3 d | ○ 73 y (F) • R 100%, L >95% | ▪ 8.0→HD] ❖ Yes | ➢ 221/80 ● 5 Rx | PTRAS L | 3 d | ▪ [2.6] Off RRT ❖ | ➢ ●
Chrysochou, 2009 18045711 | Oligoanuria, RRT, malaise, breathlessness | RAS (50–75% L), DM, HTN (199/89) | 3 d | ○ 73 y (F) • R 100%, L >95% | ▪ 8.0→HD] ❖ Yes | ➢ 221/80 ● 5 Rx | PTRAS L | 8 mo | ▪ 26 [2.0] ❖ | ➢ ●
Campbell, 2008 18335782 | N/V/D, Low back pain, anuria, RRT | HTN | 5 d | ○ 49 y (F) • R ≥60% L <60% | ▪ [9.3→HD] ❖ No | ➢ 88/76 ● 1 Rx | Aortorenal artery bypass R | 6 d | ▪ [1.8] Off RRT ❖ No | ➢ ●
Campbell, 2008 18335782 | N/V/D, Low back pain, anuria, RRT | HTN | 5 d | ○ 49 y (F) • R ≥60% L <60% | ▪ [9.3→HD] ❖ No | ➢ 88/76 ● 1 Rx | Aortorenal artery bypass R | 6 wk | ▪ [1.5] ❖ No | ➢ Controlled ● 3 Rx
Wykrzykowska, 2008 18174627 | FPE (ventilation) | Giant cell arteritis, HTN, PVD | | ○ 81 y (F) • R mild; L severe | ▪ [2.7] ❖ | ➢ 200/ ● 5 Rx | PTRAS L | 5 mo | ▪ [1.4] ❖ No | ➢ 160/ ●
Wykrzykowska, 2008 18174627 | CHF, Severe HTN (6 mo later)^§^ | Giant cell arteritis, HTN, PVD | | ○ 81 or 82 y • R severe; L patent | ▪ ❖ Yes | ➢ Severe ● | PTRAS R | | ▪ ❖ No | ➢ Improved ●
Kuznetsov, 2007 17703833 | Weakness, dyspnea, chest discomfort, N/V→Anuria, RRT | HTN, CVA, CAD, CHF, Aortic stenosis (SCr 1.5) | 2 wk | ○ 75 y (F) • B critical | ▪ [2.8→6.5→HD] ❖ Yes | ➢ 210/110 ● 3 Rx | PTRAS B (with DEP) | D/C | ▪ [1.9] Off RRT ❖ No | ➢ 115–147/ 53–72 ● 3 Rx
Kuznetsov, 2007 17703833 | Weakness, dyspnea, chest discomfort, N/V→Anuria, RRT | HTN, CVA, CAD, CHF, Aortic stenosis (SCr 1.5) | 2 wk | ○ 75 y (F) • B critical | ▪ [2.8→6.5→HD] ❖ Yes | ➢ 210/110 ● 3 Rx | PTRAS B (with DEP) | 4 mo | ▪ [1.7] ❖ | ➢ ●
Kumar, 2006 16941797 | Recurrent breathlessness, FPE × 4 | CAD, No HTN | 1 mo | ○ 58 y (M) • L 99% R 90% | ▪ [1.7] ❖ Yes | ➢ 160–170 / 100–110 ● 2 Rx | PTRAS B | 3 mo | ▪ [1.2] ❖ No | ➢ ●
George, 2006 16521653 | Dyspnea, oliguria, RRT, anasarca, orthopnea | Aortoarteritis, L nephrectomy (occluded RA) | 2 wk | ○ 51 y (F) • R 100% | ▪ [3.6→HD] ❖ Yes | ➢ 190/110 ● | PTRAS R | 2 d | ▪ [1.0] Off RRT ❖ No | ➢ ● 2 Rx
George, 2006 16521653 | Dyspnea, oliguria, RRT, anasarca, orthopnea | Aortoarteritis, L nephrectomy (occluded RA) | 2 wk | ○ 51 y (F) • R 100% | ▪ [3.6→HD] ❖ Yes | ➢ 190/110 ● | PTRAS R | 3 wk | ▪ Stable ❖ | ➢ Stable ● 2 Rx

* Exercise tolerance improved to ~50 yards and she was able to climb 2 flights of stairs before needing to stop.

† Second acute episode in same woman about 5 years later.

‡ Second episode 10 months later

# R PTRAS placed at 6 months. 6 months subsequently “kidney function remained normal and blood pressure normalized.”

§ Second episode 6 months later

AAA = abdominal aortic aneurysm, ABPM = 24 hour ambulatory blood pressure monitoring, ACS = acute coronary syndrome, AFib = atrial fibrillation, AMI = acute myocardial infarction, B = bilateral, BP = blood pressure (in mmHg), CHF = congestive heart failure, CKD IV = chronic kidney disease stage IV, COPD = chronic obstructive pulmonary disease, CRF = chronic renal failure, D/C = hospital discharge, DCM = dilated cardiomyopathy, DEP = distal embolic protection device, DM = diabetes mellitus, FPE = flash pulmonary edema, GFR = glomerular filtration rate (in mL/min/m^2^), HD = hemodialysis, HTN = hypertension, K = potassium (in mg/dL), L = left renal artery, LE = lower extremity, LVF = left ventricular failure, M/F = male or female, MetS = metabolic syndrome, MR = mitral regurgitation, N/V/D = nausea vomiting and diarrhea, nd = no data, NYHA = New York Heart Association class, PAD = peripheral artery disease, Plasty = angioplasty, Pre-Tx = pre-treatment (during acute decompensation), PTRAS = percutaneous transluminal renal angioplasty with stent, Pulm Ed = flash pulmonary edema, PVD = peripheral vascular disease (not including renal artery disease), R = right renal artery, RA = renal artery, RCA = right coronary artery stenosis, RI = “renal impairment”, RRT = renal replacement therapy (dialysis) [required], Rx = antihypertensive medications required, SCr = serum creatinine (in mg/dL), Sx = symptoms, TIA = transient ischemic attack.

The patients ranged in age from 49 to 83 years old (median 69.5); 13 were women. Most commonly, patients (n=13) had new onset dyspnea, orthopnea, CHF or flash pulmonary edema symptoms. Nine patients were described as having difficult to control, rapidly accelerating, or malignant HTN. Seven patients had acute renal failure or rapid rises in SCr or falls in GFR; four described oliguria or anuria; and eight of the patients required hemodialysis at some point. Other presenting symptoms included angina, chest pain, or acute myocardial infarction, peripheral edema, nausea and vomiting, malaise and other nonspecific symptoms. Among the six patients with reported data, presentation GFR ranged from 17 to 45 mL/min. Among 19 patients, the presentation SCr ranged from 1.1 to 9.3 mg/dL; in seven cases, there was a description of a rapid rise in SCr over the proceeding days, which usually led to hemodialysis. Presentation BP was substantially elevated in all but one case (and one additional case whose BP was not reported), ranging from 170/90 mmHg on one antihypertensive drug to 220/100 mmHg on 11 drugs. Five patients were on no or one antihypertensive drug at presentation. The lowest presentation BP was 120/70 mmHg on three drugs (in a patient who was being medically treated for RAS and presented requiring hemodialysis).

All but one patient were found to have high grade stenosis (of at least 80% or described as critical or some other term) in at least one renal artery. High grade stenosis in both renal arteries (or equivalent) was reported in 10 of 18 patients.

Two of the 10 patients refused PTRAS on first presentation and were treated medically. One of these cases (reported by Li 2012) remained stable for 4 or 5 years but after a second episode of decompensation had bilateral PTRAS.108 The second case (Islam 2009) did not have true RAS decompensation at first presentation since her rapid rise in SCr was secondary to ramipril treatment.110 However, 10 months later, the patient decompensated and suffered a myocardial infarction and required hemodialysis. She also then had PTRAS. All other patients had PTRAS or surgical revascularization (2 cases) within one or two weeks of initial decompensation.

Followup after revascularization occurred from hospital discharge to 5 years (median 5 months). Only seven of the cases reported outcomes 1 year or more after revascularization. Among the 18 cases that reported followup kidney function, all patients had improved (or stable, one patient) kidney function. All eight cases who required acute hemodialysis no longer required RRT after revascularization. Among 16 cases with followup data, BP was improved in 15; in one case108 (Li 2012), SBP was increased compared with presentation but DBP was stable; the number of medications the patient was on was not reported. In seven of eight cases with data on the number of antihypertensive medications at presentation and followup, the number of drugs was reduced or the same (one case) at followup with a lower BP. One patient was on one drug at presentation and had controlled BP at 6 week followup on three drugs. One case report (Alonso 2013) did not report kidney or BP followup but reported only that the patients pulmonary edema symptoms had fully resolved at 3 months.104 For all cases who presented with flash pulmonary edema, CHF, or dyspnea, it was stated or implied that symptoms were fully resolved without recurrence at followup.

In summary, a review of the 20 most recently published case reports of management of patients with ARAS with acute decompensation—as manifested by rapid worsening of kidney function, recent severe or difficult to control HTN, flash pulmonary edema, or related symptoms—found that all patients improved after revascularization, almost always with PTRAS. One of the case reports described a patient who refused recommended revascularization for her acute RAS decompensation. She was managed successfully for 5 years until she had a second decompensation at which point she was treated with PTRAS. Overall, the case reports all report clinically successful revascularizations in patients with acute decompensation.

## Strength of Evidence Across Study Designs

As summarized in Table 6, for all outcomes, the strength of evidence is low regarding the relative benefit of PTRAS versus medical therapy alone for patients with ARAS, across both comparative and noncomparative studies.

Table 6 Angioplasty with stent versus medical therapy alone for the treatment of ARAS: Strength of evidence

Outcome | Strength of Evidence | Design No. Studies | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Other Issues | Finding
Death | Low | RCT: 4 NRCS: 5 | Moderate | RCT: Direct Other: Indirect | RCT: inconsistent All: inconsistent | Imprecise | Undetected | Important^*^ | Comparative studies: No evidence of a difference
RRT/ESRD | Low | RCT: 4 NRCS: 5 Case report: 18 | Moderate | RCT: Direct Other: Indirect | RCT: consistent All: consistent | Imprecise | Undetected | Important^*^ | Comparative: No evidence of a difference Case reports: RRT averted with revascularization
Cardiovascular event | Low | RCT: 5 NRCS: 3 Case report: 18^†^ | Moderate | RCT: Direct Other: Indirect | RCT: consistent All: consistent | Imprecise | Undetected | Important^*^ | Comparative: No evidence of a difference Case reports: Cardiovascular symptoms resolved immediately with revascularization
Kidney function | Low | RCT 6 NRCS: 7 Case report: 18 | Moderate | RCT: Direct Other: Indirect | RCT: consistent All: inconsistent | Imprecise | Undetected | Important^*^ | RCT: No evidence of a difference NRCS: Heterogeneous effect on kidney function after PTRAS, favoring PTRAS Case reports: Improvement with revascularization
BP control | Low | RCT: 6 NRCS: 6 Case report: 18 | Moderate | RCT: Direct Other: Indirect | Comparative: inconsistent All: consistent | Imprecise | Undetected | Important^*^ | Comparative: Inconsistent Case reports: Improvement with revascularization
Adverse events | Low | RCT: 4 NRCS: 4 Cohort PTRAS: 34 Cohort Rx: 0 | Moderate | RCT: Direct Other: Indirect | Consistent | Imprecise | Suspected | Important^‡^ | Severe adverse events rare, but reported only in PTRAS studies.

AE = adverse events, ARAS = atherosclerotic renal artery stenosis, BP = blood pressure, Case = case reports, CV = cardiovascular, MCID = minimum clinically important difference, N = number of study participants, No. = number, NRCS = nonrandomized comparative studies, PTRAS = percutaneous transluminal renal angioplasty with stent placement, RCT = randomized controlled trials, RRT = renal replacement therapy, Rx = medical therapy alone, SoE = strength of evidence.

* RCTs of limited applicability to typical patients choosing PTRAS. NRCSs inadequately adjusted. Single arm studies analyzed poorly comparable cohorts of patients.

† Congestive heart failure/pulmonary edema symptoms and angina

‡ Noncomparable adverse events between PTRAS and medical therapy. Poorly reported.

Overall, there is a low strength of evidence of no difference in clinically important outcomes (death, cardiovascular events, RRT) either in terms of statistically significant differences or the arbitrary MCID of HR≤0.80. This conclusion is most applicable to those patients for whom there is clinical equipoise between the two treatments (patients for whom no clear benefit of revascularization is perceived). The RCTs generally found no clear differences in rates of clinically important outcomes but had the important limitation of low applicability to typical patients for whom PTRAS is being recommended, since these patients were excluded from the trials either by design or because of difficulty recruiting them into trials that might disallow revascularization. The NRCSs were less consistent, but provided less reliable estimates of comparative effectiveness due to inadequate adjustment for fundamental differences in patients who are chosen for revascularization and those who remain on medical therapy. For these reasons, the NRCSs were deemed to not provide sufficiently strong evidence to upgrade the strength of evidence derived from the RCTs. Likewise, the single-intervention cohorts are highly heterogeneous across studies in their patient populations and their estimates of outcome rates. It is highly unlikely that the patients in the PTRAS studies are comparable to those in the (many fewer) medical therapy studies.

Overall, there is low strength of evidence that kidney function may be improved in patients who undergo PTRAS, based on comparative studies and the indirect comparison between cohorts of patients who had PTRAS or continued medical therapy; although the RCTs generally found no difference in effect.

Overall, there is low strength of evidence that BP control is similar in patients who undergo PTRAS and those who remain on medical therapy alone. The RCTs mostly found no significant difference, but the NRCS had inconstant, heterogeneous findings.

Likewise, overall, there is low strength of evidence that clinically important adverse events are more common, though rare, related to PTRAS than medical therapy alone; however, studies generally failed to report medication-related adverse events.

As summarized in Table 7, for all outcomes, evidence is insufficient to determine the strength of evidence regarding the relative benefit of open surgery versus medical therapy alone for patients with ARAS, across both comparative and noncomparative studies. Only a single comparative study of open surgery versus medical therapy and few single-group studies of surgery exist. These did not provide sufficient evidence to adequately assess the relative difference in outcomes between the interventions.

Table 7 Surgery versus medical therapy alone for the treatment of ARAS: Strength of evidence

Outcome | SoE Grade | Design No. Studies | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Other Issues | Finding
Death | Insufficient | RCT: 1 NRCS: 0 Cohort Surgery: 4 Cohort Rx: 10 | Low | RCT: Direct Other: Indirect | Single comparative study | Imprecise | Undetected | Important^*^ | Comparative study: No statistically significant difference or MCID Single arm studies: Broadly similar
RRT | Insufficient | RCT: 1 NRCS: 0 Cohort Surgery: 2 Cohort Rx: 10 Case: 2 | Low | RCT: Direct Other: Indirect | Single comparative study | Imprecise | Undetected | Important^*^ | RCT: No statistically significant difference or MCID Single arm studies: Broadly similar Case: RRT averted with revascularization
CV event | Insufficient | RCT: 0 NRCS: 0 Cohort Surgery: 1 Cohort Rx: 10 Case: 2 | Low | RCT: none Other: indirect | No comparative studies | Imprecise | Undetected | Important^*^ | RCT: No data Single arm studies: Unclear Case: CV symptoms resolved immediately with revascularization
Kidney function | Insufficient | RCT: 1 NRCS: 0 Cohort Surgery: 1 Cohort Rx: 10 Case: 2 | Low | RCT: Direct Other: Indirect | Single comparative study | Imprecise | Undetected | Important^*^ | RCT: No difference Single arm studies: PTRAS better Case: Improvement with revascularization
BP control | Insufficient | RCT: 1 NRCS: 0 Cohort Surgery: 4 Cohort Rx: 10 Case: 2 | Low | RCT: Direct Other: Indirect | Single comparative study | Imprecise | Undetected | Important^*^ | RCT: No difference Single arm studies: PTRAS better Case: Improvement with revascularization
Adverse events | Insufficient | RCT: 1 NRCS: 0 Cohort Surgery: 3 Cohort Rx: 10 Case: 2 | Low | RCT: Direct Other: Indirect | Single comparative study | Imprecise | Suspected | Important^‡^ | RCT: No data Single arm studies: reported only in surgery studies

AE = adverse events, ARAS = atherosclerotic renal artery stenosis, BP = blood pressure, Case = case reports, CV = cardiovascular, MCID = minimum clinically important difference, N = number of study participants, No. = number, NRCS = nonrandomized comparative studies, PTRAS = percutaneous transluminal renal angioplasty with stent placement, RCT = randomized controlled trials, RRT = renal replacement therapy, Rx = medical therapy alone, SoE = strength of evidence.

* RCT of limited applicability to typical patients choosing PTRAS. Single comparative study only. Single arm studies analyzed poorly comparable cohorts of patients.

‡ Noncomparable adverse events between surgery and medical therapy. Poorly reported.

As summarized in Table 8, for each outcomes, the strength of evidence is insufficient or low regarding the relative benefit of PTRAS versus surgery for patients with ARAS, across both comparative and noncomparative studies. A single RCT and three poorly reported NRCS evaluated this comparison. There is low strength of evidence of no difference in mortality or BP control between the two revascularization approaches, but inadequate evidence for other outcomes of interest.

Table 8 Angioplasty with stent versus surgery for the treatment of ARAS: Strength of evidence

Outcome | SoE Grade | Design No. Studies | Study Limitations | Directness | Consistency | Precision | Reporting Bias | Other Issues | Finding
Death | Low | RCT: 1 NRCS: 2 Cohort PTRAS: 31 Cohort Surgery: 4 | Low | RCT: Direct Other: Indirect | RCT: consistent All: consistent | Imprecise | Undetected | Important^*^ | Comparative studies: No statistically significant difference, but MCID in RCT (OR=0.63; 95% CI 0.16, 2.53) Single arm studies: Broadly similar
RRT | Low | RCT: 0 NRCS: 1 Cohort PTRAS: 31 Cohort Surgery: 2 Case: 20 | Low | RCT: Direct Other: Indirect | RCT: no data All: consistent | Imprecise | Undetected | Important^*^ | Comparative: No difference Single arm studies: Broadly similar Case: Similar outcomes
CV event | Low | RCT: 0 NRCS: 0 Cohort PTRAS: 31 Cohort Surgery: 1 Case: 20 | Low | RCT: none Other: Indirect | RCT: no data All: inadequate data | Imprecise | Undetected | Important^*^ | Comparative: No difference Single arm studies: Unclear Case: Similar outcomes
Kidney function | Low | RCT: 1 NRCS: 1 Cohort PTRAS: 31 Cohort Surgery: 1 Case: 20 | Low | RCT: Direct Other: Indirect | RCT: consistent All: inconsistent | Imprecise | Undetected | Important^*^ | Comparative: No difference Single arm studies: PTRAS better Case: Similar improvement
BP control | Low | RCT: 1 NRCS: 2 Cohort PTRAS: 31 Cohort Surgery: 4 Case: 20 | Low | RCT: Direct Other: Indirect | RCT: consistent All: inconsistent | Imprecise | Undetected | Important^*^ | Comparative: No difference Single arm studies: PTRAS better Case: Similar improvement
Adverse events | Low | RCT: 1 NRCS: 1 Cohort PTRAS: 31 Cohort Surgery: 3 | Low | RCT: Direct Other: Indirect | Consistent | Imprecise | Suspected | Important^‡^ | Severe AE rare with both interventions, requiring additional procedures.

AE = adverse events, ARAS = atherosclerotic renal artery stenosis, BP = blood pressure, Case = case reports, CV = cardiovascular, MCID = minimum clinically important difference, N = number of study participants, No. = number, NRCS = nonrandomized comparative studies, PTRAS = percutaneous transluminal renal angioplasty with stent placement, RCT = randomized controlled trials, RRT = renal replacement therapy, Rx = medical therapy alone, SoE = strength of evidence.

* RCTs of limited applicability to typical patients choosing PTRAS. NRCSs inadequately adjusted. Single arm studies analyzed poorly comparable cohorts of patients.

† Congestive heart failure/pulmonary edema symptoms and angina

‡ Noncomparable adverse events between PTRAS and medical therapy. Poorly reported.