# References

1 Safian RD, Textor SC. Renal-artery stenosis. N Engl J Med. Feb. 8. 2001;344(6):431-42. [doi: 10.1056/NEJM200102083440607]. [pmid: 11172181].
2 de Mast Q, Beutler JJ. The prevalence of atherosclerotic renal artery stenosis in risk groups: a systematic literature review. J Hypertens. Jul. 2009;27(7):1333-40. [doi: 10.1097/HJH.0b013e328329bbf4]. [pmid: 19365285].
3 United States Renal Data System (USRDS). 1997. Annual Data Report. Bethesda, MD. U.S. Department of Health and Human Services, National Institutes of Health, National Institute of Diabetes and Digestive and Kidney Diseases.
4 Taylor AT, Fletcher JW, Nally JV, et al. Procedure guideline for diagnosis of renovascular hypertension. Society of Nuclear Medicine. J Nucl Med. Jul. 1998;39(7):1297-302. [pmid: 9669414].
5 James PA, Oparil S, Carter BL, et al. 2014 evidence-based guideline for the management of high blood pressure in adults: report from the panel members appointed to the Eighth Joint National Committee (JNC 8). Jama. Feb. 5. 2014;311(5):507-20. [doi: 10.1001/jama.2013.284427]. [pmid: 24352797].
6 K/DOQI clinical practice guidelines on hypertension and antihypertensive agents in chronic kidney disease. Am J Kidney Dis. May. 2004;43(5 Suppl 1):S1-290. [pmid: 15114537].
7 Chrysochou C, Foley RN, Young JF, et al. Dispelling the myth: the use of renin-angiotensin blockade in atheromatous renovascular disease. Nephrol Dial Transplant. Apr. 2012;27(4):1403-9. [doi: 10.1093/ndt/gfr496]. [pmid: 21993376].
8 Rundback JH, Sacks D, Kent KC, et al. Guidelines for the reporting of renal artery revascularization in clinical trials. American Heart Association. Circulation. Sep. 17. 2002;106(12):1572-85. [pmid: 12234967].
9 Ritchie J, Green D, Chrysochou C, et al. High-risk clinical presentations in atherosclerotic renovascular disease: prognosis and response to renal artery revascularization. Am J Kidney Dis. Feb. 2014;63(2):186-97. [doi: 10.1053/j.ajkd.2013.07.020]. [pmid: 24074824].
10 Parikh SA, Shishehbor MH, Gray BH, White CJ, Jaff MR. SCAI expert consensus statement for renal artery stenting appropriate use. Catheter Cardiovasc Interv. Dec. 1. 2014;84(7):1163-71. [doi: 10.1002/ccd.25559]. [pmid: 25138644].
11 Kalra PA, Guo H, Gilbertson DT, et al. Atherosclerotic renovascular disease in the United States. Kidney Int. Jan. 2010;77(1):37-43. [doi: 10.1038/ki.2009.406]. [pmid: 19865075].
12 Liang P, Hurks R, Bensley RP, et al. The rise and fall of renal artery angioplasty and stenting in the United States, 1988–2009. J Vasc Surg. Nov. 2013;58(5):1331-8 e1. [doi: 10.1016/j.jvs.2013.04.041]. [pmid: 23810297].
13 Balk E, Raman G. Comparative Effectiveness of Management Strategies for Renal Artery Stenosis: 2007 Update. Rockville (MD). 2007.
14 Balk E, Raman G, Chung M, et al. Comparative Effectiveness of Management Strategies for Renal Artery Stenosis. Rockville (MD). 2006.
15 Higgins JPT, Altman DG, Sterne JAC. Cochrane Statistical Methods Group and the Cochrane Bias Methods Group. Assessing Risk of Bias in Included Studies. Cochrane Handbook for Systematic Reviews of Interventions. John Wiley & Sons, Ltd. 2008:187-241.
16 Wells GA, Shea B, O’Connell D, Peterson J, Welch V, Losos M, Tugwell P. The Newcastle-Ottawa Scale (NOS) for assessing the quality of nonrandomised studies in meta-analyses. http://www.ohri.ca/programs/clinical_epidemiology/oxford.asp. Accessed on November 12, 2014. 2014.
17 King MT. A point of minimal important difference (MID): a critique of terminology and methods. Expert Rev Pharmacoecon Outcomes Res. Apr. 2011;11(2):171-84. [doi: 10.1586/erp.11.9]. [pmid: 21476819].
18 McAlister AM, O’Connor AM, Wells G, Grover SA, Laupacis A. When should hypertension be treated? The different perspectives of Canadian family physicians and patients. CMAJ. Aug. 22. 2000;163(4):403-8. [pmid: 10976255].
19 Cooper CJ, Murphy TP, Cutlip DE, et al. Stenting and medical therapy for atherosclerotic renal-artery stenosis. N Engl J Med. Jan. 2. 2014;370(1):13-22. [doi: 10.1056/NEJMoa1310753]. [pmid: 24245566].
20 Wheatley K, Ives N, Gray R, et al. Revascularization versus medical therapy for renal-artery stenosis. N Engl J Med. Nov. 12. 2009;361(20):1953-62. [doi: 10.1056/NEJMoa0905368]. [pmid: 19907042].
21 Berkman ND, Lohr KN, Ansari M, McDonagh M, Balk E, Whitlock E, Reston J, Bass E, Butler M, Gartlehner G, Hartling L, Kane R, McPheeters M, Morgan L, Morton SC, Viswanathan M, Sista P, Chang S. Grading the Strength of a Body of Evidence When Assessing Health Care Interventions for the Effective Health Care Program of the Agency for Healthcare Research and Quality: An Update. Methods Guide for Comparative Effectiveness Reviews. (Prepared by the RTI-UNC Evidence-based Practice Center under Contract No. 290-2007-10056-I). Rockville, MD. Agency for Healthcare Research and Quality. 2013.
22 Arthurs Z, Starnes B, Cuadrado D, Sohn V, Cushner H, Andersen C. Renal artery stenting slows the rate of renal function decline. J Vasc Surg. Apr. 2007;45(4):726-31. discussion 31–2. [doi: 10.1016/j.jvs.2006.12.026]. [pmid: 17398382].
23 Balzer KM, Pfeiffer T, Rossbach S, et al. Prospective randomized trial of operative vs interventional treatment for renal artery ostial occlusive disease (RAOOD). J Vasc Surg. Mar. 2009;49(3):667-74. discussion 74–5. [doi: 10.1016/j.jvs.2008.10.006]. [pmid: 19135837].
24 Bax L, Woittiez AJ, Kouwenberg HJ, et al. Stent placement in patients with atherosclerotic renal artery stenosis and impaired renal function: a randomized trial. Ann Intern Med. Jun. 16. 2009;150(12):840-8. W150. 1. [pmid: 19414832].
25 Cianci R, Martina P, Borghesi F, et al. Revascularization versus medical therapy for renal artery stenosis: antihypertensive drugs and renal outcome. Angiology. Jan. 2011;62(1):92-9. [doi: 10.1177/0003319710371615]. [pmid: 20547539].
26 Crutchley TA, Pearce JD, Craven TE, et al. Clinical utility of the resistive index in atherosclerotic renovascular disease. J Vasc Surg. Jan. 2009;49(1):148-55. 55 e1. 3. discussion 55. [doi: 10.1016/j.jvs.2008.08.008]. [pmid: 18951751].
27 de Donato G, Setacci C, Chisci E, Setacci F, Palasciano G. Renovascular hypertension. 8 years experience of a vascular surgery centre. J Cardiovasc Surg (Torino). Aug. 2007;48(4):403-9. [pmid: 17653002].
28 Dichtel LE, Gurevich D, Rifkin B, Varma P, Concato J, Peixoto AJ. Renal artery revascularization in patients with atherosclerotic renal artery stenosis and impaired renal function: conservative management versus renal artery stenting. Clin Nephrol. Aug. 2010;74(2):113-22. [pmid: 20630131].
29 Hanzel G, Balon H, Wong O, Soffer D, Lee DT, Safian RD. Prospective evaluation of aggressive medical therapy for atherosclerotic renal artery stenosis, with renal artery stenting reserved for previously injured heart, brain, or kidney. Am J Cardiol. Nov. 1. 2005;96(9):1322-7. [doi: 10.1016/j.amjcard.2005.06.081]. [pmid: 16253607].
30 Kalra PA, Chrysochu C, Green D, et al. The benefit of renal artery stenting in patients with atheromatous renovascular disease and advanced chronic kidney disease. Catheter Cardiovasc Interv. Jan. 1. 2010;75(1):1-10. [doi: 10.1002/ccd.22290]. [pmid: 19937777].
31 Kane GC, Xu N, Mistrik E, Roubicek T, Stanson AW, Garovic VD. Renal artery revascularization improves heart failure control in patients with atherosclerotic renal artery stenosis. Nephrol Dial Transplant. Mar. 2010;25(3):813-20. [doi: 10.1093/ndt/gfp393]. [pmid: 19666661].
32 Marcantoni C, Zanoli L, Rastelli S, Tripepi G, Matalone M, Mangiafico S, Capodanno D, Scandura S, Di Landro D, Tamburino C, Zoccali C, Castellino P. Effect of renal artery stenting on left ventricular mass: a randomized clinical trial. Am J Kidney Dis. Jul. 2012;60(1):39-46. [doi: 10.1053/j.ajkd.2012.01.022]. [pmid: 22495466].
32a Scarpioni R, Michieletti E, Cristinelli L, et al. Atherosclerotic renovascular disease: medical therapy versus medical therapy plus renal artery stenting in preventing renal failure progression: the rationale and study design of a prospective, multicenter and randomized trial (NITER). J Nephrol. 2005;18(4):423-8. [pmid: 16245247].
32b Scarpioni R, Michieletti E, Pavone L, et al. Atherosclerotic renovascular disease (ARVD): Medical therapy plus renal artery stenting (PTRS), compared with medical therapy alone, do not offer more chances in preventing cardio-vascular (CV) or renal events. Preliminary results of a prospective, multicenter and randomized trial (Conference Abstract). World Congress of Nephrology. May 22, 2009. Milan, Italy. 2009.
33 Sofroniadou S, Kassimatis T, Srirajaskanthan R, Reidy J, Goldsmith D. Long-term safety and efficacy of renin-angiotensin blockade in atherosclerotic renal artery stenosis. Int Urol Nephrol. Oct. 2012;44(5):1451-9. [doi: 10.1007/s11255-011-0091-y]. [pmid: 22127407].
34 Uzzo RG, Novic AC, Goormastic M, Mascha E, Pohl M. Medical versus surgical management of atherosclerotic renal artery stenosis. Transplant Proc. Mar. 2002;34(2):723-5. [pmid: 12009679].
34a Schwarzwalder U, Hauk M, Zeller T. RADAR - A randomised, multi-centre, prospective study comparing best medical treatment versus best medical treatment plus renal artery stenting in patients with haemodynamically relevant atherosclerotic renal artery stenosis. Trials. 2009;10:60. [pmid: 19635148].
34b Zeller T. RADAR – Data of a prematurely terminated randomized, multi-centre, prospective study comparing best medical treatment versus best medical treatment plus renal artery stenting in patients with hemodynamically relevant atherosclerotic renal artery stenosis (Conference Abstract). Vasa. 2013;42(Suppl 84):40. [pmid: 23385225].
35 Ziakka S, Ursu M, Poulikakos D, Papadopoulos C, Karakasis F, Kaperonis N, Papagalanis N. Predictive factors and therapeutic approach of renovascular disease: four years’ follow-up. Ren Fail. 2008;30(10):965-70. [doi: 10.1080/08860220802389334]. [pmid: 19016147].
36 Patel VI, Conrad MF, Kwolek CJ, LaMuraglia GM, Chung TK, Cambria RP. Renal artery revascularization: outcomes stratified by indication for intervention. J Vasc Surg. Jun. 2009;49(6):1480-9. [doi: 10.1016/j.jvs.2009.02.004]. [pmid: 19497511].
37 Messerli FH, Bangalore S, Makani H, Rimoldi SF, Allemann Y, White CJ, Textor S, Sleight P. Flash pulmonary oedema and bilateral renal artery stenosis: the Pickering syndrome. Eur Heart J. Sep. 2011;32(18):2231-5. [doi: 10.1093/eurheartj/ehr056]. [pmid: 21406441].
38 Levey AS, Stevens LA, Schmid CH, et al. new equation to estimate glomerular filtration rate. Ann Intern Med. May. 5. 2009;150(9):604-12. [pmid: 19414839].
39 Murphy TP, Cooper CJ, Cutlip DE, et al. Roll-in experience from the Cardiovascular Outcomes with Renal Atherosclerotic Lesions (CORAL) study. J Vasc Interv Radiol. Apr. 2014;25(4):511-20. [doi: 10.1016/j.jvir.2013.09.018]. [pmid: 24325931].
40 Bruno RM, Daghini E, Versari D, et al. Predictive role of renal resistive index for clinical outcome after revascularization in hypertensive patients with atherosclerotic renal artery stenosis: a monocentric observational study. Cardiovasc Ultrasound. 2014;12:9. [doi: 10.1186/1476-7120-12-9]. [pmid: 24555729].
41 Iannone LA, Underwood PL, Nath A, et al. Effect of primary balloon expandable renal artery stents on long-term patency, renal function, and blood pressure in hypertensive and renal insufficient patients with renal artery stenosis. Cathet Cardiovasc Diagn. Mar. 1996;37(3):243-50. [doi: 10.1002/(SICI)1097-0304(199603)37:3<243::AID-CCD3>3.0.CO;2-C]. [pmid: 8974797].
42 Blum U, Krumme B, Flugel P, Gabelmann A, Lehnert T, Buitrago-Tellez C, Schollmeyer P, Langer M. Treatment of ostial renal-artery stenoses with vascular endoprostheses after unsuccessful balloon angioplasty. N Engl J Med. Feb. 13. 1997;336(7):459-65. [doi: 10.1056/NEJM199702133360702]. [pmid: 9017938].
43 Harden PN, MacLeod MJ, Rodger RS, et al. Effect of renal-artery stenting on progression of renovascular renal failure. Lancet. Apr. 19. 1997;349(9059):1133-6. [pmid: 9113012].
44 White CJ, Ramee SR, Collins TJ, Jenkins JS, Escobar A, Shaw D. Renal artery stent placement: utility in lesions difficult to treat with balloon angioplasty. J Am Coll Cardiol. Nov. 15. 1997;30(6):1445-50. [pmid: 9362400].
45 Gross CM, Kramerr J, Waigand J, Uhlich F, Olthoff H, Luft FC, Dietz R. Ostial renal artery stent placement for atherosclerotic renal artery stenosis in patients with coronary artery disease. Cathet Cardiovasc Diagn. Sep. 1998;45(1):1-8. [pmid: 9736342].
46 van de Ven PJ, Kaatee R, Beutler JJ, et al. Arterial stenting and balloon angioplasty in ostial atherosclerotic renovascular disease: a randomised trial. Lancet. Jan. 23. 1999;353(9149):282-6. [doi: 10.1016/S0140-6736(98)04432-8]. [pmid: 9929021].
47 Rocha-Singh KJ, Mishkel GJ, Katholi RE, et al. Clinical predictors of improved long-term blood pressure control after successful stenting of hypertensive patients with obstructive renal artery atherosclerosis. Catheter Cardiovasc Interv. Jun. 1999;47(2):167-72. [doi: 10.1002/(SICI)1522-726X(199906)47:2<167::AID-CCD7>3.0.CO;2-R]. [pmid: 10376497].
48 Dangas G, Laird JR, Mehran R, Lansky AJ, Mintz GS, Leon MB. Intravascular ultrasound-guided renal artery stenting. J Endovasc Ther. Jun. 2001;8(3):238-47. [doi: 10.1583/1545-1550(2001)008<0238:IUGRAS>2.0.CO;2]. [pmid: 11491257].
49 Dorros G, Jaff M, Mathiak L, He T. Multicenter Palmaz stent renal artery stenosis revascularization registry report: four-year follow-up of 1,058 successful patients. Catheter Cardiovasc Interv. Feb. 2002;55(2):182-8. [pmid: 11835644].
50 Gill-Leertouwer TC, Gussenhoven EJ, Deinum J, van Dijk LC, Pattynama PM. Shrinkage of the distal renal artery 1 year after stent placement as evidenced with serial intravascular ultrasound. Br J Radiol. Nov. 2002;75(899):879-83. [pmid: 12466252].
51 Ramos F, Kotliar C, Alvarez D, Baglivo H, Rafaelle P, Londero H, Sanchez R, Wilcox CS. Renal function and outcome of PTRA and stenting for atherosclerotic renal artery stenosis. Kidney Int. Jan. 2003;63(1):276-82. [doi: 10.1046/j.1523-1755.2003.00734.x]. [pmid: 12472793].
52 Gill KS, Fowler RC. Atherosclerotic renal arterial stenosis: clinical outcomes of stent placement for hypertension and renal failure. Radiology. Mar. 2003;226(3):821-6. [doi: 10.1148/radiol.2263011244]. [pmid: 12601202].
53 Gray BH, Olin JW, Childs MB, Sullivan TM, Bacharach JM. Clinical benefit of renal artery angioplasty with stenting for the control of recurrent and refractory congestive heart failure. Vasc Med. 2002;7(4):275-9. [pmid: 12710843].
54 Henry M, Henry I, Klonaris C, Polydorou A, Rath P, Lakshmi G, Rajacopal S, Hugel M. Renal angioplasty and stenting under protection: the way for the future?. Catheter Cardiovasc Interv. Nov. 2003;60(3):299-312. [doi: 10.1002/ccd.10669]. [pmid: 14571477].
55 Kennedy DJ, Colver WR, Brewster PS, Ankenbrandt M, Burket MW, Nemeth AS, Khuder SA, Thomas WJ, Shapiro JI, Cooper CJ. Renal insufficiency as a predictor of adverse events and mortality after renal artery stent placement. Am J Kidney Dis. Nov. 2003;42(5):926-35. [pmid: 14582036].
56 Zeller T, Frank U, Muller C, Burgelin K, Sinn L, Horn B, Flugel PC, Schwarzwalder U, Roskamm H, Neumann FJ. Stent-supported angioplasty of severe atherosclerotic renal artery stenosis preserves renal function and improves blood pressure control: long-term results from a prospective registry of 456 lesions. J Endovasc Ther. Apr. 2004;11(2):95-106. [doi: 10.1583/03-1062.1]. [pmid: 15056029].
57 Rocha-Singh K, Jaff MR, Rosenfield K. Evaluation of the safety and effectiveness of renal artery stenting after unsuccessful balloon angioplasty: the ASPIRE-2 study. J Am Coll Cardiol. Sep. 6. 2005;46(5):776-83. [doi: 10.1016/j.jacc.2004.11.073]. [pmid: 16139124].
58 Sapoval M, Zahringer M, Pattynama P, et al. Low-profile stent system for treatment of atherosclerotic renal artery stenosis: the GREAT trial. J Vasc Interv Radiol. Sep. 2005;16(9):1195-202. [doi: 10.1097/01.RVI.0000171765.67665.D3]. [pmid: 16151060].
59 Zeller T, Rastan A, Kliem M, et al. Impact of carbon coating on the restenosis rate after stenting of atherosclerotic renal artery stenosis. J Endovasc Ther. Oct. 2005;12(5):605-11. [doi: 10.1583/05-1599MR.1]. [pmid: 16212462].
60 Rivolta R, Bassi C, Stradiotti P, Paparella M. Stenting of renal artery stenosis: is it beneficial in chronic renal failure?. J Nephrol. Nov–Dec. 2005;18(6):749-54. [pmid: 16358234].
61 Tsao CR, Lee WL, Liu TJ, Chen YT, Ting CT. Delicate percutaneous renal artery stenting minimizes postoperative renal injury and protects kidney in patients with severe atherosclerotic renal artery stenosis and impaired renal function. Int Heart J. Nov. 2005;46(6):1061-72. [pmid: 16394602].
62 Holden A, Hill A, Jaff MR, Pilmore H. Renal artery stent revascularization with embolic protection in patients with ischemic nephropathy. Kidney Int. Sep. 2006;70(5):948-55. [doi: 10.1038/sj.ki.5001671]. [pmid: 16837918].
63 Girndt M, Kaul H, Maute C, Kramann B, Kohler H, Uder M. Enhanced flow velocity after stenting of renal arteries is associated with decreased renal function. Nephron Clin Pract. 2007;105(2):c84-9. [doi: 10.1159/000097866]. [pmid: 17164562].
64 Ruchin PE, Baron DW, Wilson SH, Boland J, Muller DW, Roy PR. Long-term follow-up of renal artery stenting in an Australian population. Heart Lung Circ. Apr. 2007;16(2):79-84. [doi: 10.1016/j.hlc.2006.12.008]. [pmid: 17317314].
65 Goncalves JA, Amorim JE, Soares Neto MM, Ribeiro AB, Lima VC. Clinical efficacy of percutaneous renal revascularization with stent placement in atherosclerotic renovascular disease. Arq Bras Cardiol. Jan. 2007;88(1):85-90. [pmid: 17364124].
66 Baril DT, Lookstein RA, Jacobs TS, Won J, Marin ML. Durability of renal artery stents in patients with transrenal abdominal aortic endografts. J Vasc Surg. May. 2007;45(5):915-20. discussion 20–1. [doi: 10.1016/j.jvs.2007.01.022]. [pmid: 17391902].
67 Zahringer M, Sapoval M, Pattynama PM, et al. Sirolimus-eluting versus bare-metal low-profile stent for renal artery treatment (GREAT Trial): angiographic follow-up after 6 months and clinical outcome up to 2 years. J Endovasc Ther. Aug. 2007;14(4):460-8. [doi: 10.1583/1545-1550(2007)14[460:SVBLSF]2.0.CO;2]. [pmid: 17696619].
68 Cooper CJ, Haller ST, Colyer W, et al. Embolic protection and platelet inhibition during renal artery stenting. Circulation. May. 27. 2008;117(21):2752-60. [doi: 10.1161/CIRCULATIONAHA.107.730259]. [pmid: 18490527].
69 Lekston A, Chudek J, Gasior M, et al. Comparison of early and long-term impact of percutaneous transluminal renal artery angioplasty alone or with brachytherapy on renal function in patients with reno-vascular hypertension. Kardiol Pol. Oct. 2008;66(10):1061-6. discussion 7–8. [pmid: 19006027].
70 Rocha-Singh K, Jaff MR, Lynne Kelley E. Renal artery stenting with noninvasive duplex ultrasound follow-up: 3-year results from the RENAISSANCE renal stent trial. Catheter Cardiovasc Interv. Nov. 15. 2008;72(6):853-62. [doi: 10.1002/ccd.21749]. [pmid: 19006254].
71 Rastan A, Krankenberg H, Muller-Hulsbeck S, et al. Improved renal function and blood pressure control following renal artery angioplasty: the renal artery angioplasty in patients with renal insufficiency and hypertension using a dedicated renal stent device study (PRECISION). EuroIntervention. Aug. 2008;4(2):208-13. [pmid: 19110785].
72 Leesar MA, Varma J, Shapira A, et al. Prediction of hypertension improvement after stenting of renal artery stenosis: comparative accuracy of translesional pressure gradients, intravascular ultrasound, and angiography. J Am Coll Cardiol. Jun. 23. 2009;53(25):2363-71. [doi: 10.1016/j.jacc.2009.03.031]. [pmid: 19539148].
73 Jokhi PP, Ramanathan K, Walsh S, Fung AY, Saw J, Fox RS, Zalunardo N, Buller CE. Experience of stenting for atherosclerotic renal artery stenosis in a cardiac catheterization laboratory: technical considerations and complications. Can J Cardiol. Aug. 2009;25(8):e273-8. [pmid: 19668788].
74 Sapoval M, Tamari I, Goffette P, Downes M, Senechal Q, Fanelli F, Reimer P, Negaiwi Z, De Cassin P, Heye S, Korobov V, Tsetis D, Abada H. One year clinical outcomes of renal artery stenting: the results of ODORI Registry. Cardiovasc Intervent Radiol. Jun. 2010;33(3):475-83. [doi: 10.1007/s00270-009-9733-1]. [pmid: 19908091].
75 Beck AW, Nolan BW, De Martino R, et al. Predicting blood pressure response after renal artery stenting. J Vasc Surg. Feb. 2010;51(2):380-5. discussion 5. [doi: 10.1016/j.jvs.2009.08.088]. [pmid: 19939607].
76 Trani C, Tommasino A, Giammarinaro M, et al. Renal artery stenting in patients with chronic ischemic heart disease. Catheter Cardiovasc Interv. Jul. 1. 2010;76(1):26-34. [doi: 10.1002/ccd.22525]. [pmid: 20578190].
77 Kobo O, Hammoud M, Makhoul N, Omary H, Rosenschein U. Screening, diagnosis, and treatment of renal artery stenosis by percutaneous transluminal renal angioplasty with stenting. Isr Med Assoc J. Mar. 2010;12(3):140-3. [pmid: 20684176].
78 Staub D, Zeller T, Trenk D, et al. Use of B-type natriuretic peptide to predict blood pressure improvement after percutaneous revascularisation for renal artery stenosis. Eur J Vasc Endovasc Surg. Nov. 2010;40(5):599-607. [doi: 10.1016/j.ejvs.2010.07.013]. [pmid: 20739200].
79 Kawarada O, Yokoi Y, Morioka N, Shiotani S, Higashimori A. Cardiac benefits of renal artery stenting. EuroIntervention. Sep. 2010;6(4):485-91. [doi: 10.4244/EIJ30V6I4A81]. [pmid: 20884436].
80 Rzeznik D, Przewlocki T, Kablak-Ziembicka A, Kozanecki A, Roslawiecka A, Lach J, Tracz W, Podolec P. Effect of renal artery revascularization on left ventricular hypertrophy, diastolic function, blood pressure, and the one-year outcome. J Vasc Surg. Mar. 2011;53(3):692-7. [doi: 10.1016/j.jvs.2010.09.054]. [pmid: 21129903].
81 Rocha-Singh KJ, Novack V, Pencina M, D’Agostino R, Ansel G, Rosenfield K, Jaff MR. Objective performance goals of safety and blood pressure efficacy for clinical trials of renal artery bare metal stents in hypertensive patients with atherosclerotic renal artery stenosis. Catheter Cardiovasc Interv. Nov. 1. 2011;78(5):779-89. [doi: 10.1002/ccd.23055]. [pmid: 21648052].
82 Valluri A, Severn A, Chakraverty S. Do patients undergoing renal revascularization outside of the ASTRAL trial show any benefit? Results of a single-centre observational study. Nephrol Dial Transplant. Feb. 2012;27(2):734-8. [doi: 10.1093/ndt/gfr356]. [pmid: 21765186].
83 Mannarino A, Spatoliatore G, Caselli GM, Toti G, Becherelli P. Different outcomes of atherosclerotic renal artery stenosis managed with stenting: results from a cohort study. Ren Fail. 2012;34(2):142-8. [doi: 10.3109/0886022X.2011.646807]. [pmid: 22260219].
84 Trani C, Porto I, Tommasino A, Giammarinaro M, Burzotta F, Niccoli G, Leone AM, Coroleu SF, Cautilli G, Mazzari MA, Schiavoni G, Crea F. Baseline inflammatory status and long-term changes in renal function after percutaneous renal artery stenting: a prospective study. Int J Cardiol. Aug. 10. 2013;167(3):1006-11. [doi: 10.1016/j.ijcard.2012.03.078]. [pmid: 22503569].
85 Jaff MR, Bates M, Sullivan T, Popma J, Gao X, Zaugg M, Verta P. Significant reduction in systolic blood pressure following renal artery stenting in patients with uncontrolled hypertension: results from the HERCULES trial. Catheter Cardiovasc Interv. Sep. 1. 2012;80(3):343-50. [doi: 10.1002/ccd.24449]. [pmid: 22511402].
86 Bersin RM, Ansel G, Rizzo A, Bob Smouse H, Sinha S, Sachar R, Dave R, Weinstoc S, Feldman R, Roubin GS. Nine-month results of the REFORM study: a prospective, single-arm, multicenter clinical study of the safety and effectiveness of the Formula balloon-expandable stent for treatment of renal artery stenosis. Catheter Cardiovasc Interv. Aug. 1. 2013;82(2):266-73. [doi: 10.1002/ccd.24481]. [pmid: 22581488].
87 Christie JW, Conlee TD, Craven TE, Hurie JB, Godshall CJ, Edwards MS, Hansen KJ. Early duplex predicts restenosis after renal artery angioplasty and stenting. J Vasc Surg. Nov. 2012;56(5):1373-80. discussion 80. [doi: 10.1016/j.jvs.2012.05.067]. [pmid: 23083664].
88 Cianci R, Martina P, Gigante A, Di Donato D, Polidori L, Presta P, Labbadia R, Amoroso D, Zaccaria A, Barbano B, Fuiano G. Predictor factors for renal outcome in renal artery stenosis. Eur Rev Med Pharmacol Sci. Feb. 2013;17(4):507-12. [pmid: 23467950].
89 Chrysant GS, Bates MC, Sullivan TM, Bachinsky WB, Popma JJ, Peng L, Omran HL, Jaff MR. Proper patient selection yields significant and sustained reduction in systolic blood pressure following renal artery stenting in patients with uncontrolled hypertension: long-term results from the HERCULES trial. J Clin Hypertens (Greenwich). Jul. 2014;16(7):497-503. [doi: 10.1111/jch.12341]. [pmid: 24909590].
90 Weinberg I, Keyes MJ, Giri J, Rogers KR, Olin JW, White CJ, Jaff MR. Blood pressure response to renal artery stenting in 901 patients from five prospective multicenter FDA-approved trials. Catheter Cardiovasc Interv. Mar. 1. 2014;83(4):603-9. [doi: 10.1002/ccd.25263]. [pmid: 24307609].
91 Laird JR, Rundback J, Zierler RE, Becker GJ, O’Shaughnessy C, Shuck JW, Allie D, Olin JW, Cantwell-Gab K, Thomas J. Safety and efficacy of renal artery stenting following suboptimal renal angioplasty for de novo and restenotic ostial lesions: results from a nonrandomized, prospective multicenter registry. J Vasc Interv Radiol. May. 2010;21(5):627-37. [doi: 10.1016/j.jvir.2010.01.019]. [pmid: 20304680].
92 Accessed by Weinberg 2014 on August 21, 2013. URL no longer valid.
93 Losito A, Errico R, Santirosi P, Lupattelli T, Scalera GB, Lupattelli L. Long-term follow-up of atherosclerotic renovascular disease. Beneficial effect of ACE inhibition. Nephrol Dial Transplant. Aug. 2005;20(8):1604-9. [doi: 10.1093/ndt/gfh865]. [pmid: 15870215].
94 Safak E, Wilke C, Derer W, Busjahn A, Gross M, Moeckel M, Mueller DN, Luft FC, Dechend R. Long-term follow-up of patients with atherosclerotic renal artery disease. J Am Soc Hypertens. Jan–Feb. 2013;7(1):24-31. [doi: 10.1016/j.jash.201212.001]. [pmid: 23321402].
95 Silva VS, Martin LC, Franco RJ, Carvalho FC, Bregagnollo EA, Castro JH, Gavras I, Gavras H. Pleiotropic effects of statins may improve outcomes in atherosclerotic renovascular disease. Am J Hypertens. Oct. 2008;21(10):1163-8. [doi: 10.1038/ajh.2008.249]. [pmid: 18670414].
96 Webster J, Marshall F, Abdalla M, Dominiczak A, Edwards R, Isles CG, Loose H, Main J, Padfield P, Russell IT, Walker B, Watson M, Wilkinson R. Randomised comparison of percutaneous angioplasty vs continued medical therapy for hypertensive patients with atheromatous renal artery stenosis. Scottish and Newcastle Renal Artery Stenosis Collaborative Group. J Hum Hypertens. May. 1998;12(5):329-35. [pmid: 9655655].
97 Hackam DG, Duong-Hua ML, Mamdani M, Li P, Tobe SW, Spence JD, Garg AX. Angiotensin inhibition in renovascular disease: a population-based cohort study. Am Heart J. Sep. 2008;156(3):549-55. [doi: 10.1016/j.ahj.2008.05.013]. [pmid: 18760140].
98 Hackam DG, Wu F, Li P, Austin PC, Tobe SW, Mamdani MM, Garg AX. Statins and renovascular disease in the elderly: a population-based cohort study. Eur Heart J. Mar. 2011;32(5):598-610. [doi: 10.1093/eurheartj/ehq452]. [pmid: 21156722].
99 Alhadad A, Ahle M, Ivancev K, Gottsater A, Lindblad B. Percutaneous transluminal renal angioplasty (PTRA) and surgical revascularisation in renovascular disease--a retrospective comparison of results, complications, and mortality. Eur J Vasc Endovasc Surg. Feb. 2004;27(2):151-6. [doi: 10.1016/j.ejvs.2003.10.009]. [pmid: 14718896].
100 Cherr GS, Hansen KJ, Craven TE, Edwards MS, Ligush J, Levy PJ, Freedman BI, Dean RH. Surgical management of atherosclerotic renovascular disease. J Vasc Surg. Feb. 2002;35(2):236-45. [pmid: 11854720].
101 Galaria II, Surowiec SM, Rhodes JM, Illig KA, Shortell CK, Sternbach Y, Green RM, Davies MG. Percutaneous and open renal revascularizations have equivalent long-term functional outcomes. Ann Vasc Surg. Mar. 2005;19(2):218-28. [doi: 10.1007/s10016-004-0165-8]. [pmid: 15735947].
102 Demming T, Frey N, Langer C. Pickering syndrome: high-risk stenting of a renal artery stenosis in a multimorbid patient presenting with progressive congestive heart failure. Clin Res Cardiol. Aug. 2013;102(8):615-7. [doi: 10.1007/s00392-013-0579-9]. [pmid: 23673780].
103 Ishida R, Komaki K, Nakayama M, Sonomura K, Nakanouchi T, Naya Y, Mori Y, Kusaba T. Percutaneous transluminal renal angioplasty remarkably improved severe hypertension and renal function in a patient with renal artery stenosis and postrenal kidney failure. Ren Fail. 2013;35(4):551-5. [doi: 10.3109/0886022X.2013.773844]. [pmid: 23473081].
104 Noce A, Canale MP, Durante O, di Villahermosa SM, Rovella V, Fiorini F, Parolini C, Di Daniele N. Refractory hypertension and rapidly progressive renal failure due to bilateral renal artery stenosis: case report. Arch Ital Urol Androl. Dec. 2012;84(4):249-52. [pmid: 23427756].
105 Alonso JV, Caballero RM, Lopera EL, Avalos FC, Navarro C. Flash pulmonary edema and renal artery stenosis: pickering syndrome. Am J Emerg Med. Feb. 2013;31(2):454 e1-4. [doi: 10.1016/j.ajem.2012.07.016]. [pmid: 22944546].
106 Navaravong L, Ali RG, Giugliano GR. Acute renal artery occlusion: making the case for renal artery revascularization. Cardiovasc Revasc Med. Nov–Dec. 2011;12(6):399-402. [doi: 10.1016/j.carrev.201105.002]. [pmid: 21855421].
107 George T, Latchumanadhas K, Abraham G, Devapriya S, Ezhilan J, Mullasari AS. Successful hybrid procedure in flash pulmonary edema. Saudi J Kidney Dis Transpl. May. 2011;22(3):531-3. [pmid: 21566313].
108 Li WS, Gilchrist M, Robertson S, Isles C. Bilateral renovascular disease with cardiorenal failure: intervene early or watch and wait?. QJM. Jun. 2012;105(6):567-9. [doi: 10.1093/qjmed/hcr068]. [pmid: 21558176].
109 Kindo M, Gerelli S, Billaud P, Mazzucotelli JP. Flash pulmonary edema in an orthotopic heart transplant recipient. Interact Cardiovasc Thorac Surg. Feb. 2011;12(2):323-5. [doi: 10.1510/icvts.2010.254755]. [pmid: 21118836].
110 Islam MA, Rosenfield K, Maree AO, Patel PM, Jaff MR. Percutaneous revascularization of occluded renal arteries in the setting of acute renal failure. Vasc Med. Nov. 2009;14(4):365-9. [doi: 10.1177/1358863X09103200]. [pmid: 19808722].
111 Kanamori H, Toma M, Fukatsu A. Improvement of renal function after opening occluded atherosclerotic renal arteries. J Invasive Cardiol. Sep. 2009;21(9):E171-4. [pmid: 19726830].
112 Dippel EJ. Percutaneous renal intervention utilizing distal embolic protection. J Invasive Cardiol. Aug. 2009;21(8):423-4. [pmid: 19652259].
113 Dziemianko I, Kuzinar J, Dorobisz A, Zynek-Litwin M, Garcarek J, Klinger M. Critical bilateral renal arterial stenosis presenting as cardio-renal syndrome: isolated ultrafiltration preceding percutaneous transluminal revascularization. Congest Heart Fail. Mar–Apr. 2009;15(2):96-8. [doi: 10.1111/j.1751-7133.200900052.x]. [pmid: 19379457].
114 Campbell JE, John M, Bates MC. Surgical rescue and restoration of renal function in an anuric renal failure patient: a case report. W V Med J. Jan–Feb. 2008;104(1):22-4. [pmid: 18335782].
115 Wykrzykowska JJ, Williams M, Laham RJ. Stabilization of renal function, improvement in blood pressure control and pulmonary edema symptoms after opening a totally occluded renal artery. J Invasive Cardiol. Jan. 2008;20(1):E26-9. [pmid: 18174627].
116 Chrysochou C, Sinha S, Chalmers N, Kalra PR, Kalra PA. Anuric acute renal failure and pulmonary oedema: a case for urgent action. Int J Cardiol. Feb. 6. 2009;132(1):e31-3. [doi: 10.1016/j.ijcard.2007.07.121]. [pmid: 18045711].
117 Kuznetsov E, Schifferdecker B, Jaber BL, Soukas P, Liangos O. Recovery of acute renal failure following bilateral renal artery angioplasty and stenting. Clin Nephrol. Jul. 2007;68(1):32-7. [pmid: 17703833].
118 Kumar SC. Bilateral renal artery stenosis presenting as flash pulmonary edema. J Assoc Physicians India. Aug. 2006;54:651-4. [pmid: 16941797].
119 George PV, Pati PK, Chandy ST, Gupta S, Samuel V. Recanalization of a single functioning kidney. Indian Heart J. Nov–Dec. 2005;57(6):741-3. [pmid: 16521653].
120 Komatsu S, Ohara T, Takewa M, Takahashi S, Nomamoto T, Kamata T, Nishiuchi K, Kobayashi Y, Kodama K. Nonobstructive angioscopy in patient with atherosclerotic renal artery stenosis. Journal of Cardiology Cases. 2014;9(1):18-21.
121 Hirsch AT, Haskal ZJ, Hertzer NR, et al. ACC/AHA 2005 Practice Guidelines for the management of patients with peripheral arterial disease (lower extremity, renal, mesenteric, and abdominal aortic): a collaborative report from the American Association for Vascular Surgery/Society for Vascular Surgery, Society for Cardiovascular Angiography and Interventions, Society for Vascular Medicine and Biology, Society of Interventional Radiology, and the ACC/AHA Task Force on Practice Guidelines (Writing Committee to Develop Guidelines for the Management of Patients With Peripheral Arterial Disease): endorsed by the American Association of Cardiovascular and Pulmonary Rehabilitation; National Heart, Lung, and Blood Institute; Society for Vascular Nursing; TransAtlantic Inter-Society Consensus; and Vascular Disease Foundation. Circulation. Mar. 21. 2006;113(11):e463-654. [doi: 10.1161/circulationaha.106.174526]. [pmid: 16549646].
122 Rooke TW, Hirsch AT, Misra S, et al. 2011 ACCF/AHA focused update of the guideline for the management of patients with peripheral artery disease (updating the 2005 guideline). Vasc Med. Dec. 2011;16(6):452-76. [doi: 10.1177/1358863x11424312]. [pmid: 22128043].
123 Rooke TW, Hirsch AT, Misra S, Sidawy AN, Beckman JA, Findeiss L, Golzarian J, Gornik HL, Jaff MR, Moneta GL, Olin JW, Stanley JC, White CJ, White JV, Zierler RE. Management of patients with peripheral artery disease (compilation of 2005 and 2011 ACCF/AHA Guideline Recommendations): a report of the American College of Cardiology Foundation/American Heart Association Task Force on Practice Guidelines. J Am Coll Cardiol. Apr. 9. 2013;61(14):1555-70. [doi: 10.1016/j.jacc.2013.01.004]. [pmid: 23473760].
124 Jones NJ, Bates ER, Chetcuti SJ, Lederman RJ, Grossman PM. Usefulness of translesional pressure gradient and pharmacological provocation for the assessment of intermediate renal artery disease. Catheter Cardiovasc Interv. Sep. 2006;68(3):429-34. [doi: 10.1002/ccd.20697]. [pmid: 16892443].
125 Williamson E, Morley R, Lucas A, Carpenter J. Propensity scores: from naive enthusiasm to intuitive understanding. Stat Methods Med Res. Jun. 2012;21(3):273-93. [doi: 10.1177/0962280210394483]. [pmid: 21262780].
126 Rubin DB. Estimating causal effects from large data sets using propensity scores. Ann Intern Med. Oct. 15. 1997;127(8 Pt 2):757-63. [pmid: 9382394].
127 Dahabreh IJ, Sheldrick RC, Paulus JK, Chung M, Varvarigou V, Jafri H, Rassen JA, Trikalinos TA, Kitsios GD. Do observational studies using propensity score methods agree with randomized trials? A systematic comparison of studies on acute coronary syndromes. Eur Heart J. Aug. 2012;33(15):1893-901. [doi: 10.1093/eurheartj/ehs114]. [pmid: 22711757].
128 MEDCAC Meeting 7/18/2007: Percutaneous Transluminal Angioplasty (PTA) and Stenting of the Renal Arteries. Baltimore, MD. Centers for Medicare & Medicaid Services. 2007. http://www.cms.gov/medicare-coverage-database/details/medcac-meeting-details.aspx?MEDCACId=39.
129 IOM (Institute of Medicine). Clinical Practice Guidelines We Can Trust. Washington, DC. The National Academies Press. 2011.