# Methods

## Technical Expert Panel

This report on the comparison of aggressive medical therapy, percutaneous transluminal renal angioplasty with stent placement (PTRAS), and surgical revascularization for the management of atherosclerotic renal artery stenosis (ARAS)is based on a systematic review of the literature. We convened a Technical Expert Panel (TEP), which included nephrologists, invasive cardiologists and radiologists with expertise in RAS, vascular surgeons, the medical officer from the CORAL study (in the Division of Cardiovascular Sciences at NHLBI), and an FDA representative (in the Division of Cardiovascular Devices). The TEP includes experts nominated by the Society of Interventional Radiology, the Kidney and Urology Foundation of America, the National Kidney Foundation, and the American College of Cardiology Foundation/American Heart Association. The TEP provided input to help refine the protocol, identify important issues, and define parameters for the review of evidence. The TEP was also asked to suggest additional studies for evaluation by the Evidence-based Practice Center (EPC).

## Search Strategy

A comprehensive search of the scientific literature was conducted to identify relevant studies addressing the Key Questions that have been published since the original RAS reports, which had a final search date of April 23, 2007. We searched MEDLINE®, the Cochrane Central Trials Registry® and Cochrane Database of Systematic Reviews®, and Embase (2007 – March 16, 2016). The reference lists of existing systematic reviews were hand-searched, and the TEP was asked to identify additional studies. With the dual goals of increasing the sensitivity of the search and of assessing the risk of potential publication bias, we searched the “grey literature” for relevant completed studies in the FDA database (with assistance from our FDA TEP representative), clinicaltrials.gov, the World Health Organization International Clinical Trials Registry Platform (ICTRP) (http://apps.who.int/trialsearch/default.aspx), and conference proceedings from 2012 through 2014 for the National Kidney Foundation, the American Society of Nephrology, the Kidney and Urology Foundation, the American Urological Association, and the Society of Vascular Surgery. In our searches, we combined terms for renal artery stenosis, renal hypertension, and renal vascular disease, limited to adult humans and relevant research designs, including case reports and series (see Appendix A for the complete search strategies). Furthermore, we solicited studies via Scientific Information Packets from manufacturers (one study was sent to us, which was already known to us).

## Study Selection

We assessed titles and/or abstracts of citations identified from literature searches for inclusion, using the criteria described below. Full-text articles of potentially relevant abstracts were retrieved and a second review for inclusion was conducted by reapplying the inclusion criteria. Both abstract and full-text screening was conducted in duplicate with conflicts resolved by reconciliation with the whole research team. All rejected full-text articles were confirmed by the project lead.

Studies included in the original reports were reassessed for inclusion based on the current eligibility criteria. Those that remain eligible are fully included in the current update.

## Population and Condition of Interest

We included studies of adults (≥18 years) with ARAS, as defined by the study authors, whether unilateral, bilateral, or in patients with a solitary functioning kidney. We excluded studies in which >20 percent of patients had fibromuscular dysplasia, arteritis-associated RAS, embolic or thrombotic stenosis, or other nonatherosclerotic stenosis. We excluded studies of patients with previous surgical or angioplasty interventions for RAS (i.e., with restenosis or instent stenosis) or with RAS in the setting of a transplanted kidney, renal artery aneurysms (requiring repair), or concurrent cancer (including renal cell carcinoma). We allowed studies that performed simultaneous repair of aortic disease (e.g., aneurysm) only if the RAS was the primary indication for surgery and the aortic disease surgery was incidental.

## Interventions of Interest

The primary interventions of interest were “aggressive medical therapy”—defined as antihypertensive drugs, antilipid (lipid lowering) drugs, and antiplatelet drugs—and PTRAS. However, the review covers a broader range of interventions that are currently used in practice, including a range of medical therapies alone, PTRAS, and open surgical revascularization.

Specifically, we included studies of any medical intervention or set of medical interventions in patients who did not have revascularization. In particular, use (and tolerance) of ACEi or ARB was of interest.

We included studies of PTRAS (where ≥80% of patients had stent placement). We excluded “drive-by” angioplasty—renal artery angioplasty done at the time of coronary angiography (or angioplasty) in patients who do not have previously known RAS. There was consensus among the TEP members that the currently accepted invasive intervention for ARAS in the large majority of patients in the United States is PTRAS. In contrast with the original reports, given advances in revascularization interventions, studies of angioplasty without stent placement are not included.

We included studies of any renal artery revascularization, with the caveats about concomitant aortic surgery noted above. We excluded studies that used endografts or endarterectomy that included the renal arteries to prevent or repair renal artery damage due to the aortic surgery.

We excluded “natural history” studies that did not evaluate a specific intervention, but instead followed patients regardless of treatment. This restriction is in contrast with the original reports.

## Comparators of Interest

Given the known paucity of comparative studies, we included both noncomparative (single group) studies and comparative studies that compared any of the three interventions of interest.

## Outcomes of Interest

With the TEP, we identified clinical and surrogate outcomes of greatest interest regarding the comparison of medical and revascularization interventions. It was agreed that given the chronicity of the disease process, only long-term clinical outcomes were of interest, along with adverse effects at any time. For the purposes of this report, “long-term” was defined as at least 6 months, but results at 12 months or more are of greater interest.

Outcomes of interest included:

- Mortality, all cause
- Kidney function
  ○ Event (e.g., need for renal replacement therapy)
  ○ Categorical (e.g., better/worse)
  ○ Continuous (i.e., glomerular filtration rate, creatinine clearance, serum creatinine [SCr])
- Blood pressure (BP)
  ○ Event (e.g., hypertensive crisis)
  ○ Categorical (e.g., better/worse)
  ○ Continuous BP
  ○ Medication need (e.g., number of antihypertensive drugs used)
  ○ Angiotensin converting enzyme inhibitor (ACEi) or angiotensin receptor blocker (ARB) tolerance
- Congestive heart failure (CHF) events, including flash pulmonary edema (including hospitalization)
- Other cardiovascular events (cardiac, cerebrovascular, peripheral vascular)
- Adverse events (e.g., postprocedure in-hospital or 30-day deaths, peri- and postprocedure events, drug reactions)

For Key Questions 2 and 3, we also included subgroup and regression analyses that compared preintervention patient and intervention characteristics and outcomes of interest. These included, but were not limited to, patient demographics; clinical, imaging, laboratory, and anatomic characteristics of the RAS; and treatment variables, such as periprocedural medications, type of stent, use of distal protection devices, or other adjunct techniques. We extracted details from studies that reported analyses on the likelihood of outcomes based on the presence of patient or procedure related variables (e.g., that compared death rates among patients with high or low kidney function). We did not extract data related to comparisons of average values of the variables in patients with dichotomized outcomes (e.g., that reported mean age of those who lived and those who died). These latter analyses were not considered to be sufficiently helpful for a clinician making a decision of which intervention to recommend to a given patient.

When outcomes were reported at multiple time points, we included those that occurred at 6 months, 12 months, and each subsequent year, so long as there were at least 10 subjects being evaluated.

## Years of Intervention of Interest

The original report restricted studies to those in which patients were treated after publication of the Fifth Report of the Joint National Committee on Prevention, Detection, Evaluation, and Treatment of High Blood Pressure (JNC-5) in 1993, when emphasis was placed on attempting to achieve lower BP levels than earlier sets of recommendations, together with recommendations for use of antilipid and antiplatelet treatments, and increasing use of ACEi and ARB. The current update maintains this time period for when patients were evaluated and treated.

## Study Designs of Interest

The basic parameters were maintained for intervention-specific study design eligibility criteria are the same as in the previous report.

### Comparative Studies

For studies that compared two or more of the three intervention categories (medical therapy, PTRAS, surgical), we included studies of any study design, whether prospective or retrospective, as long as at least 10 subjects were evaluated in each group. Any comparative study that failed to meet eligibility criteria (e.g., angioplasty without stent versus comparator) was also examined to determine whether individual groups of subjects were eligible for review (e.g., the medical therapy arm).

### Medical Therapy Only Studies

For single-group medical intervention studies, we included only prospective studies of antihypertensive, antilipid, or antiplatelet medications with at least 10 subjects who received treatment.

### Angioplasty With Stenting Studies

For single-group PTRAS studies, we included only prospective studies with at least 30 subjects who received treatment. The majority of available articles on ARAS have reported on groups of subjects who received PTRAS; therefore a higher sample size threshold was used. Furthermore, it was known from the original EPC reports and from an early screen of the literature that there is a large volume of PTRAS cohort studies. Therefore, it was agreed to restrict the review to the (theoretically) less biased prospective studies.

### Surgical Revascularization Studies

For single-group surgical studies, we included prospective or retrospective studies. We included prospective studies with at least 10 subjects who had surgery. Because there are relatively few prospective surgical studies, we also included retrospective studies with at least 100 subjects.

### Case Reports

To address the issue of patients excluded from essentially all comparative and almost all single group studies because they have acute decompensation (and, therefore, “require” revascularization), we included case reports and case series of patients with acute decompensation as defined by acute symptoms with acute worsening of kidney function, new-onset flash pulmonary edema, CHF, or peripheral edema, and/or recent-onset uncontrollable HTN. We selected the 20 most recently published eligible case reports (through March 2015, prior to submission of the draft report), regardless of the intervention(s) employed.

## Data Extraction

Data extraction was conducted into customized forms in the Systematic Review Data Repository (SRDR) online system (http://srdr.ahrq.gov) designed to capture all elements relevant to the Key Questions. These included population characteristics, including description of patients’ RAS, descriptions of the interventions analyzed, descriptions of relevant outcomes, enrolled and analyzed sample sizes, study design features, funding sources, results (including adverse events), and risk of bias assessment. We captured methodological descriptions and results of subgroup or predictor (regression) analyses for any preintervention factor. Analyses based on postintervention factors (such as stent restenosis or followup BP) were excluded. When multiple models were reported, the most adjusted model was extracted. The forms were tested on several studies and revised as necessary.

All eligible studies from the original reports were entered into SRDR based on the original completed data extraction forms and, when necessary, the full-text articles.

## Risk of Bias Assessment

We based the methodological quality of each study on predefined criteria. We used the Cochrane risk of bias tool for randomized controlled trials (RCT)15—which asks about risk of selection bias, performance bias, detection bias, attrition bias, reporting bias, and other potential biases—and selected questions from the Newcastle Ottawa Scale16 about comparability of cohorts, representativeness of the population, and adjustment for different lengths of followup. All eligible studies from the original reports were reevaluated for methodological quality in the same way as new studies.

## Data Synthesis

All included studies were summarized in narrative form and in summary tables that tabulate the important features of the study populations, design, intervention, outcomes, and results. Meta-analysis was considered, but given the large clinical and study design heterogeneity of the randomized and observational comparative studies (primarily in terms of indications for intervention) and the large heterogeneity in outcome definitions and results of the single arm studies, meta-analysis was not deemed to be appropriate. Studies are summarized semiquantitatively and, for PTRAS and medical therapy studies, graphically.

The report uses the same basic structure as the original reports. Namely, it is organized by study design first (comparative studies, each of the single intervention analyses, and case reports), then by Key Question and outcome, within each study design section. Studies are summarized semiquantitatively and, for PTRAS and medical therapy studies, graphically.

## Minimal Clinically Important Differences

The concept of minimal clinically important difference (MCID) was considered to help users of this report to determine the comparative value of treatments. However, no useful guidance for determining thresholds for MCID was found. Several members of the TEP were sceptical about the concept in regards to RAS management given the current state of knowledge about RAS management and the complexity of RAS and its interactions with concurrent diseases (including cardiac disease and chronic kidney disease). MCIDs for individual patients require contextualization for their particular circumstances, medical history, and preferences. The TEP did not suggest MCIDs for outcomes of interest, except possibly statistically significant differences (i.e., an MCID of 0). We sought guidance from the Agency for healthcare and Research Quality (AHRQ) staff, other EPC review leads, AHRQ reports and guidance documents, clinical practice guidelines, PubMed and internet searches. Guidelines for kidney disease (www.kdigo.org, www.kdoqi.org) and hypertension (JNC-8^5^) do not consider or suggest MCID for continuous or categorical outcomes. Two publications were illuminating on the subject. In a critique, Madeline King commented “There is no universal [MCID], despite the appeal of the notion. Indeed, for a particular patient-reported outcome instrument or scale, the [MCID] is not an immutable characteristic, but may vary by population and context. At both the group and individual level, the [MCID] may depend on the clinical context and decision at hand, the baseline from which the patient starts, and whether they are improving or deteriorating.”17 In a survey of Canadian physicians and patients with HTN, median MCIDs for major cardiovascular events ranged from 1 to 6 percent (absolute risk reduction), depending on predicted risk, with up to one-quarter of patients stating a preference for an MCID of 0 (they would want treatment “even if there was no benefit”).18 Notably, patients expressed a statistically significantly larger MCID than physicians; patients were less likely to want treatment given a risk scenario.

The CORAL study used a 25 percent reduction in a composite of cardiovascular and kidney events for their power calculation. The researchers’ opinion was that “this threshold of effect size (25%) is a clinically reasonable goal for an expensive and invasive treatment. A smaller effect on a composite outcome, with an expensive and invasive therapy, is unlikely to be sufficiently compelling to justify such treatment.”19 This implies that the hazard ratio (HR) should be ≤0.75 to be clinically important. The ASTRAL “was designed to detect a reduction of 20 percent in the mean slope of [1/SCr].”20 However, few studies reported slope in change in kidney function and the trials reported heterogeneous kidney function measures (slope of kidney function change, with various measures; absolute kidney function change, with various measures; categorical changes, variously defined).

With these various considerations in mind, the decision was made to use an arbitrarily determined MCID of 25 percent (translating into HR≤0.75) for clinical outcomes. No MCID was used for kidney function and BP measures. The MCIDs were considered in summary conclusions about comparative effectiveness and in strength of evidence determination (see next).

## Grading the Strength of Evidence

As per the AHRQ Methods Guide,21 we assigned an overall grade describing the body of evidence for each Key Question that was based the number of studies, their study designs, the study limitations (i.e., risk of bias), the directness of the evidence to the Key Questions, the consistency of study results, the precision of any estimates of effect (taking into account MCID), the likelihood of reporting bias, other limitations, and the overall findings across studies. Limitations in any of these factors downgraded the strength of evidence among the categories high, moderate, or low, or we made a determination that there was insufficient evidence to estimate an effect. The grading was done by the team as a whole. RCTs and well-adjusted comparative observational studies were deemed to provide stronger evidence than poorly- or unadjusted comparative studies, which in turn provided stronger evidence than noncomparative studies. Issues related to the domains of study limitations, directness, consistency, reporting bias, and other limitations could decrease the strength of evidence, as described in the Methods Guide.

## Peer Review

A draft version of this report was reviewed by a panel of invited expert reviewers and the general public. The reviewers included experts in nephrology, cardiology, interventional radiology, and vascular surgery. These experts were either directly invited by the EPC or offered comments through a public review process. Revisions of the draft were made, where appropriate, based on their comments. The draft and final reports were also reviewed by the Task Order Officer and an Associate Editor from another EPC. However, the findings and conclusions are those of the authors, who are responsible for the contents of the report.