# Introduction

## Background

Renal artery stenosis (RAS) is defined as the narrowing of the lumen of the renal artery. Atherosclerosis accounts for 90 percent of cases of RAS and usually involves the ostium and proximal third of the main renal artery and the perirenal aorta.1 Atherosclerotic RAS (ARAS) is a progressive disease that may occur alone or in combination with hypertension (HTN) and ischemic kidney disease. ARAS is becoming increasingly common because of atherosclerosis in an aging population with increasing prevalence of diabetes, obesity, hyperlipidemia, aortoiliac occlusive disease, coronary artery disease, and HTN. Based on a recent systematic review,2 the prevalence of RAS among the general hypertensive population is unknown, but among people with clinical characteristics of renovascular HTN—including severe HTN, therapy-resistant HTN, HTN-onset at a young age, recent onset of HTN, or presence of an abdominal bruit—RAS prevalence (generally defined as stenosis ≥50%) is 14.1 percent (95% confidence interval [CI] 12.7 to 15.8%).2 Among people with diabetes mellitus and HTN, the prevalence is 20.0 percent (95% CI 15.4 to 25.5%) and among people undergoing coronary angiography, the prevalence is 10.5 percent (95% CI 9.8 to 11.2%). In the United States, 11 to 14 percent of new patients entering dialysis programs were found to have ARAS from 1996 to 2001.^3^

Optimal strategies for evaluating patients suspected of having RAS remain unclear. Patients with moderate to high risk atherovascular diseases who present with uncontrolled HTN or unexplained abnormal kidney function tests are generally evaluated for RAS.1, 4, 5 A reduction in estimated glomerular filtration rate of at least 30 percent from baseline following the introduction of angiotensin converting enzyme inhibitor (ACEi) or angiotensin-receptor blocker (ARB) therapy is a clinical clue suggestive of RAS.6 However, it is important to note that the primary reason for diagnosing ARAS is to set the patient up for revascularization, since medical management of ARAS is identical to medical management of other patients with difficult to control HTN who are at increased risk of cardiovascular events and kidney damage. A variety of physiological studies to assess the renin-angiotensin system and perfusion studies to assess renal blood flow are available. However, the clinical clues can be nonspecific and physiologic studies have limited usefulness in ARAS, especially among the elderly. Initial evaluation often relies on imaging techniques such as duplex ultrasonography, magnetic resonance angiography, computed tomographic angiography, and radionuclide renal scanning. However, magnetic resonance and computed tomographic angiography may also be contraindicated in patients with kidney insufficiency and can be compromised by the presence of metallic implants such as aortic endografts. The value of ultrasonography may depend on operator’s experience, body habitus, the presence of bowel gas, and may be less reliable in visualizing distal segments of renal arteries. Currently, catheter angiography remains the de facto reference standard for evaluating the degree of stenosis in RAS, but carries risk of contrast-induced nephropathy and the risks of any invasive vascular procedure. However, angiography is not a true reference standard since it intrinsically has measurement error that may vary by equipment and operator. The accuracy of angiography to measure degree of stenosis has not been compared to autopsy or pathology confirmation of the lesion. Furthermore, the link between angiographic stenosis and translesional pressure drop, the more direct measure of the hemodynamic significance of the stenosis.

The goals of therapy are improvement in uncontrolled HTN, preservation or salvage of kidney function, prevention or treatment of cardiac syndromes such as pulmonary edema or unstable angina, and ultimately improved survival. Combination therapy with multiple antihypertensive agents, typically including ACEi or ARBs, calcium channel blockers, and/or beta blockers, are frequently prescribed with a goal of normalizing blood pressure (BP). Statins are commonly prescribed to lower low density lipoprotein cholesterol, and antiplatelet agents, such as aspirin or clopidogrel, are prescribed to reduce thrombosis. This “triple therapy” (antihypertensive, antilipid, and antiplatelet medications) approach is much more intensive than is typically prescribed for patients with primary HTN. Among patients treated with medical therapy alone, there might be a risk for deterioration of kidney function since the treatments do not reduce the stenosis and thus cannot substantially improve blood flow to the kidneys. Based on studies found for this review, as described in more detail in the Results, about 10 percent or more of patients with RAS treated medically require renal replacement therapy (RRT) within about 5 years. RAS patients treated medically also appear to be at relatively high risk for cardiovascular disease (e.g., one study reported that 12 percent of patients had a new cardiovascular event at about 3 years7). ACEi and ARBs are effective in controlling renovascular HTN in 86 to 92 percent of these patients, but a loss of kidney function due to reduction in transcapillary filtration pressure might, in some patients, result in acute or chronic kidney disease.1 Thus, both treatment options (percutaneous transluminal renal angioplasty with stent placement [PTRAS] and medical therapy alone) have risks. Whether loss of kidney function and other clinical outcomes differ based on treatment choice is a question of interest.

Indications for and timing of revascularization for ARAS are topics of considerable debate. The American Heart Association lists three clinical criteria for revascularization: 1) HTN (accelerated, refractory, or malignant [HTN with coexistent end-organ damage]), 2) preservation of kidney function, and 3) cardiac syndromes (recurrent “flash” pulmonary edema or unstable angina with significant RAS).8 By one prospective study’s estimate, at diagnosis of ARAS about half of people meet at least one of these criteria (refractory HTN, rapid kidney function decline, or flash pulmonary edema).9 The decision to proceed with revascularization must be weighed against the morbidity and mortality risks of the invasive procedures. Per expert opinion, the Society for Cardiovascular Angiography and Interventions also includes “hemodynamically significant” stenoses to warrant consideration for revascularization, including angiographic stenosis of 50 to 70 percent—only with an abnormal translesional pressure gradient—or stenosis greater than 70 percent.10 Renal artery revascularization may provide immediate improvement in kidney function and BP; however, as with all invasive interventions, it may also result in procedural complications of bleeding, dissection, or embolization in some patients.

The current standard for revascularization in most patients is PTRAS across the stenosis. Angioplasty without stent placement is rarely employed due to the high rate of restenosis. Placement of renal artery stents can also resolve dissections, minimize stenosis recoil and restenosis, and correct translesional pressure gradients. Most patients undergoing renal artery revascularization have been exposed to many years of relative kidney ischemia and poorly controlled HTN. Thus, revascularization may not have substantial long-term clinical benefit due to prior kidney and cardiovascular damage and ongoing atherosclerotic processes that requires continuation of medical management.

Even after revascularization, patients generally continue triple therapy with antihypertensive agents, antiplatelet agents, and statins, though fewer (or lower dose) antihypertensive agents may be necessary to control BP. Furthermore, patients may be better able to tolerate ACEi or ARBs after revascularization. Particularly for patients with diabetes or with congestive heart failure (CHF), the ability to use ACEi or ARBs can be renoprotective and reduce cardiovascular disease.

Revascularization by surgical reconstruction is generally reserved for patients with complicated renal artery anatomy or who require pararenal aortic reconstructions for aortic aneurysms or severe aortoiliac occlusive disease. The percentage of patients undergoing surgical revascularization has dropped precipitously over time. In the U.S. Medicare population, among people having renal revascularization, 33 percent had surgical revascularization in 1992; by 2004, this had dropped to 1.5 percent.11 The total number of PTRAS performed in the outpatient setting remained stable from 2005 to 2009 ((3.8 and 3.7 per 100,000, respectively). The number of inpatient PTRAS procedures for the management of RAS has decreased significantly after 2006. (7.9 per 100,000 in 2006 to 4.2 per 100,000 in 2009).12

The Tufts Evidence-based Practice Center (EPC) conducted a Comparative Effectiveness Review of management strategies for RAS in 2006 (with an update in 2007).13, 14 The review evaluated medical therapies (without revascularization), angioplasty (with or without stent, but focusing primarily on with stent), surgical revascularization, and natural history studies. The review included 68 studies, but none of the studies evaluated the principal question of interest—namely, the relative effects of intensive medical therapy and PTRAS. The review concluded that the evidence did not support one treatment approach over another for the general population of people with ARAS. There was weak or inadequate evidence for most interventions and outcomes and whether any clinical or intervention characteristics affect outcomes.

Since the original EPC review, the two major then-ongoing trials of PTRAS versus medical therapy alone, the Cardiovascular Outcomes in Renal Atherosclerotic Lesions (CORAL) and the Angioplasty and Stenting for Renal Artery Lesions (ASTRAL) trials, have been published. These trials have influenced clinical decisionmaking regarding management of ARAS. Without clear benefit on BP or kidney function in these trials, indications for interventional treatment have been interpreted to be limited. The trials also failed to identify specific subpopulations that may benefit from revascularization. As a result, since their publication, fewer patients are referred for procedures, and medical therapy alone, using antihypertensive agents, antiplatelet agents, and statins, has become the standard of care. Importantly though, the trials had difficulties recruiting patients, mostly because clinicians and patients often had strong preferences for or against undergoing revascularization that precluded their enrollment for randomized treatment. Therefore, questions remain about the applicability of these trials and the true value of PTRAS for patients who have (or whose clinicians have) a strong preference for PTRAS.

A subset of patients effectively excluded from the trials includes patients with acute decompensation related to ARAS. These patients have rapidly declining kidney function with possible oliguria or anuria, flash pulmonary edema, and/or intractable malignant HTN. It is generally understood that these patients usually benefit from rapid revascularization, which must be undertaken before the kidneys are permanently injured. However, less well understood is which patients may or may not benefit from revascularization.

Thus, controversy remains regarding optimal strategies for evaluation and management of patients with ARAS. In particular, a fuller understanding in needed of which patients are most likely to benefit from revascularization and for which continued aggressive medical therapy alone may be most appropriate.

## Scope and Key Questions

This report summarizes the evidence evaluating the comparative effectiveness and safety of PTRAS, surgical revascularization, and medical therapy in the treatment of ARAS, particularly after long-term followup. Key Questions addressed in this report remain unchanged from the original reviews and are as follows:

1. For patients with ARAS in the modern management era (i.e., since JNC-5 in 1993), what is the evidence on the effects of aggressive medical therapy (i.e., antihypertensive, antiplatelet, and antilipid treatment) compared to PTRAS on long-term clinical outcomes (at least 6 months) including BP control, preservation of kidney function, flash pulmonary edema, other cardiovascular events, and survival?
  1a What are the patient characteristics, including etiology, predominant clinical presentation, and severity of stenosis, in the studies?
  1b What adverse events and complications have been associated with aggressive medical therapy or PTRAS?
2. What clinical, imaging, laboratory and anatomic characteristics are associated with improved or worse outcomes when treating with either aggressive medical therapy alone or PTRAS?
3. What treatment variables are associated with improved or worse outcomes of PTRAS, including periprocedural medications, type of stent, use of distal protection devices, or other adjunct techniques?

Note: The Fifth Joint National Committee (JNC-5) on Detection, Evaluation, and Treatment of High Blood Pressure guidelines (1993) marked a substantial change from previous guidelines in treatment recommendations for HTN, including more aggressive BP targets. This time point also marks when ACEi began to be used more routinely for patients with severe HTN.

## Analytic Framework

We applied the analytic framework depicted in Figure 1 to answer the Key Questions in the evaluation of the treatment modalities for ARAS. This framework addressed relevant clinical outcomes. It also examined clinical predictors that affected treatment outcomes. While evidence from high quality randomized controlled trials (RCT) was preferred, these data were rare, so nonrandomized and uncontrolled studies were used to augment the evidence.

Figure 1 Analytic framework for evaluating the effectiveness and safety of treatments for renal artery stenosis

GFR = glomerular filtration rate; KQ = Key Question; RRT = renal replacement therapy; SBP/DBP/MAP = systolic, diastolic, and mean arterial pressures; SCr = serum creatinine.

* Usually a combination of antihypertensive medications, antilipid medications (statins), and antiplatelet medications.

Figure 1: Analytic Framework. This figure depicts the key questions within the context of the PICO. In general, the figure illustrates how treatment interventions (medication therapy, angioplasty with stent, or surgery) affect clinical outcomes (death, renal replacement therapy, cardiovascular events, and pulmonary edema), either directly or through intermediate outcomes (kidney function—both GFR and serum creatinine—and improvement, and blood pressure—including hypertension, systolic, diastolic, and mean arterial pressures, and antihypertensive medication requirements). It also shows that the various interventions may lead to adverse events (including 30 day mortality, vascular damage, acute kidney injury, and other complications). The associations between treatments and outcomes and harms are addressed primarily by key question 1. Key questions 2 and 3 also evaluate these associations but in the context of key potential effect modifiers. For key question 2, these are patient characteristics, including clinical, imaging, laboratory, and anatomic characteristics. For key question 3, these are treatment characteristics including periprocedural medications, type of stent, use of distal protection devices, or other adjunct techniques.

### Types of Participants

The population of interest for this report is adults with ARAS that is of sufficient severity to warrant aggressive management, either due to resistant HTN, evidence of reduced kidney function, or the high likelihood of poor outcomes based on such factors as CHF severity or frequency, threatened renal mass, diastolic dysfunction. Because of the variety of techniques used to diagnose and define RAS, the definitions used by study authors were accepted. Patients with ARAS commonly also have aortic disease, which must be treated simultaneously. The original 2006 report was restricted to studies that performed only renal artery procedures. However, it is increasingly common that subclinical aortic disease is treated at the same time as the renal artery lesion in a single invasive intervention. Therefore, this report aims to include studies of all ARAS treatments, regardless of whether an aortic procedure was also conducted, as long as the primary indication for the intervention was the ARAS. Studies of patients with severe aortic disease requiring surgery who also had a concomitant renal artery stent placed were excluded since the ARAS was not the primary indication for the intervention.

### Types of Interventions

The primary interventions of interest are aggressive medical therapy, PTRAS, and open vascular repairs. However, this review covers any medical (noninvasive) intervention, PTRAS, and any open vascular surgery whose primary indication is amelioration of RAS. This review does not update the literature on angioplasty without stent or natural history studies.

### Types of Outcome Measures

The primary outcomes of interest include long-term (6 months or more) mortality, kidney function, HTN, cardiovascular disease, and related outcomes, in addition to adverse events and complications (including 30-day mortality).

### Types of Studies

The ideal study to answer the Key Questions would be a RCT directly comparing the primary interventions of interest. However, given the paucity of RCTs and of nonrandomized comparative studies, this review evaluates studies of cohorts of patients who received one treatment (or one set of treatments) without a control group.

### Case Reports

Due to concerns that the trial and observational studies do not adequately address outcomes in patients with ARAS who have acute decompensation, this review also includes a summary of the more recent case reports of patients treated for acute decompensation, including malignant HTN or acutely uncontrollable HTN, flash pulmonary edema, acute kidney injury, and recent-onset end-stage renal disease requiring dialysis.