# Technical Expert Panel

In designing the study questions and methodology at the outset of this report, the EPC consulted several technical and content experts. Broad expertise and perspectives were sought. Divergent and conflicted opinions are common and perceived as healthy scientific discourse that results in a thoughtful, relevant systematic review. Therefore, in the end, study questions, design, methodologic approaches, and/or conclusions do not necessarily represent the views of individual technical and content experts.

Technical Experts must disclose any financial conflicts of interest greater than $10,000 and any other relevant business or professional conflicts of interest. Because of their unique clinical or content expertise, individuals with potential conflicts may be retained. The TOO and the EPC work to balance, manage, or mitigate any potential conflicts of interest identified.

The list of Technical Experts who provided input to this report follows:

- Richard Cambria, M.D.
  Harvard Medical School
  Cambridge, MA
- Kenneth Cavanaugh, Ph.D.^*^
  * Provided input on Draft Report.
  U.S Food and Drug Administration
  Silver Spring, MD
- Matthew Corriere, M.D., M.S.^*^
  Wake Forest University School of Medicine
  Winston-Salem, NC
- Joseph Nally, Jr., M.D.^*^
  Cleveland Clinic
  Cleveland, OH
- Jeffrey Olin, M.D.
  Icahn School of Medicine at Mount Sinai
  New York, NY
- Diane Reid, M.D.^*^
  National Institutes of Health
  Bethesda, MD
- John H. Rundback, M.D., FAHA, FSVM, FSIR^*^
  Holy Name Medical Center
  Teaneck, NJ
- Stephen C. Textor, M.D., FAHA^*^
  Mayo Clinic
  Rochester, MN
- Katherine Tuttle, M.D., FACP, FASN^*^
  Providence Health Care and University of Washington School of Medicine
  Spokane, WA
- Jonathan Winston, M.D., FAHA, FSVM, FSIR
  Holy Name Medical Center
  Teaneck, NJ