# Discussion

This review included 76 studies that evaluated medical therapy, percutaneous transluminal renal angioplasty with stent placement (PTRAS), or surgical revascularization since approximately 1995 in patients with atherosclerotic renal artery stenosis (ARAS), in addition to the 20 most recent case reports of revascularization in patients with acute decompensation related to ARAS. The review was restricted to primary treatment of patients being treated principally for ARAS, thus, excluding studies of treatment of restenosis or of patients with a transplanted kidney, and revascularization procedures not done primarily for ARAS (e.g., done during endovascular aortic aneurysm or dissection repairs). Among the eligible studies, only five randomized controlled trials (RCT)compared the two most common interventions in current practice, namely PTRAS (with continued medical therapy) and medical therapy alone. However, in only three of these (CORAL, RASCAD, and STAR)19, 24, 32 were all patients treated with “aggressive” or “optimal” medical therapy, namely antihypertensives, a statin, and an antiplatelet drug.

## Summary

The trials of PTRAS versus medical therapy found no difference in long-term outcomes in patients for whom there was equipoise between the two interventions. These results generalize to patients who are similar to those enrolled in the RCTs—patients with a moderate degree of stenosis (e.g., 50–70%), medically controlled hypertension (HTN), relatively stable kidney function, without symptoms such as pulmonary edema, for whom revascularization is an option but not considered necessary in current clinical practice (since the patients and their clinicians had to agree to the possibility of not having PTRAS)—but possibly not to many patients undergoing PTRAS, since, in clinical practice, there is often a strong belief that PTRAS is superior to continued medical therapy alone. Many patients presenting with ARAS would not have qualified for, and thus would not have been enrolled in, the RCTs. In one of the recent prospective studies of PTRAS, 23 percent of patients presenting with ARAS had flash pulmonary edema or rapidly declining kidney function, which would have excluded them from most of the trials. It remains unclear whether PTRAS (with continuation of medical therapy) offers a clinical benefit to patients currently indicated to have PTRAS compared with remaining on medical therapy alone. The relative effectiveness of PTRAS versus continued medical therapy in patients with a high degree of stenosis (e.g., >80%) or commonly used indications for revascularization (refractory HTN, rapid kidney deterioration, or recurrent pulmonary edema) remains unclear. Among the single group (noncomparative) studies, after PTRAS, on average, glomerular filtration rate did not improve, but blood pressure (BP) generally decreased by about 10 to 30 mmHg at the same time that the number of antihypertensive medications used decreased by about 0.5 drugs. In different cohorts of patients, those remaining on medical therapy alone generally had BP decreases by an average of about 5 to 10 mmHg without significant changes in the number of antihypertensive medications used. These differences were not seen in the comparative studies and do not appear to correlate with improvement in clinical outcomes or prevention of cardiovascular events. This apparent discordance may highlight the noncomparability between patient enrolled in RCTs (for whom there is clinical equipoise) or included in single group studies of PTRAS (who are deemed to need revascularization) and medical therapy(who are deemed to not need revascularization).

For the clinical outcomes, there is little suspicion of publication bias. The grey literature search did not reveal any unpublished comparative studies or study results. The recent, larger RCTs powered for clinical outcomes have fully published their findings, per their protocols. Furthermore, the commonly reported “negative” or “null” findings argues against the likelihood that studies or results have not been published because they did not show benefit.

Arguably, given the results of the RCTs, an important question is which factors predict patient response to each intervention. In populations such as those included in the RCTs, some patients may benefit more from medical therapy only and some from PTRAS plus medical therapy, resulting in no difference overall. More generally, for all patients it is important to know which factors would predict better outcomes with PTRAS than medical therapy.

We analyzed noncomparative studies, wherein everyone received a single treatment option (medical therapy alone, PTRAS, or open surgery). We evaluated these studies primarily to gather information about typical responses upon followup (e.g., change in BP or incidence of clinical events) and to evaluate possible predictors of outcomes. These studies generally found a wide range of outcomes among patients who, in separate studies, were treated with medical therapy, PTRAS, or open surgical revascularization. As examples, all-cause death was reported between 9 and 56 percent of patients on medical therapy, between 0 and 53 percent of patients after PTRAS, and in 26 to 36 percent of patients after surgical revascularization. Similarly glomerular filtration rate and SBP changes on medical therapy ranged from −8 to −0.7 mL/min and −22 to −6 mmHg; after PTRAS these outcomes ranged from −9 to 10 mL/min and −51 to 28 mmHg. These wide ranges suggest that there were underlying large differences across noncomparative studies in patient populations included in each study. Examples of such differences include different severity of renal artery stenosis (RAS), baseline BP and kidney function, concomitant cardiovascular disease and other comorbidities. Furthermore, particularly for these studies, it would be flawed to compare outcomes across the three sets of studies (by intervention) since the patients in each study type are even more noncomparable than patients in each study of a particular intervention may be to each other. Noncomparative studies of medical therapy included all patients who had not had an invasive intervention, including immediately after diagnosis. In contrast, noncomparative studies of PTRAS and open surgery for the most part included patients who had failed medical therapy alone, since medical therapy is standard of care regardless of other treatments and if they were doing well on medical therapy alone, no further intervention would have been necessary. Furthermore, patients receiving open surgery generally have some other indication for surgery, even if not well described in the studies, that precluded use of PTRAS.

Data on adverse events were, overall, sparse, particularly for medical therapy. While rates of PTRAS complications varied across studies, in the RCTs, which used rigorous criteria for enrolling and implementing PTRAS and prospectively collected adverse event data, complication rates were low. The relative rarity of reporting of adverse events raises suspicion that adverse events were not captured by study researchers and/or that they were not reported in publications.

## Subgroup and Predictor Analyses

Nevertheless, there is clearly a subset of patients who have improved kidney function and improved BP control after PTRAS compared to their kidney and BP status while on medical therapy alone (pre-PTRAS). There is a strong indication of heterogeneity of treatment effect occurring, such that some patients benefit but others fail to. After PTRAS, in most studies, between 10 and 20 percent of patients have kidney function improvement and about 40 to 80 percent have BP improvement.

The case reports of patients who presented with acute decompensation of their ARAS—namely rapidly developing uncontrollable HTN, acute kidney injury, new onset dialysis, flash pulmonary edema, or other signs of decompensating congestive heart failure—provide anecdotal evidence that this subset of patients can benefit from renal artery revascularization. Certainly, these case reports are not an unbiased sample of such patients. It is striking that all case reports were patients who had successful outcomes, but it is highly unlikely that all patients with acute decompensation benefit from revascularization; particularly those already on dialysis. Descriptions of patients who failed to benefit would be interesting and could potentially yield some insights to predict who may not benefit. Better, a study that includes an unbiased sample of these patients is needed.

Analyses of predictors of outcomes after PTRAS yielded generally inconsistent or not particularly illuminating findings. The trials (CORAL and ASTRAL)19, 20 failed to find factors that describe a putative subset of patients who benefited from PTRAS. The one observational study that reported an analysis of predictors with terms describing the interaction between the predictor factors and intervention (Ritchie 2014) found that patients presenting with flash pulmonary edema with both rapidly declining kidney function and refractory HTN (but not either of the latter conditions alone) had reduced relative rates of death compared with those treated medically.9 This finding comports with the generally good outcomes seen in case reports of patients with acute decompensation. In the observational studies of PTRAS, the most consistent, though not universal, finding was that patients with worse kidney function or BP were most likely to have improvement in those outcomes after PTRAS; though to what degree this is due to regression to the mean is unclear. Studies were not consistent regarding whether patients with bilateral stenosis had significantly different effects on kidney function or BP than patients with unilateral disease. Regarding clinical event outcomes, the most consistent finding was that people with worse cardiovascular risk factors or history of cardiovascular disease were more likely to die or have future cardiovascular events, consistent with what would be found in the general population regardless of treatment.

Across all studies, most patients were elderly (≥65 years), with mean or median ages generally between about 60 and 80 years old. The CORAL trial found no difference in their composite cardiovascular and renal outcome between study participants above and below age 70 years.19 One angioplasty cohort study found no significant difference by age in a similar composite cardiovascular-renal outcome.75 None of the medication alone cohort studies reported on age as an outcome predictor.

The data on whether different intervention techniques (such as different stent types or use of brachytherapy or embolization protection devices) improve outcomes remains sparse, but does not support any specific PTRAS-related technique.

Future publications are expected from the CORAL study that may shed further light on patient-level predictors of outcomes (and of relative effectiveness between PTRAS and medical therapy) and of the relative effect of differences in treatment, such as the use of embolic protection devices or whether translesional pressure gradients were measured, both of which were at the discretion of operators. Of note, SPRINT, a recent multicenter RCT conducted in a general population of adults with hypertension has reported that medical therapy with an systolic BP (SBP) target of 120 mmHg decreased the risk of cardiovascular events by about one-third and mortality by about one-quarter compared to the more-typical target of 140 mmHg. Subgroup analyses, including among patients with cardiovascular disease and with chronic kidney disease have not yet been reported. While this trial suggests that more intensive medical therapy might be clinically beneficial, which would lessen any relative benefit of revascularization, it would be highly speculative to conclude that using a treatment goal of 120 mmHg would be safe or effective in patients with RAS. The medical therapy studies found an average reduction in SBP of only about 5 mmHg; more intensive medical therapy may not succeed in further lowering BP but may increase treatment-related adverse events. Even if SBP were successfully lowered to under 120 mmHg, it is possible that such low BP may be harmful to patients with systemic atherosclerosis and comorbid conditions.

## Comparison With Prior Comparative Effectiveness Review

Since 2007, the comparative study evidence has improved sufficiently to allow us to focus on PTRAS versus medical therapy (and surgery). In the 2006 and 2007 reports, because of limited evidence, studies of PTRA (without stenting) or of either PTRAS or PTRA were included as proxies for evaluation of PTRAS. With the publication of trials of PTRAS specifically, we were able to exclude these studies. Thus, of the two RCTs and eight nonrandomized comparative studies of PTRAS or PTRA included in the 2006 review, only one reported on an analysis of interest to the current review.29 The evidence regarding the principal comparison of interest—PTRAS versus medical therapy—is, therefore, based on almost all recently published studies. Due to the limitations of the new studies, though, the conclusions about the relative benefits and harms of the interventions remain weak. It might be noted that, in contrast with the current review, the strength of evidence in the original reports was graded as “acceptable” for some outcomes. The apparent downgrading of the evidence can be explained by application of the more rigorous, current methodology for evaluating strength of evidence than was used in 2006 and 2007. Similarly, only one of the other comparative studies (of surgery vs. medical therapy34) was included in the original reviews.

The evidence from single-group studies was also mostly from newly published studies since 2007. This includes 35 of 63 single-group studies of PTRAS, 13 of 17 single-group studies of medical therapy, and one of four surgical single-group studies. Similarly, among studies providing evidence for Key Questions 2 and 3 (patient and treatment characteristics as predictors of outcomes) from single intervention groups, 12 of 20 PTRAS studies, both medical therapy studies, and one of the two surgical studies are newly published. While there is currently more evidence about more predictors and outcomes, the studies still do not provide conclusive evidence to support which patients should (or should not) have revascularization over continued medical therapy alone.

## Comparison With Current Clinical Practice Guidelines

The current evidence is in concordance with current clinical practice guidelines, specifically the 2005 American College of Cardiology Foundation/American Heart Association (ACCF/AHA) guideline for the management of patients with peripheral artery disease (including RAS),121 the 2011 ACCF/AHA guideline update (which did not change the original 2005 guideline),122, 123 and the 2014 Society for Cardiovascular Angiography and Interventions (SCAI) expert consensus statement.10

Although this review did not address the comparative effectiveness of different antihypertensive medications and few studies evaluated only a single class of antihypertensive medications or compared effectiveness in patients with unilateral versus bilateral disease, the evidence supports the conclusion that antihypertensive medications reduce BP in most patients with RAS.

The 2011 ACCF/AHA update occurred after publication of the ASTRAL study, but before publication of the CORAL study. The 2014 SCAI consensus statement was able to fully consider both studies. Consistent with the evidence, both guidelines recommend against PTRAS in patients who do not have hemodynamically significant RAS or who do not have signs or symptoms of decompensation. Both guidelines note the limitations regarding the applicability of the patients included in ASTRAL or CORAL. Taking into account the limitations of the evidence, both guidelines state that PTRAS may be an appropriate option for patients with hemodynamically significant RAS. The SCAI consensus statement is more cautious, though, limiting their recommendation to “carefully selected patients.”10 This review found only a low strength of evidence, hampered by imprecision and few RCTs, of possibly no difference in clinical outcomes between PTRAS and medication treatment, but possibly better kidney function and BP control after PTRAS.

Both guidelines recommend revascularization in patients with decompensation. These patients have rarely been included in the RCTs and were not specifically analyzed in the nonrandomized comparative studies. However, the case reports provide anecdotal evidence that these patients may benefit from revascularization.

The guidelines recommend consideration of open surgery for selected patients receiving revascularization, primarily based on anatomy or concomitant aortic disease. The review found low strength of evidence of no difference in mortality or BP control between the two revascularization approaches and inadequate evidence for other outcomes of interest. However, the review does not directly address the types of patients for whom open surgery is recommended. The review also excluded studies of patients receiving concomitant aortic surgery.

In agreement with this review, the SCAI consensus statement found insufficient evidence to make a recommendation regarding use of embolic protection devices during PTRAS. This review did not evaluate glycoprotein IIb/IIIa inhibitors, for which the guideline also stated there is insufficient evidence.

## Possible Reasons for Inconclusive Evidence, Including Study Limitations

There are several plausible reasons why renal artery revascularization may not substantially improve clinical outcomes in individual patients. Primarily, there is substantial overlap in the etiologic factors of aortorenal vascular disease, parenchymal kidney disease, and cardiac and cerebral vascular diseases. While diabetes mellitus, dyslipidemia, and elevated BP are associated with atherosclerotic narrowing of the renal arteries and consequent worsening of BP and kidney function, they are also independently associated with direct kidney injury. Overcoming the renal artery lesion may fail to improve HTN or kidney function, which may be mediated not only by ARAS but also by underlying kidney disease (due to parenchymal disease or prior irreversible damage from ARAS). The underlying pathophysiology and atherosclerotic milieu present in individuals with ARAS is unchanged by PTRAS. Therefore, continuation of aggressive medical therapy (antihypertensives, statins, and antilipid drugs) is still necessary after PTRAS to minimize risk of cardiovascular events (including cardiac, stroke, kidney, aortic aneurysm, and peripheral vascular disease outcomes). Theoretically, some reduction in antihypertensive medication dose or number of drugs may be feasible after PTRAS due to better BP control, but this is not borne out by the limited evidence. However, the complexity in how antihypertensive drug regimens are varied in response to changes in BP (and kidney function in regards to ARBs) in the setting of patients with atherosclerotic disease may make it unrealistic to find a common pattern in changes in drug doses or numbers with treatment.

A number of issues complicate the process of making decisions both for individual patients and for populations of patients. For one, the exact definition of ARAS varies depending on which diagnostic test is used, what threshold for stenosis is preferred, what degree of either resistant HTN or of kidney damage is required, and whether other evidence of atherosclerotic disease is present. Furthermore, the definition and relative importance of these items have been and continue to change as new diagnostic tests are used or existing tests are refined, as definitions of chronic kidney disease change, as treatments for HTN improve, and as techniques and modalities of surgical and percutaneous interventions change and, presumably, improve. In addition, for individual patients, the evaluation of RAS may be complicated by the risks, difficulties, and expense of the diagnostic tests, including acute kidney injury due to contrast dye. In clinical practice, the primary indication for performing renal angiography or other testing to diagnose ARAS is to determine whether a given patient should have revascularization. Patients who are not candidates for revascularization will not benefit from testing since medical therapy—antihypertensives as tolerated, antilipid drugs, and antiplatelet drugs—is identical with or without confirmation of the diagnosis. With the exception of the CORAL trial, which used an angiographic core lab, studies did not implement standardized methods for assessing the degree of artery stenosis to confirm whether they met criteria for PTRAS. The CORAL trial found that the standardized core lab measures of stenosis severity was generally lower than estimates made by individual investigators. The CORAL trial was also the only comparative study that explicitly incorporated translesional pressure gradient measurements into its eligibility criteria and assessment of stenosis severity. Patients with moderate percent stenosis (60–80%) also had to have translesional pressure gradient of >20 mmHg. If PTRAS studies inadvertently included patients with “nonsevere” stenosis (due to poor estimation of percent stenosis or inclusion of people without hemodynamic compromise, as estimated by translesional pressure gradient,124 the studies may be biased to the null, since one would not expect revascularization to be more effective than medical therapy alone in these patients.

Not only did definitions of ARAS vary (affecting eligibility criteria), but the studies also were highly heterogeneous in terms of definitions of outcomes, particularly clinical and categorical outcomes related to BP control and kidney function. Few studies used standard definitions of BP or kidney function improvement or worsening; for the most part, each used an ad hoc definition that varied across studies. Conclusions across studies are therefore limited about incidence and relative rates of these outcomes. Furthermore, most studies (particularly the single group studies) included and analyzed all-comers who had the intervention of interest, regardless of baseline kidney function or BP. This may also have biased the effect of the interventions toward the null as, for example, patients with normal kidney function at baseline would not be expected to have any improvement in kidney function following, for example, PTRAS. However, we did not discern a relationship between average baseline kidney function or BP and outcomes.

For individual patients and their clinicians, the question of what the preferred treatment for ARAS may be is fraught with difficulties largely related to the frequent frailty of these patients and the known complications from any of the interventions. These patients are generally elderly, often with severe cardiovascular disease, including atherosclerosis and diastolic left ventricular dysfunction, often with moderate or severe chronic kidney disease, and with diabetes. Each of the antihypertensive agents carries substantial risks of bothersome and dangerous adverse events, which may be more likely or serious when multiple drugs are used. These drugs in general need to be taken lifelong and may only prevent further worsening of cardiovascular or kidney disease, as opposed to reducing the severity of existing disease. Invasive interventions, whether open or percutaneous, however, also carry risks of immediate death, cardiovascular events, acute and permanent kidney injury, and pain or other effects on quality of life. Also, the procedure may not carry any noticeable benefit to patients, in that they are likely to continue to require antihypertensive medications and may have no survival benefit or lessened risk of cardiovascular events or renal replacement therapy (RRT). Thus the relative overall effectiveness of angioplasty and continued aggressive medical therapy for most patients with ARAS remains unclear. For some patients with acutely worsening kidney or cardiovascular function, anecdotal evidence strongly suggests a benefit from revascularization.

Another limiting issue was that adverse event reporting was generally sparse and not reported in a consistent manner. In particular for adverse events, reporting was different for different interventions. Across all studies, both comparative and single arm, studies reported on adverse events related to PTRAS but not medical therapy. Revascularization studies tended to focus exclusively on periprocedure complications, without considering any RAS-related drug adverse events.

## Future Research

Given the limitation of who could be recruited into trials of PTRAS versus medical therapy, well-analyzed, high-quality observational studies could yield some better insights into whether patients who receive PTRAS based on standards of practice actually do better because of the intervention. Such studies would have to be multicenter and from practices that have different thresholds or criteria for which patients have PTRAS to allow for an overlap across the centers in patients who likely would have continued medical therapy alone at more conservative centers but would have had PTRAS at more aggressive centers. A registry of all patients being considered for revascularization (that, ideally, includes a representative sample of ARAS patients not being considered for revascularization) could provide the basis for future studies that could allow for more generalizable, stronger evidence. In addition, a set of future studies should focus specifically on patients who are proven to have hemodynamically significant RAS, based on a combination of determination of severe percent stenosis (>75–80% thresholds have been used by existing studies) and abnormal translesional pressure gradients (e.g., >20 mmHg systolic gradient) in patients with moderate percent stenosis (e.g., 60–80%).19, 124 Conceptually, it is appropriate to consider invasive treatment only for those people with clinically (or hemodynamically) significant disease. In studies, it is only in these patients that that one would expect a clinical effect of treatment.

It can be argued that nonrandomized comparative studies should be analyzed by propensity score adjustment, where the outcomes are adjusted for each patient’s likelihood of having received PTRAS. Such an analysis could better account for differences between groups due to fundamental differences in treatment assignment (who gets which treatment) and may come close to estimating the associations that theoretically could be found in a RCT in patients who are commonly thought to “require” PTRAS.125–127 However, none of the comparative observational studies performed such an analysis or even sufficiently adjusted their analyses to overcome the inherent clinical differences in patients who go ahead with invasive revascularization and those who continue with medical therapy alone. Therefore, the studies continue to provide an inadequate evaluation of whether the general population of patients for whom PTRAS is thought to be indicated truly benefit from the procedure in terms of the most important patient-centered outcomes of death, RRT, and cardiovascular events. Future, well-conducted, well-analyzed (preferably prospective) observational studies are warranted. The design and implementation of such studies, while not simple, should be easier to implement and less resource intensive than the larger, well-conducted, and complex recent RCTs. Existing larger studies could be reanalyzed both to better compare interventions and to further evaluate potential subgroup differences or predictors of outcomes (e.g., based on stenosis severity or cointerventions)

There have been suggestions to create a national registry of all PTRAS, as discussed at the 2007 MEDCAC Panel discussion of RAS.128 However, there is not consensus that a registry would be of sufficient value to mandate, or if one were created, who specifically should be included. Among the concerns was that a national registry would preclude enrollment of patients into then-ongoing randomized trials. However, now that those trials are complete, this may no longer be a major concern. The main advantages of a national registry of patients undergoing PTRAS would be to better understand who is undergoing the procedure, what their outcomes are, and, most importantly, to better answer Key Questions 2 and 3, namely, what patient and treatment factors predict outcomes. There remains a need for evidence to better define which patients would most (or least) benefit from revascularization. A registry, however, would not be able to compare PTRAS to continued medical therapy, unless somehow a registry were created of patients diagnosed with sufficiently severe RAS who did not undergo revascularization.

As recommended by the Institute of Medicine report on guideline implementation, “[guideline] developers [and guideline] implementers… should collaborate in an effort to align their needs with one another” to best support unbiased guidance.129 Thus, future guidelines on ARAS management would benefit not only on reliance on this and related comprehensive systematic reviews, but also from collaboration among nephrologists, interventional radiologists, interventional cardiologists, vascular surgeons, and other stakeholders.

## Conclusions

Overall, the evidence suggests that PTRAS does not provide a benefit over medical therapy alone in patients for whom there is equipoise between the two intervention approaches. Observational studies suggest that patients with greater indications for PTRAS—specifically worse kidney function (variously defined), higher BP (also variously defined), or flash pulmonary edema—may be more likely to have improved kidney function and BP with PTRAS. Nevertheless, it still remains unknown whether these “high risk” patients have benefits in survival and avoiding cardiovascular events and RRT, compared to remaining on medical therapy. Anecdotal evidence confirms that some patients with acute decompensation due to ARAS benefit clinically from revascularization. There is an intrinsic discordance between the RCTs that ask “how does PTRAS compare with current medical therapy” and observational studies that for the most part ask either “how effective is medical therapy for patients who are thought not to require revascularization” or “how effective is revascularization when used in patients who are thought to require it (usually because of “failed” medical therapy)”. Future studies or reanalyses of data in existing studies are needed to determine the relative effectiveness of PTRAS and medical therapy in patients for whom PTRAS is currently commonly recommended. Since patients who receive PTRAS are generally different in their health status from those who remain on medical therapy alone, propensity score adjustment of large observational datasets may allow for relatively unbiased analyses of these patients by properly accounting for these differences.